# Excluded Studies

Table 1 Excluded studies

Study | Reason for Exclusion
Aasbo et al., 2002^1^ | Anesthesia
Aasvang et al., 2005^2^ | Review
Aeberhard et al., 1999^3^ | Surgical experience data not on hernia recurrence but on other outcomes such as operation time or other complications
Agarwal et al., 2010^4^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Agresta et al., 2009^5^ | Did not address any Key Question
Aigner et al., 2011^6^ | Abstract only
Aitola et al., 1998^7^ | Did not focus sufficiently on a patient population of interest; 18% (9/49) had recurrent hernia
Akbulut et al., 2003^8^ | Did not report any outcomes of interest
Akcaboy et al., 2009^9^ | Anesthesia
Akhtar et al., 1998^10^ | Did not address any Key Question
Akolekar et al., 2008^11^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Alani et al., 2006^12^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Albright et al., 2011^13^ | Nonconcurrent enrollment
Alfieri et al., 2006^14^ | Neurectomy
Altinli et al., 2011^15^ | Abstract only
Amato et al., 2009^16^ | Review
Amid et al., 1994^17^ | Clinical comment
Amid et al., 1996^18^ | Did not address any Key Question
Anadol et al., 2011^19^ | Nonrandomized study that did not attempt to control for selection bias
Anderson et al., 1980^20^ | Antibiotics
Andrew et al., 1994^21^ | Surgical experience data not on hernia recurrence but on other outcomes such as operation time or other complications
Antao et al., 2004^22^ | Nonconcurrent enrollment
Arregui et al., 2005^23^ | Case series
Arvidsson et al., 2000^24^ | Narrative review
Arvidsson et al., 2005^25^ | Did not address any Key Question
Atkinson et al., 2004^26^ | Did not address any Key Question
Aufenacker et al., 2004^27^ | Antibiotics
Awad et al., 2007^28^ | Nonconcurrent enrollment
Aydede et al., 2003^29^ | Did not report any outcomes of interest
Aytac et al., 2004^30^ | Did not address any Key Question
Babineau et al., 2004^31^ | Surgical experience information not specific to laparoscopic hernia repair
Baca et al., 1995^32^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Baca et al., 2000^33^ | Unable to obtain
Balakrishnan et al., 2008^34^ | Case series
Ballantyne et al., 2001^35^ | Case series
Baltazar et al., 1976^36^ | Did not address any Key Question
Bar-Dayan et al., 2004^37^ | Anesthesia
Baris et al., 2003^38^ | Anesthesia
Barkun et al., 1995^39^ | Did not address any Key Question
Barkun et al., 1999^40^ | Only half of the open repairs used a mesh; data on these repairs was not reported separately
Barrat et al., 2003^41^ | Did report any post-treatment outcomes
Barth et al., 1998^42^ | Did not address any Key Question
Batorfi et al., 1995^43^ | Did not report any outcomes comparing procedures
Bay-Nielsen et al., 1999^44^ | Anesthesia
Beddy et al., 2006^45^ | Did not report any outcomes of interest
Beets et al., 1997^46^ | Did not address any Key Question
Bell et al., 2003^47^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Bemdsen et al., 2002^48^ | Did not address any Key Question
Bencini et al., 2004^49^ | Incisional hernia
Ben-David et al., 1995^50^ | Anesthesia
Ben-Haim et al., 2002^51^ | Incisional hernia
Benizri et al., 2006^52^ | Nonconcurrent enrollment
Berndsen et al., 2002^53^ | Did not address any Key Question
Berndsen et al., 2002^54^ | Did not address any Key Question
Berndsen et al., 2007^55^ | Did not address any Key Question
Bessell et al., 1996^56^ | Did not address any Key Question
Bhattacharya et al., 2010^57^ | Anesthesia
Biemans et al., 1998^58^ | Did not address any Key Question
Bilgin et al., 1997^59^ | Abstract only
Billingham et al., 2010^60^ | Review
Birk et al., 1998^61^ | Case series
Bisgaard et al., 2010^62^ | Did not address any Key Question
Bittner et al., 2005^63^ | Review
Bittner et al., 2010^64^ | Case series
Blaser et al., 2011^65^ | Abstract only
Borenstein et al., 2005^66^ | Did not address any Key Question
Bozuk et al., 2003^67^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Brandt et al., 2008^68^ | Background
Bright et al., 2010^69^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Bringman et al., 2001^70^ | Did not address any Key Question
Bringman et al., 2001^71^ | Did not address any Key Question
Brooks et al., 1994^72^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Brunner et al., 2011^73^ | Abstract only
Burney et al., 2004^74^ | Anesthesia
Cahil et al., 1989^75^ | Did not address any Key Question
Callesen et al., 1998^76^ | Did not address any Key Question
Callesen et al., 1998^77^ | Case series
Callesen et al., 1999^78^ | Did not address any Key Question
Callesen et al., 1999^79^ | Confounding by indication
Calliskan et al., 2010^80^ | Neurectomy
Campanelli et al., 2008^81^ | Trial protocol
Canonico et al., 2003^82^ | Review
Casati et al., 2004^83^ | Anesthesia
Castoro et al., 1996^84^ | Did not address any Key Question
Ceccarelli et al., 2008^85^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Celdran et al., 2004^86^ | Antibiotics
Cesana et al., 2011^87^ | Abstract only
Champault et al., 2007^88^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Champault et al., 2011^89^ | Case series
Chan et al., 2004^90^ | Case series
Chan et al., 2004^91^ | Did not address any Key Question
Chan et al., 2011^92^ | Did not address any Key Question
Chawla et al., 2005^93^ | Novel technique
Cheek et al., 1998^94^ | Review
Chowbey et al., 2003^95^ | Case series
Chu et al., 1993^96^ | Case series
Chung et al., 1999^97^ | Review
Cingi et al., 2005^98^ | Did not address any Key Question
Cocks et al., 1998^99^ | Nonconcurrent enrollment
Cohen et al., 1998^100^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Cohen et al., 1998^101^ | Case series
Collaborative group et al., 2000^102^ | Review
Collage et al., 2010^103^ | Clinical comment
Connelly et al., 1997^104^ | Anesthesia
Conroy et al., 1993^105^ | Anesthesia
Corbitt et al., 1991^106^ | Case series
Cornell et al., 1994^107^ | Did not address any Key Question
Courtney et al., 2002^108^ | Did not address any Key Question
Cox et al., 2011^109^ | Abstract only
Craven et al., 2009^110^ | Review
Cunningham et al., 1996^111^ | Did not address any Key Question
Czudek et al., 2009^112^ | Case series
Dallas et al., 2011^113^ | Abstract only
Damamme et al., 1998^114^ | Not English
Daniel et al., 1997^115^ | Case series
Danielsson et al., 1999^116^ | Did not address any Key Question
Dasari et al., 2009^117^ | Retrospective questionnaire data relying on memory
Davenport et al., 2003^118^ | Clinical comment
Davis et al., 1994^119^ | Anesthesia
de Jonge et al., 2008^120^ | Review
de Sa Ribeiro et al., 2010^121^ | Case series
de Vries et al., 2007^122^ | Did not address any Key Question
Decker et al., 1998^123^ | Did not address any Key Question
Dedemadi et al., 2010^124^ | Review
Demiraran et al., 2006^125^ | Anesthesia
Demirbas et al., 2003^126^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
DeTurris et al., 2002^127^ | Review
Deysine et al., 1991^128^ | Did not address any Key Question
Deysine et al., 2006^129^ | Did not address any Key Question
Di Filippo et al., 2006^130^ | Anesthesia
Di Vita et al., 2000^131^ | Did not address any Key Question
Di Vita et al., 2001^132^ | Did not address any Key Question
Di Vita et al., 2005^133^ | Did not address any Key Question
Dick et al., 1996^134^ | Case series
Dickinson et al., 2008^135^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Dierking et al., 1992^136^ | Anesthesia
Dilek et al., 2005^137^ | Did not report any outcomes of interest
Dion et al., 1996^138^ | Data were considering for the surgical experience question, however of the 158 patients undergoing laparoscopic repair, data related to surgical experience were only reported for 118 of them, and the reason for this selection was not reported.
Dorflinger et al., 1984^139^ | Did not address any Key Question
DuBois et al., 1997^140^ | Case series
Dueholm et al., 1989^141^ | Anesthesia
Duff et al., 2007^142^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Edelman et al., 2001^143^ | Did not report any outcomes of interest
Edelman et al., 2002^144^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Edelman et al., 2008^145^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Eker et al., 2011^146^ | Abstract only
Eller et al., 2002^147^ | Case series
El-Radaideh et al., 2006^148^ | Anesthesia
emedicine et al., 2010^149^ | Background
Eno et al., 2000^150^ | Did not report whether mesh was used for open hernia repair
epocrates et al., 2010^151^ | Background
Erhan et al., 2008^152^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Erichsen et al., 1995^153^ | Anesthesia
Erol et al., 2009^154^ | Anesthesia
Ersin et al., 2006^155^ | Did not report any outcomes of interest
EU et al., 2000^156^ | Review
EU Hernia Trialists Collaboration et al., 2002^157^ | Review
Evans et al., 1973^158^ | Antibiotics
Evans et al., 2002^159^ | Surgical experience data not on hernia recurrence but on other outcomes such as operation time or other complications
Fallas et al., 1994^160^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Farooq et al., 2007^161^ | Unable to obtain
Feliu et al., 2004^162^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Feliu et al., 2004^163^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Felix et al., 1995^164^ | Nonconcurrent enrollment
Felix et al., 1995^165^ | Did not report any outcomes comparing procedures
Felix et al., 1996^166^ | Did not report any outcomes comparing procedures
Felix et al., 1997^167^ | Case series
Felix et al., 1999^168^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Fell et al., 1988^169^ | Anesthesia
Ferzli et al., 2004^170^ | Did not address any Key Question
Ferzli et al., 2006^171^ | Case series
Fielding et al., 1995^172^ | Case series
Filipi et al., 1996^173^ | Did not focus sufficiently on a patient population of interest; 18% (9/53) had recurrent hernia.
Fine et al., 2006^174^ | Case series
Fischer et al., 1999^175^ | Narrative review bilateral
Fischer et al., 2000^176^ | Anesthesia
Fitzgibbone et al., 1995^177^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Fleming et al., 2001^178^ | Did not address any Key Question
Forte et al., 2003^179^ | Case series
Friis et al., 1996^180^ | Did not address any Key Question
Fuenfer et al., 1996^181^ | Case series
Fujita et al., 2004^182^ | Confounding by indication
Gao et al., 2010^183^ | Review
Garg et al., 2009^184^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Gholghesaei et al., 2005^185^ | Review
Gianetta et al., 2000^186^ | Did not address any Key Question
Gilbert et al., 2004^187^ | Did not address any Key Question
Gilbert et al., 2006^188^ | Combined narrative review and original data; original data comparing surgeons was not specific to laparoscopy
Gillion et al., 1999^189^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Girao et al., unpublished190 | Did not address any Key Question
Go et al., 1998^191^ | Narrative review
Godfrey et al., 1981^192^ | Anesthesia
Gokcora et al., 1996^193^ | Did not address any Key Question
Golash et al., 2011^194^ | Abstract only
Gontarz et al., 1998^195^ | Abstract only
Gonullu et al., 2002^196^ | Anesthesia
Goodwin et al., 1995^197^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Gramke et al., 2006^198^ | Anesthesia
Grant et al., 2002^199^ | Review
Grant et al., 2002^200^ | Review
Grossmann et al., 1995^201^ | Case series
Grunwaldt et al., 2005^202^ | Narrative review
Gultekin et al., 2007^203^ | Anesthesia
Gunes et al., 2004^204^ | Anesthesia
Gupta et al., 2003^205^ | Anesthesia
Gurleyik et al., 1998^206^ | Did not address any Key Question
Gursoy et al., 1997^207^ | Case series
Guzman-Valdivia et al., 2003^208^ | Did not address any Key Question
Hadzic et al., 2006^209^ | Anesthesia
Hair et al., 2000^210^ | Data for different procedures not reported separately
Haitian et al., 2009^211^ | TEP procedure did not use a mesh, thus the study did not address any Key Question
Hakeem et al., 2010^212^ | Review protocol
Halm et al., 2005^213^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Harjai et al., 2007^214^ | Did not address any Key Question
Hatch et al., 1994^215^ | Case series
Hawasli et al., 2002^216^ | Did not address any Key Question
Hay et al., 1995^217^ | Did not address any Key Question
Hernandez-Granados et al., 2000^218^ | Did not address any Key Question
Hetzer et al., 1993^219^ | Did not address any Key Question
Hidalgo et al., 2005^220^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Hilgert et al., 1999^221^ | Did not address any Key Question
Himpens et al., 1993^222^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Himpens et al., 1997^223^ | TEP procedure did not use a mesh, thus the study did not address any Key Question
Hindmarsh et al., 2003^224^ | Did not report whether mesh was used for open hernia repair
Holcomb et al., 1996^225^ | Case series
Hon et al., 2009^226^ | Anesthesia
Hong et al., 2010^227^ | Anesthesia
Horgan et al., 1996^228^ | Animal research
Horharin et al., 2006^229^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Horstmann et al., 2006^230^ | Nonconcurrent enrollment
Horton et al., 1993^231^ | Case series
Horzia et al., 2006^232^ | Did not address any Key Question
Huang et al., 2005^233^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Hussein et al., 1998^234^ | Case series
Ismail et al., 2009^235^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Jacobs et al., 2004^236^ | Background
Jain et al., 2008^237^ | Antibiotics
Jain et al., 2009^238^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Jani et al., 2005^239^ | Did not address any Key Question
Jansson et al., 2000^240^ | Did not address any Key Question
Janu et al., 1997^241^ | Did not address any Key Question
Janu et al., 1998^242^ | Did not address any Key Question
Jarhult et al., 1999^243^ | Nonconcurrent enrollment
Jeans et al., 2007^244^ | Narrative review
Jenkins et al., 2008^245^ | Background
Jenkinson et al., 1995^246^ | Did not address any Key Question
Jess et al., 2000^247^ | Antibiotics
Joshi et al., 1999^248^ | Anesthesia
Juang et al., 2011^249^ | Case series
Juul et al., 1999^250^ | Did not address any Key Question
Kald et al., 1997^251^ | Did not address any Key Question
Kald et al., 1997^252^ | Nonconcurrent enrollment
Kalman et al., 1995^253^ | Anesthesia
Karakayali et al., 2007^254^ | Did not address any Key Question
Kark et al., 1995^255^ | Case series
Karthikesalingam et al., 2010^256^ | Review
Kaufman et al., 1996^257^ | Case series
Kawji et al., 1999^258^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Kaynak et al., 2007^259^ | Did not address any Key Question
Khajanchee et al., 2001^260^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Khajanchee et al., 2004^261^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Khan et al., 2006^262^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Khan et al., 2010^263^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Khoury et al., 1995^264^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Kimura et al., 1998^265^ | Nonconcurrent enrollment
Kingsley et al., 1998^266^ | Did not address any Key Question
Kingsnorth et al., 1992^267^ | Did not address any Key Question
Kingsnorth et al., 1999^268^ | Clinical comment
Kingsnorth et al., 2000^269^ | Unable to locate
Kingsnorth et al., 2002^270^ | Anesthesia
Kiruparan et al., 1998^271^ | Nonconcurrent enrollment
Klein et al., 2002^272^ | Anesthesia
Klin et al., 2010^273^ | Background
Knapp et al., 1976^274^ | Anesthesia
Knock et al., 1999^275^ | Case series
Kocijan et al., 2010^276^ | Case series
Koinig et al., 2000^277^ | Anesthesia
Koning et al., 2010^278^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Korenstein et al., 2008^279^ | Did not address any Key Question
Korman et al., 1997^280^ | Did not address any Key Question
Koukourou et al., 2001^281^ | Did not address any Key Question
Kovacs et al., 1997^282^ | Did not address any Key Question
Kozol et al., 1997^283^ | Did not address any Key Question
Krahenbuhl et al., 1997^284^ | Surgical experience data not on hernia recurrence but on other outcomes such as operation time or other complications
Krahenbuhl et al., 1998^285^ | Surgical experience data not on hernia recurrence but on other outcomes such as operation time or other complications
Krane et al., 1995^286^ | Anesthesia
Krupinski et al., 1997^287^ | Did not address any Key Question
Kucuk et al., 2010^288^ | Did not address any Key Question
Kuhry et al., 2007^289^ | Review
Kumar et al., 1997^290^ | Anesthesia
Kumar et al., 2002^291^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Kunz et al., 1993^292^ | Did not address any Key Question
Kux et al., 1994^293^ | Did not address any Key Question
Kuzu et al., 2005^294^ | Antibiotics
Lai et al., 1998^295^ | Did not address any Key Question
Lange et al., 2005^296^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Lange et al., 2011^297^ | Review
Lau et al., 2000^298^ | Did not focus sufficiently on a patient population of interest (44% of the TEP group, 14/32, had recurrent hernia, and the other 56% had primary hernia).
Lau et al., 2001^299^ | Did not address any Key Question
Lau et al., 2002^300^ | Anesthesia
Lau et al., 2002^301^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Lau et al., 2002^302^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups (only controlled for age)
Lau et al., 2003^303^ | Case series
Lau et al., 2003^304^ | Review
Lau et al., 2003^305^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Lau et al., 2003^306^ | Confounding by indication: patient clinical factors decided treatment assignment
Lau et al., 2005^307^ | Only included females
Lauscher et al., 2008^308^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Lauscher et al., 2008^309^ | Nonconcurrent enrollment
Lawrence et al., 1995^310^ | Surgical experience data not on hernia recurrence but on other outcomes such as operation time or other complications
Lawrence et al., 1996^311^ | Surgical experience data not on hernia recurrence but on other outcomes such as operation time or other complications
Lawrence et al., 1997^312^ | Surgical experience data not on hernia recurrence but on other outcomes such as operation time or other complications
Lazorthes et al., 1992^313^ | Antibiotics
Lee et al., 2002^314^ | Did not address any Key Question
Lee et al., 2010^315^ | Case series
Leibl et al., 2000^316^ | Did not address any Key Question
Leibl et al., 2005^317^ | Narrative review
Lepere et al., 2000^318^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Lepere et al., 2008^319^ | Did not address any Key Question
Lerut et al., 1998^320^ | Narrative review
Liebl et al., 1999^321^ | Review
Lin et al., 1993^322^ | Anesthesia
Lin et al., 1998^323^ | Anesthesia
Lin et al., 2011^324^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Litwin et al., 1994^325^ | Data were considering for the surgical experience question, however of the 317 patients undergoing laparoscopic repair, data related to surgical experience were only reported for 40 of them, and the reason for this selection was not reported.
Liu et al., 1992^326^ | Did not address any Key Question
Liu et al., 1994^327^ | Case series
Ljem et al., 1997^328^ | Did not address any Key Question
Lobe et al., 1992^329^ | Case series
Lorenz et al., 2000^330^ | Did not address any Key Question
Lotan et al., 2004^331^ | Case series
Lowham et al., 1997^332^ | Narrative review
Lugo Vicente et al., 1995^333^ | Case series
Lukaszczyk et al., 1996^334^ | Confounding by indication: patient clinical factors decided treatment assignment
Machotta et al., 2003^335^ | Anesthesia
Maddern et al., 1993^336^ | Did not address any Key Question
Maddern et al., 1994^337^ | Did not address any Key Question
Maddox et al., 2008^338^ | Case series
Maggiore et al., 2001^339^ | Did not address any Key Question
Mahon et al., 2003^340^ | Considered for the comparison of laparoscopic and open repair for bilateral and recurrent hernia, however the data were not reported separately for these two conditions. Overall 79% of hernias were bilateral (156/198, and 14 of the 156 were also recurrent). Overall, 28% of hernias were recurrent (56/198, and 14 of the 56 were also bilateral).
Malviya et al., 1992^341^ | Anesthesia
Mann et al., 1998^342^ | Narrative review
Mann et al., 1998^343^ | Did not focus sufficiently on a patient population of interest (24% or 12/51 had recurrent hernia, and the other 76% had primary hernia)
Marappan et al., 1996^344^ | Surgical experience data not on hernia recurrence but on other outcomes such as operation time or other complications
Markar et al., 2010^345^ | Review
Markey et al., 1997^346^ | Anesthesia
Massaron et al., 2007^347^ | Nonconcurrent enrollment
Massaron et al., 2008^348^ | Nonconcurrent enrollment
Matsota et al., 2007^349^ | Anesthesia
Matyja et al., 2010^350^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Mayagoitia et al., 2004^351^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Mayagoitia et al., 2006^352^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
McCormack et al., 2005^353^ | Review
McCormack et al., 2005^354^ | Review
McCormack et al., 2008^355^ | Review
McGillicuddy et al., 1998^356^ | Did not address any Key Question
McIntosh et al., 1998^357^ | Comment on cost measurement
McIntosh et al., 2000^358^ | Did not address any Key Question
McNally et al., 2009^359^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Mellinger et al., 2004^360^ | Clinical comment
Memon et al., 1999^361^ | Did not report data comparing the procedures
Memon et al., 2003^362^ | Review
Menakuru et al., 2006^363^ | Case series
Merello et al., 1997^364^ | Abstract only
Merhav et al., 1993^365^ | Anesthesia
Metzger et al., 2001^366^ | Did not address any Key Question
Miedema et al., 2004^367^ | Did not address any Key Question
Miguel et al., 1998^368^ | Case series
Mikkelsen et al., 1996^369^ | Anesthesia
Millikan et al., 1994^370^ | Did not address any Key Question
Miltenberg et al., 1998^371^ | Review
Miyazaki et al., 2001^372^ | Did not address any Key Question
Mok et al., 1998^373^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Mokete et al., 2001^374^ | Did not address any Key Question
Mollen et al., 2007^375^ | Narrative review contralateral
Montupet et al., 2011^376^ | Case series
Moores et al., 1990^377^ | Anesthesia
Morgan et al., 1991^378^ | Did not address any Key Question
Muller-Riemenschneider et al., 2007^379^ | Incisional hernia
Mulroy et al., 1999^380^ | Anesthesia
Murat et al., 2005^381^ | Anesthesia
Muzio et al., 2006^382^ | Surgical experience data not on hernia recurrence but on other outcomes such as operation time or other complications
Naguib et al., 1991^383^ | Anesthesia
Naguib et al., 1995^384^ | Anesthesia
Naja et al., 2005^385^ | Anesthesia
Nathanson et al., 1996^386^ | Did not address any Key Question
Nazir et al., 1996^387^ | Case series
Neagu et al., 2000^388^ | Unable to verify
Negro et al., 2011^389^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Newman et al., 1993^390^ | Surgical experience data not on hernia recurrence but on other outcomes such as operation time or other complications
Nicholson et al., 1999^391^ | Did not address any Key Question
Nienhuijs et al., 2005^392^ | Case series
Nienhuijs et al., 2007^393^ | Review
Nishimura et al., 2000^394^ | Did not address any Key Question
Nixon et al., 2009^395^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Niyogi et al., 2010^396^ | Did not address any Key Question
Nordin et al., 2002^397^ | Did not address any Key Question
Nordin et al., 2003^398^ | Anesthesia
Nordin et al., 2004^399^ | Anesthesia
Nordin et al., 2007^400^ | Anesthesia
Nordin et al., unpublished401 | Did not address any Key Question
Nyhus et al., 1993^402^ | Background
Oberg et al., 2005^403^ | Case series
Obrist et al., 2011^404^ | Abstract only
O’Dwyer et al., 2003^405^ | Anesthesia
Oehlenschlager et al., 2010^406^ | Did not address any Key Question
Ohana et al., 2006^407^ | Did not address any Key Question
O’Hanlon et al., 1996^408^ | Anesthesia
O’Riordain et al., 1998^409^ | Anesthesia
Osuigwe et al., 2006^410^ | Antibiotics
Ozcengiz et al., 2001^411^ | Anesthesia
Ozgediz et al., 2007^412^ | Did not address any Key Question
Ozgun et al., 2002^413^ | Anesthesia
Ozkan et al., 2009^414^ | Anesthesia
Ozmen et al., 2011^415^ | Abstract only
Paajanen, 2003^416^ | Did not address any Key Question
Paajanen et al., 2010^417^ | Nonrandomized study with a multivariate analysis but it did not specifically address any Key Questions (e.g., the open vs laparoscopic comparison in the multivariate analysis included many non-mesh procedures).
Page et al., 2002^418^ | Did not address any Key Question
Paily et al., 2009^419^ | Case series
Pala et al., 2009^420^ | Anesthesia
Panos et al., 1992^421^ | Did not address any Key Question
Panton et al., 1994^422^ | Case series
Papachristou et al., 2002^423^ | Confounding by indication
Papaziogas et al., 2004^424^ | Did not address any Key Question
Pappalardo et al., 1999^425^ | Case series
Pardieck et al., 1998^426^ | Case series
Passariello et al., 2004^427^ | Anesthesia
Paul et al., 1994^428^ | Did not address any Key Question
Pawanindra et al., 2010^429^ | Did not address any Key Question
Payne et al., 1992^430^ | Anesthesia
Payne et al., 1996^431^ | Abstract only
Peiper et al., 1994^432^ | Anesthesia
Pelissier et al., 2006^433^ | Case series
Perez et al., 2005^434^ | Antibiotics
Perko et al., 2011^435^ | Did not address any Key Question
Pessaux et al., 2006^436^ | Antibiotics
Pet≤hßzi et al., 1999^437^ | Case series
Picchio et al., 2004^438^ | Neurectomy
Pierides et al., 2011^439^ | Duplicate of already included article
Platt et al., 1990^440^ | Antibiotics
Podolsky et al., 2010^441^ | Did not address any Key Question
Polat et al., 2003^442^ | Did not report any outcomes of interest
Poobalan et al., 2001^443^ | Did not address any Key Question
Poobalan et al., 2003^444^ | Review
Pradhan et al., 2008^445^ | Anesthesia
Praveen et al., 2009^446^ | Antibiotics
Prieto-Díaz-Chávez et al., 2005^447^ | Did not address any Key Question
Prieto-Diaz-Chavez et al., 2009^448^ | Did not address any Key Question
Prior et al., 1998^449^ | Did not address any Key Question
Pullyblank et al., 2002^450^ | Case series
Purkayastha et al., 2008^451^ | Review
Quilici et al., 1993^452^ | Surgical experience data not on hernia recurrence but on other outcomes such as operation time or other complications
Quilici et al., 1996^453^ | Surgical experience data not on hernia recurrence but on other outcomes such as operation time or other complications
Quilici et al., 2000^454^ | Did not report data comparing the procedures
Rahr et al., 2006^455^ | Did not report any outcomes of interest
Rajapandian et al., 2010^456^ | Case series
Ramon et al., 1998^457^ | Abstract only
Ramshaw et al., 1995^458^ | Nonconcurrent enrollment
Ramshaw et al., 1996^459^ | Nonconcurrent enrollment
Ramshaw et al., 1996^460^ | Case series
Ramshaw et al., 1996^461^ | Nonconcurrent enrollment
Ravichandran et al., 2000^462^ | Neurectomy
Richards et al., 2004^463^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Rizk et al., 1994^464^ | Did not address any Key Question
Rogers et al., 1998^465^ | Fewer than 10 patients enrolled in at least one of the relevant groups
Romsing et al., 2001^466^ | Anesthesia
Ron et al., 2007^467^ | Risk of developing pediatric contralateral hernia
Rose et al., 1999^468^ | Case series
Rosen et al., 2001^469^ | Did not report any outcomes of interest
Rosenberg et al., 2008^470^ | Background
Rowbotham et al., 1998^471^ | Anesthesia
Rudkin et al., 1995^472^ | Did not address any Key Question
Ruhanen et al., 1994^473^ | Anesthesia
Rukas et al., 2000^474^ | Unable to verify
Rulli et al., 1998^475^ | Did not address any Key Question
Rutkow et al., 1993^476^ | Did not address any Key Question
Rutkow et al., 1995^477^ | Case series
Rutkow et al., 2003^478^ | Not an empirical study
Saad et al., 1999^479^ | Case series
Saad et al., 2011^480^ | Case series
Saadawy et al., 2009^481^ | Anesthesia
Saggar et al., 2008^482^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Salameh et al., 2002^483^ | Did not report how many open repairs involved a mesh
Sale et al., 2006^484^ | Did not address any Key Question
Sanabria et al., 2007^485^ | Review
Sanchez-Manuel et al., 2009^486^ | Review
Sandbichler et al., 1996^487^ | Case series
Sandenaa et al., 2001^488^ | Did not address any Key Question
Santoro et al., 2007^489^ | Nonconcurrent enrollment
Saranga Bharathi et al., 2008^490^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Saranga Bharathi et al., 2008^491^ | Background
Sarli et al., 2001^492^ | Simultaneous cholecystectomy
Savarise et al., 2001^493^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Schafer et al., 2010^494^ | Review
Schindler et al., 1991^495^ | Anesthesia
Schmedt et al., 2002^496^ | Review
Schmedt et al., 2005^497^ | Review
Schmidt et al., 2006^498^ | Nonconcurrent enrollment
Schneider et al., 2003^499^ | Did not focus sufficiently on a patient population of interest (21% of patients, 12/56, had recurrent hernia, and the other 79% had primary hernia, and data were not reported separately)
Schrenk et al., 1996^500^ | Did not address any Key Question
Schroder et al., 2004^501^ | Did not address any Key Question
Schultz et al., 1995^502^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Schurz et al., 1995^503^ | Did not report whether mesh was used for open hernia repair
Schwab et al., 2004^504^ | Did not address any Key Question
Schwab et al., 2006^505^ | Nonconcurrent enrollment
Schwab et al., 2008^506^ | Simulated hernia repair
Schwobel et al., 1999^507^ | Case series
Scott et al., 1989^508^ | Anesthesia
Scott et al., 2008^509^ | Review
Shah et al., 2009^510^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Shah et al., 2011^511^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Shamim et al., 2006^512^ | Did not address any Key Question
She et al., 2011^513^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Shehata et al., 2011^514^ | Abstract only
Sherwinter et al., 2010^515^ | Nonconcurrent enrollment
Simons et al., 1996^516^ | Did not address any Key Question
Sinclair et al., 1988^517^ | Anesthesia
Sinha et al., 2006^518^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Smedburg et al., 1984^519^ | Did not address any Key Question
Smeds et al., 2010^520^ | Did not address any Key Question
Smith et al., 2001^521^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Somri et al., 1998^522^ | Anesthesia
Sondenaa et al., 2001^488^ | Did not address any Key Question
Song et al., 2000^523^ | Anesthesia
Sosa et al., 1994^524^ | Case series
Spittal et al., 1992^525^ | Anesthesia
Splinter et al., 1995^526^ | Anesthesia
Srsen et al., 2008^527^ | Did not focus sufficiently on a patient population of interest (17% of patients, 36/216, had recurrent hernia, and the other 83% had primary hernia, and data were not reported separately)
Staerkle et al., 2009^528^ | Case series
Stark et al., 1999^529^ | Surgical experience data not on hernia recurrence but on other outcomes such as operation time or other complications
Steinau et al., 1999^530^ | Case series
Stengel et al., 2004^531^ | Review
Stoker et al., 1994^532^ | Surgical experience data not on hernia recurrence but on other outcomes such as operation time or other complications
Stoppa et al., 1998^533^ | Background
Stylopoulos et al., 2003^534^ | Cost-effectiveness analysis
Subwongcharoen et al., 2002^535^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Sucullu et al., 2010^536^ | Did not report any outcomes of interest
Surana et al., 1993^537^ | Case series
Tagaya et al., 1995^538^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Tai et al., 2011^539^ | Nonrandomized study that did not attempt to control for selection bias
Takahara et al., 1995^540^ | Did not address any Key Question
Tammadon et al., 2005^541^ | Case series
Tamme et al., 2005^542^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Tanovia et al., 2005^543^ | Did not address any Key Question
Tanphiphat et al., 1998^544^ | Did not address any Key Question
Tantia et al., 2009^545^ | Did not report any outcomes comparing procedures
Taylor et al., 1997^546^ | Antibiotics
Teasdale et al., 1982^547^ | Anesthesia
Terzi et al., 2005^548^ | Antibiotics
Tetik et al., 1994^549^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Thaha et al., 2008^550^ | Review
Thapar et al., 2000^551^ | Did not address any Key Question
Thill et al., 1994^552^ | Did not address any Key Question
Topal et al., 1997^553^ | Case series
Topart et al., 2005^554^ | Nonconcurrent enrollment
Toufique et al., 2009^555^ | Case series
Toy et al., 1996^556^ | Case series
Tran et al., 1992^557^ | Did not address any Key Question
Triantafyllidis et al., 2011^558^ | Abstract only
Tsai et al., 2010^559^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Tsakayannis et al., 2004^560^ | Neurectomy
Tschudi et al., 1996^561^ | Surgical experience data not on hernia recurrence but on other outcomes such as operation time or other complications
Tucker et al., 1995^562^ | Case series
Turial et al., 2011^563^ | Case series
Twersky et al., 1995^564^ | Anesthesia
Tzovaras et al., 2007^565^ | Antibiotics
Ulman et al., 1995^566^ | Case series
Unknown author et al., 2004^567^ | Trial synopsis
Ure et al., 2000^568^ | Did not address any Key Question
Vale et al., 2003^569^ | Review
Vale et al., 2004^570^ | Did not address any Key Question
Vallribrera et al., 1997^571^ | Did not address any Key Question
van den Heuvel et al., 2011^572^ | Narrative review
Van Den Tol et al., 1996^573^ | Did not address any Key Question
van der Pool et al., 2010^574^ | Case series
van der Zwaal et al., 2008^575^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Van Hee et al., 1998^576^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
van Veen et al., 2007^577^ | Did not address any Key Question
van Veen et al., 2007^578^ | Did not address any Key Question
van Veen et al., 2008^579^ | Anesthesia
Varshney et al., 1995^580^ | Did not address any Key Question
Velanovich et al., 2000^581^ | Confounding by indication
Velanovich et al., 2006^582^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Velasco et al., 1996^583^ | Nonconcurrent enrollment
Velasco et al., 1998^584^ | Case series
Vidovic et al., 2007^585^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Vincent et al., 2003^586^ | Did not address any Key Question
Vogt et al., 1996^587^ | Did not address any Key Question
Voyles et al., 2002^588^ | Review
Vrijland et al., 2002^589^ | Did not address any Key Question
Waechter et al., 2001^590^ | Anesthesia
Wake et al., 2008^591^ | Review
Wassef et al., 1998^592^ | Anesthesia
Webb et al., 1999^593^ | Review protocol
Weiland et al., 1998^594^ | Wound closure
Welborn et al., 1990^595^ | Anesthesia
Weldon et al., 2004^596^ | Anesthesia
Wennstrom et al., 2004^597^ | Did not address any Key Question
Weyhe et al., 2007^598^ | Narrative review
Weyhe et al., 2007^599^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Wheeler et al., 1993^600^ | Case series
Willaert et al., 2009^601^ | Review protocol
Williams et al., 1999^602^ | Survey of beliefs
Williams et al., 2001^603^ | Anesthesia
Wilson et al., 1995^604^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Wilson et al., 2010^605^ | Did not address any Key Question
Winslow et al., 2004^606^ | Surgical experience data not on hernia recurrence but on other outcomes such as operation time or other complications
Witkowski et al., 2000^607^ | Unable to verify
Woods et al., 2008^608^ | Narrative review
Wulkan et al., 1996^609^ | Case series
Yamamoto et al., 2002^610^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups
Yerdel et al., 2001^611^ | Antibiotics
Zampieri et al., 2008^612^ | Case series
Zeybek et al., 2008^613^ | Did not address any Key Question
Zhao et al., 2009^614^ | Review
Zhu et al., 2009^615^ | Did not report any outcomes of interest
Zib et al., 2002^616^ | Review
Zieren et al., 2003^617^ | Case series
Zigman et al., 1998^618^ | Case series
Zollinger et al., 2003^619^ | Background
Zwaal et al., 2008^620^ | Nonrandomized study that did not attempt to control for possible baseline differences between groups