# Search Strategy

## Electronic Database Searches

The following databases have been searched for relevant information:

Name | Date Limits | Platform/Provider
ClinicalTrials.gov | Searched October 29, 2010 | www.clinicaltrials.gov
The Cochrane Central Register of Controlled Trials (CENTRAL) | Through 2010, Issue 10 | www.thecochranelibrary.com
The Cochrane Database of Methodology Reviews (Methodology Reviews) | Through 2010, Issue 10 | www.thecochranelibrary.com
The Cochrane Database of Systematic Reviews (Cochrane Reviews) | Through 2010, Issue 10 | www.thecochranelibrary.com
Database of Abstracts of Reviews of Effects (DARE) | Through 2010, Issue 10 | www.thecochranelibrary.com
EMBASE (Excerpta Medica) | 1990 through November 4, 2011 | OVID SP
Health Technology Assessment Database (HTA) | Through 2010, Issue 10 | www.thecochranelibrary.com
MEDLINE and PreMEDLINE | 1999 through November 4, 2011 | OVID SP
PubMed | Searched November 17, 2011 | http://www.ncbi.nlm.nih.gov/pubmed
U.K. National Health Service Economic Evaluation Database (NHS EED) | Through 2010, Issue 10 | www.thecochranelibrary.com

## Hand Searches of Journal and Nonjournal Literature

Journals and supplements maintained in ECRI Institute's collections were routinely reviewed. Nonjournal publications and conference proceedings from professional organizations, private agencies, and government agencies were also screened. Other mechanisms used to retrieve additional relevant information included review of bibliographies/reference lists from peer-reviewed and gray literature. (Gray literature consists of reports, studies, articles, and monographs produced by federal and local government agencies, private organizations, educational facilities, consulting firms, and corporations. These documents do not appear in the peer-reviewed journal literature.)

The search strategies employed combinations of freetext keywords as well as controlled vocabulary terms including (but not limited to) the following concepts. The strategy below is presented in OVID syntax; the search was simultaneously conducted across EMBASE and MEDLINE. A parallel strategy was used to search the databases comprising the Cochrane Library.

## Medical Subject Headings (MeSH), EMTREE, PsycINFO and Keywords

[underlined: Conventions]:

OVID

$ | = | truncation character (wildcard)
exp | = | “explodes” controlled vocabulary term (e.g., expands search to all more specific related terms in the vocabulary's hierarchy)
.de. or / | = | limit controlled vocabulary heading
.fs. | = | floating subheading
.hw | = | limit to heading word
.md. | = | type of methodology (PsycINFO)
.mp. | = | combined search fields (default if no fields are specified)
.pt. | = | publication type
.ti. | = | limit to title
.tw. | = | limit to title and abstract fields

PubMed

[mh] | = | MeSH heading
[majr] | = | MeSH heading designated as major topic
[pt] | = | publication type
[sb] | = | subset of PubMed database (In Process, Publisher, Systematic)
[sh] | = | MeSH subheading (qualifiers used in conjunction with MeSH headings)
[tiab] | = | keyword in title or abstract

Topic-Specific Search Terms – Alphabetical Listing

Concept | Controlled Vocabulary | Keywords
Adverse effects | Laparoscopy/ae Patient safety/ | Adverse effect$ Adverse event$ Bowel Bladder Complication$ Injur$ Numbness Patient and safety Recurrence Vascular Visceral
Costs | Cost-benefit analysis/ Cost and cost analysis/ Cost effectiveness analysis/ Laparoscopy/economics | Cost$ Cost benefit analysis Cost?effectiveness
Hernia | Hernia, inguinal/ Inguinal canal Inguinal hernia/ Inguinal region/ | Abdominal Direct Fascia Groin Hernia Hernias Indirect Inguinal
Surgical device | Fibrin glue/ad Laparoscope/ Polypropylenes/ Surgical equipment/ Surgical mesh | Bassini Composix Fibrin glue Hernia Implant$ Intra?peritoneal onlay mesh IPOM Kugel McVay Mesh Mesh plug Polypropylene Prolene PTFE Shouldice Stoppa Suture Synthetic mesh Total extra?peritoneal Transabdominal pre?peritoneal Ugahary
Surgical experience | Inguinal hernia/su Laparoscopic surgery/me Surgery/me | Education Experience Expert$ Knowledge Learning curve Training Volume adj outcome$
Surgical technique | Exp surgical approach/ Exp surgical equipment/ Exp surgical technique/ Hernioplasty/ Herniorrhaphy/ Laparoscopy/me Laparoscopic surgery/ Su.fs. | Extra adj peritoneal Intra adj peritoneal Hernioplast$ Herniorrhaph$ Intraperitoneal onlay mesh IPOM Laparoscop$ Lichtenstein Mesh plug Minimal access laparoscop$ Minimally invasive Open mesh Open and surg$ Preperitoneal TAPP TEP Total extraperitoneal Transabdominal Transperitoneal
Treatment outcome | Clinical effectiveness/ Convalescence/ Length of stay/ Operation duration/ Pain, postoperative/ Pain measurement/ Postoperative complications/ Postoperative pain/ Recurrence/pc Treatment outcome/ | Heal$ Outcome$ Pain Painful

## EMBASE/MEDLINE

Remove overlap, 1990-current

Set Number | Concept | Search Statement
1 | Hernia | Hernia, inguinal/ or inguinal hernia/ or inguinal canal/ or inguinal region/
2 | | ((hernia or hernias) and (groin or inguinal or direct or indirect or fascia or abdominal)).ti,ab.
3 | Combine sets | or/1-2
4 | Surgical technique | Laparoscopy/me or laparoscopic surgery/ or hernioplasty/ or herniorrhaphy/
5 | | Exp surgical approach/ or exp surgical technique/ or exp surgical equipment/ or su.fs.
6 | | (Lichtenstein or open mesh or laparscop$ or extra?peritoneal or intra?peritoneal or pre?peritoneal or hernioplast$ or herniorrhaph$ or (minimal adj (access or invasive)) or transabdominal or transperitoneal or mesh plug).mp. or ((open and surg$) or (extra adj peritoneal) or (intra adj peritoneal)).ti,ab.
7 | Combine sets | or/4-6
8 | Surgical experience | Laparoscopic surgery/ or inguinal hernia/su or surgery/me or laparoscopy/
9 | | (educat$ or train$ or knowledge or experience or expert$ or learning curve or (volume adj2 outcome$)).mp.
10 | Combine sets | 8 and 9
11 | Surgical device | Surgical mesh/ or polypropylene/ or surgical equipment/ or laparoscope/ or fibrin glue/ad
12 | | (mesh or plug or polypropylene or prolene or synthetic or PTFE or prosthesis or prostheses or fibrin glue or suture$ or implant$).mp.
13 | | (Prolene hernia system or mesh plug or composix or kugel or bassini or shouldice or Lichtenstein or mcvay or stoppa or ugahary or “transabdominal pre?peritoneal” or “TAPP” or “TEP” or total extra?peritoneal or “IPOM” or “intra?peritoneal onlay mesh”).mp.
14 | Combine sets | or/11-13
15 | Treatment outcome | Pain, postoperative/ or pain measurement/ or postoperative complications/ or recurrence/pc or treatment outcome/ or convalescence/ or length of stay/ or operation duration/ or (pain and (adverse events or complications)).fs.
16 | | (pain or painful or outcome$ or heal$).mp.
17 | Adverse effects | Laparoscopy/ae or patient safety or ((injur$ and (vascular or visceral or bladder or bowel)) or adverse effect$ or adverse event$ or complication$ or (patient and safety) or recurrence or numbness).mp.
18 | | Treatment outcome/ or clinical effectiveness
19 | Combine sets | or/15-18
20 | Cost | Cost analysis/ or cost-benefit analysis/ or laparoscopy/ec or cost effectiveness analysis/ or cost benefit analysis.mp. or cost$.mp. or cost?effective$.mp.
21 | Combine sets: Hernia, surgical technique or device | 3 and (7 or 14)
22 | Combine sets: Hernia and surgical experience | 3 and 10
23 | Combine sets: Surgical experience and costs, outcomes, adverse effects | 22 and (19 or 20)
24 | Combine sets: Hernia, surgical technique, device, costs, outcomes, adverse effects | 21 and (19 or 20)
25 | Combine sets: | 23 or 24
26 | Limit by date | Limit 25 to yr=“1990-2011”
27 | Eliminate overlap | Remove duplicates from 25
28 | Eliminate pub types | 27 not (letter/ or editorial/ or news/ or comment/ or case report.mp. or case reports/ or note/ or conference paper/ or (letter or editorial or news or comment or case reports).pt.)
29 | Apply trials hedge | 28 and (Randomized controlled trial/ or random allocation/ or double-blind method/ or single-blind method/ or placebos/ or cross-over studies/ or crossover procedure/ or cross over studies/ or double blind procedure/ or single blind procedure/ or placebo/ or latin square design/ or crossover design/ or double-blind studies/ or single-blind studies/ or tripleblind studies/ or random assignment/ or exp controlled study/ or exp clinical trial/ or exp comparative study/ or cohort analysis.mp. or follow-up studies/ or intermethod comparison/ or parallel design/ or control group/ or prospective study/ or retrospective study/ or case control study/ or major clinical study/ or evaluation studies/ or follow-up studies/ or random$.hw. or random$.ti. or placebo$.mp. or ((singl$ or doubl$ or tripl$ or trebl$) and (dummy or blind or sham)).mp. or latin square.mp. or ISRCTN$.mp. or ACTRN$.mp. or (NCT$ not NCT).mp.)
30 | Apply systematic review hedge | 28 and ((research synthesis or pooled).mp. or systematic review/ or meta analysis/ or metaanalysis/ or ((evidence base$ or methodol$ or systematic or quantitative$ or studies or search$).mp. and (review/ or review.pt.)))
31 | Combine | 29 or 30