# Acknowledgments

Several Key Informants declined to be acknowledged; however, we are grateful for their valuable contribution to this report. The Evidence-based Practice Center would like to thank Eileen Erinoff, M.S.L.I.S., and Helen Dunn for providing literature retrieval and documentation management support, and Lydia Dharia for her assistance with the final preparations of the report.