# Abbreviations

AAS: Activity assessment scale
ADV: Adverse event
AHRQ: Agency for Healthcare Research and Quality
ASA: American Society of Anesthesiologists
BMI: Body mass index
CI: Confidence interval
CPPV: Contralateral patent processus vaginalis
EPC: Evidence-based Practice Center
FDA: U.S. Food and Drug Administration
HOSP: Hospital-related outcomes
INSUFF: Insufficient evidence SOE rating
IPOM: Intraperitoneal onlay mesh
IQR: Interquartile range
KQ: Key Question
Lich.: Lichtenstein procedure
MCSD: Minimum clinically significant difference
N: Number of patients
NR: Not reported
OPM: Open preperitoneal mesh
OR: Odds ratio
PCS: Physical Component Summary
PHS: Prolene Hernia System
PP: Polypropylene
PTFE: Polytetrafluoroethylene
PVDF: Polyvinylidene fluoride
QALYs: Quality adjusted life years
QOL: Quality of life
RC: Hernia recurrence
RCT: Randomized controlled trial
RR: Relative risk
RTDA: Return to daily activities
RTW: Return to work
SD: Standard deviation
SF-36: Short Form 36 quality of life instrument
SFN: Satisfaction
SOE: Strength of evidence
TAPP: Transabdominal preperitoneal repair (laparoscopic)
TEP: Totally extraperitoneal repair (laparoscopic)
TOO: Task Order Officer
VAS: Visual analog scale
WW: Watchful waiting