# Acknowledgments

This study was supported by Contract 290-02-0016 from the Agency for Healthcare Research and Quality, Task No. 7. We acknowledge the continuing support of Beth Collins-Sharp, Ph.D., R.N., and Lia Snyder, M.P.H., of AHRQ.

We extend our appreciation to the members of our Technical Expert Panel, listed below. All provided thoughtful advice and input during our research process.

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI International and the University of North Carolina. We particularly acknowledge Timothy Carey, M.D., M.P.H., for insightful comments on the first draft and helpful suggestions throughout the project; Lynn Whitener, Dr.P.H., M.S.L.S., our EPC Librarian; and UNC supporting staff Stacey Williams and Jonathan Ward. We also express our gratitude to RTI staff Tammeka Swinson, Research Analyst, and both Jennifer Drolet, M.A., and Melissa Fisch, B.A., editors.

## Technical Expert Panel

- Susan G. Kornstein, M.D.
- Professor of Psychiatry and Obstetrics and Gynecology
- Virginia Commonwealth University
- Richmond, Virginia

- Anand Kumar, M.D.
- Professor of Psychiatry and Director of Geriatric Ambulatory Care Programs
- University of California
- Los Angeles, California

- John Williams, M.D.
- Professor of Medicine and Psychiatry
- Duke University
- Durham, North Carolina

## AHRQ Contacts

- Beth A.Collins Sharp, Ph.D., R.N.
- Director
- Evidence-based Practice Center Program
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD

- Lia Snyder, M.P.H.
- Task Order Officer
- Evidence-based Practice Center Program
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD