# Results

## Overview of All Key Questions

We identified 2,099 citations from searches and reviews of reference lists. Figure 2 documents the disposition of the 293 articles in this review, working from 884 articles retrieved for full review, 66 included for background, and 525 excluded at this stage (Appendix C). One study of interest could not be retrieved after multiple attempts. We included 293 published articles reporting on 187 studies of good or fair quality: 89 head-to-head randomized controlled trials (RCTs) (94 articles), 57 placebo-controlled RCTs (63 articles), 7 articles on meta-analyses or systematic reviews (7 articles), 20 observational studies (27 articles), and 14 studies of other design (16 articles). We incorporated data from 24 additional placebo-controlled studies for meta-regression only. Evidence tables for included studies, by key question, can be found in Appendix D.

Figure 2. Results of literature search

Reasons for exclusion were based on eligibility criteria or methodological criteria. We excluded 62 studies that originally met eligibility criteria but were later rated as poor quality for internal validity (Appendix E). The two main reasons for rating as poor of RCTs were high loss to followup (more than 40 percent) and lack of intention-to-treat (ITT) analysis. Among meta-analyses, lack of a systematic literature search was the main reason for exclusion; this problem leads to a selected spectrum of trials and subsequently to biased results.

Most efficacy trials were not powered to establish a greater efficacy of a particular drug over another. Therefore, we report differences in effect sizes for individual studies, even if they are not statistically significant.

Of 187 included studies, 126 (67.4 percent) were financially supported by pharmaceutical companies; 17 (9.2 percent) were funded by governmental agencies or independent funds. For 44 (23.5 percent) of included studies, we could not determine the funding source.

Studies reviewed for this report employed a notable array of diagnostic scales and health status or quality of life instruments. Most were pertinent to depressive and other disorders considered in this report, but some are considered more generic instruments that assess, e.g., health-related quality of life. Table 7 lists abbreviations of diagnostic scales and health status or quality of life instruments encountered in this literature.

Table 7 Abbreviations and full names of diagnostic scales and other instruments

Abbreviation | Full Name of Instrument
BDI | Beck Depression Inventory
Beck's SSI | Scale for Suicide Ideation
BIMT | Blessed Information and Memory Test
BPI | Brief Pain Inventory
BQOL | Battelle Quality of Life Measure
BQOLS | Battelle Quality of Life Scale
BSI | Brief Symptom Inventory of Depression
CAS | Clinical Anxiety Scale
CES-D | Center for Epidemiological Studies-Depression Scale
CGI | Clinical Global Impressions
CGI-I | Clinical Global Impressions Improvement Scale
CGI-S | Clinical Global Impressions Severity Scale
CLAS | Clifton Assessment Schedule
DESS | Discontinuation Emergent Signs and Symptoms Checklist
FSCL | Fatigue Symptoms Checklist
FSQ | Functional Status Questionnaire
GAF-S | Global Assessment of Functioning Scale
HAD-A | Hospital Anxiety and Depression Rating Scale
HAM-A | Hamilton Rating Scale for Anxiety
HAM-D | Hamilton Rating Scale for Depression
HADRS | Hamilton Depression Rating Scale
HSCL-D20 | Hopkins Symptom Checklist - Depression
IDAS | Irritability, Depression, and Anxiety Scale
IDS C | Inventory for Depressive Symptomatology - Clinician Rated
IDS SR | Inventory for Depressive Symptomatology - Self Rated
MADRS | Montgomery-Asberg Depression Rating Scale
MAF | Multidimensional Assessment of Fatigue
MMSE | Mini Mental State Examination
PGI-I | Patient Global Impression of Improvement
POMS-FI | Profile of Mood States Fatigue/Inertia Subscale
PRSexDQ | Psychotropic-Related Sexual Dysfunction Questionnaire
QLDS | Quality of Life in Depression Scale
Q-LES-Q, QLSQ | Quality of Life Enjoyment and Satisfaction Questionnaire
SCL 56 | Hopkins Symptom Checklist- 56 item version
SF-36 | Medical Outcomes Study Health Survey - Short Form 36
SIP | Sickness Impact Profile
SLT | Shopping List Task
VAS | Visual Analogue Scale
UKU-SES | Utvalg for Kliniske Undersogelse Side Effect Scale

## Key Question 1: Efficacy or effectiveness in treating depressive disorders and symptoms

1a Do commonly used medications for depression differ in efficacy or effectiveness in treating depressive symptoms in adults with major depressive disorder (MDD), dysthymia, or subsyndromal depressive disorders?
1b If a patient has responded to one agent in the past, is that agent better than current alternatives at treating depressive symptoms?

### Major Depressive Disorder (MDD): Overview

The following second-generation antidepressants are currently approved by the US Food and Drug Administration (FDA) for the treatment of depressive disorders in adults: bupropion, citalopram, duloxetine, escitalopram, fluoxetine, mirtazapine, nefazodone, paroxetine, sertraline, trazodone, and venlafaxine. Fluvoxamine has not been approved for the treatment of MDD but was included on the list of medications of interest that Agency for Healthcare Research and Quality (AHRQ) provided to us for this review.

In all, 72 RCTs (reported in 74 articles) compared the efficacy or effectiveness of one second-generation antidepressant with another for treating patients with MDD. Details can be found in Evidence Table 1, Appendix D.

Table 8 provides selected information on all these studies; they are grouped according to the main classes compared—selective serotonin reuptake inhibitors (SSRI) vs. SSRI, SSRI vs. selective serotonin and norepinephrine reuptake inhibitor (SSNRI) and SNRI; SSRI vs. other second-generation antidepressants—and then listed alphabetically by the specific drugs compared. Most subjects were younger than 60 years; 10 trials were conducted in populations of 60 years or older. In the text below, studies are of fair quality unless otherwise specified.

Table 8 Study characteristics, response and remission rates, and quality ratings of studies in adults with major depressive disorder

Study | N | Duration | Comparison and Dose (mg/d) | Response (%) and Significance Level | Remission (%) and Significance Level | Quality Rating
SSRIs vs. SSRIs
Burke et al., 2002 ^24^ | 491 | 8 weeks | Citalopram 40 | 45.6 vs. 51.2 | NR | Fair
| | | Escitalopram 20 | P = NR (ns)
| | 8 weeks | Citalopram 40 | 45.6 vs. 50 | NR
| | | Escitalpram 10 | P = NR (ns)
Colonna et al., 2005 ^25^ | 357 | 8 weeks | Citalopram 20 | 55 vs. 63 | 45 vs. 55 | Fair
| | | Escitalopram 10 | P < 0.05 | P = NR
| | 24 weeks | Citalopram 20 | 78 vs. 80 | 71 vs. 76
| | | Escitalopram 10 | P = NR (ns) | P = NR
Lepola et al., 2003 ^26^ | 471 | 8 weeks | Citalopram 20–40 | 52.6 vs. 63.7 | 42.8 vs. 52.1 | Fair
| | | Escitalopram 10–20 | P = 0.021 | P = 0.036
Moore et al., 2005 ^27^ | 280 | 8 weeks | Citalopram 40 | 61.3 vs. 76.1 | 43.6 vs. 56.1 | Fair
| | | Escitalopram 20 | P = 0.008 | P = 0.04
Patris et al., 1996 ^28^ | 357 | 8 weeks | Citalopram 20 | 78 vs. 76 | 75 vs. 68 | Fair
| | | Fluoxetine 20 | P = NR (ns) | P = 0.26
Haffmans et al., 1996 ^29^ | 217 | 6 weeks | Citalopram 20–40 | 30.5 vs. 28.4 | 14 vs. 8 | Fair
| | | Fluvoxamine 100–200 | P = NR | P = NR (ns)
Ekselius et al., 1997 ^30^ | 400 | 24 weeks | Citalopram 20–60 | 81 vs. 75.5 | NR | Good
| | | Sertraline 50–150 | P = NR (ns)
Kasper et al., 2005 ^31^ | 518 | 8 weeks | Escitalopram 10 | 46 vs. 37 | 40 vs. 30 | Fair
| | | Fluoxetine 20 | P = NR (ns) | P = NR (ns)
Dalery and Honig, 2003 ^32^ | 184 | 6 weeks | Fluoxetine 20 | 60 vs. 60 | NR | Fair
| | | Fluvoxamine 100 | P = NR (ns)
Rapaport et al., 1996 ^33^ | 100 | 7 weeks | Fluoxetine 20–80 | NR | NR | Fair
| | | Fluvoxamine 100–150
Cassano et al., 2002 ^34^ | 242 | 52 weeks | Fluoxetine 20–60 | NR | NR | Fair
| | | Paroxetine 20–40
Chouinard et al., 1999 ^35^ | 203 | 12 weeks | Fluoxetine 20–80 | 68.4 vs. 67 | 59.2 vs. 58 | Fair
| | | Paroxetine 20–50 | P = 0.93 | P = 0.84
De Wilde et al., 1993 ^36^ | 100 | 6 weeks | Fluoxetine 20–60 | 62 vs. 67 | NR | Fair
| | | Paroxetine 20–40 | P = NR
Fava et al., 1998 ^37^ | 128 | 12 weeks | Fluoxetine 20–80 | NR | NR | Fair
| | | Paroxetine 20–50
Gagiano et al., 1993 ^38^ | 90 | 6 weeks | Fluoxetine 20–60 | 63 vs. 70 | NR | Fair
| | | Paroxetine 20–40 | P = NR
Schöne and Ludwig, 1993 ^39^ | 108 | 6 weeks | Fluoxetine 20–60 | 37.5 vs. 16 | NR | Fair
| | | Paroxetine 20–40 | P = 0.03
Tignol, 1993 ^40^ | 178 | 6 weeks | Fluoxetine 20 | 78 vs. 75 | NR | Fair
| | | Paroxetine 20 | P = NR (ns)
Fava et al., 2002 ^41^ | 284 | 10–16 weeks | Fluoxetine 20–60 | 64.8 vs. 68.8 vs. 72.9 | 54.4 vs. 57.0 vs. 59.4 | Fair
| | | Paroxetine 20–60 | P = NR | P = NR
| | | Sertraline 50–200
Bennie et al., 1995 ^42^ | 286 | 6 weeks | Fluoxetine 20–40 | 51 vs. 59 | NR | Fair
| | | Sertraline 50–100 | P = NR
Boyer et al., 1998 ^43^ | 242 | ≈ 26 weeks | Fluoxetine 50–150 | 42.6 vs. 47.4 | NR | Fair
| | | Sertraline 20–60 | P = NR
Newhouse et al., 2000 ^44,^ ^45^ | 236 | 12 weeks | Fluoxetine 20–40 | 71 vs. 73 | 46 vs. 45 | Fair
| | | Sertraline 50–100 | P = NR | P = NR
Sechter et al., 1999 ^46^ | 234 | 24 weeks | Fluoxetine 20–60 | 64 vs. 74 | NR | Fair
| | | Sertraline 50–150 | P = NR
Van Moffaert et al., 1995 ^47^ | 165 | 8 weeks | Fluoxetine 20 | Data NR | NR | Fair
| | | Sertraline 50 | P = NR (ns)
Fava et al., 2000 ^48^ | 284 | 26–32 weeks | Fluoxetine 20–60 | NR | NR | Fair
| | | Sertraline 50–200
| | | Paroxetine 20–60
Kroenke et al., 2001 ^49^ | 601 | 36 weeks | Fluoxetine 20 | NR | NR | Fair
| | | Sertraline 50
| | | Paroxetine 20
Kiev and Fieger, 1997 ^50^ | 60 | 7 weeks | Fluvoxamine 50–150 | Data NR | NR | Fair
| | | Paroxetine 20–50 | P = NR (ns)
Nemeroff et al., 1995 ^51^ | 95 | 7 weeks | Fluvoxamine 50–150 | Data NR | NR | Fair
| | | Sertraline 50–200 | P = NR (ns)
Rossini et al., 2005 ^52^ | 93 | 7 weeks | Fluvoxamine 150 | Dat NR | NR | Fair
| | | Sertraline 200 | P = NR (ns)
Aberg-Wistedt et al., 2000 ^53^ | 353 | 8 weeks | Paroxetine 20–40 | 63 vs. 63 | 57.3 vs. 51.6 | Fair
| | | Sertraline 50–150 | P = NR (ns) | P = NR (ns)
| 353 | 24 weeks | Paroxetine 20–40 | 69 vs. 72 | 73.7 vs. 80.2
| | | Sertraline 50–150 | P = NR (ns) | P = NR (ns)
SSRIs vs. SSNRIs and SNRIs
Leinonen et al., 1999 ^54^ | 270 | 8 weeks | Citalopram 20–60 | 88 vs. 85 | NR | Fair
| | | Mirtazapine 15–60 | P = 0.54
| | | | Faster onset of mirtazapine
Allard et al., 2004 ^55^ | 150 | 22 weeks | Citalopram 10–30 | 93 vs. 93 | 23 vs. 19 | Fair
| | | Venlafaxine XR 75–150 | P = NR (ns) | P = NR (ns)
Bielski et al., 2004 ^56^ | 198 | 8 weeks | Escitalopram 20 | 61 vs. 48 | 36 vs. 32 | Fair
| | | Venlafaxine XR 225 | P = NR (ns) | P = NR (ns)
Montgomery et al., 2004 ^57^ | 293 | 8 weeks | Escitalopram 10–20 | 77 vs. 80 | 70 vs. 70 | Fair
| | | Venlafaxine XR 75–150 | P = NR (ns) | P = NR (ns)
Goldstein et al., 2002 ^58^ | 173 | 8 weeks | Fluoxetine 20 | 45 vs. 49 | 30 vs. 43 | Fair
| | | Duloxetine 40–120 | P = 0.39 | P = 0.82
Hong et al., 2003 ^59^ | 133 | 6 weeks | Fluoxetine 20–40 | 51 vs. 58 | 27 vs. 35 | Fair
| | | Mirtazapine 15–45 | P = NR (ns) | P = NR (ns)
| | | | Faster onset of mirtazapine
Versiani et al., 2005 ^60^ | 297 | 8 weeks | Fluoxetine 20–40 | Data NR | 41.4 vs. 40.1 | Fair
| | | Mirtazapine 15–60 | P = NR (ns) | P = NR (ns)
| | | | Faster onset of mirtazapine
Wheatley et al., 1998 ^61^ | 133 | 6 weeks | Fluoxetine 20–40 | Data NR | 25.4 vs. 23.3 | Fair
| | | Mirtazapine 15–60 | P = NR (ns) | P = NR (ns)
| | | | Faster onset of mirtazapine
Alves et al., 1999 ^62^ | 87 | 12 weeks | Fluoxetine 20–40 | 74 vs. 87 | 41 vs. 51 | Fair
| | | Venlafaxine 75–150 | P = NR | P = NR
Costa e Silva, 1998 ^63^ | 382 | 8 weeks | Fluoxetine 20–40 | 82 vs. 86.8 | 60.2 vs. 60.2 | Fair
| | | Venlafaxine 75–225 | P = 0.074 | P = NR
De Nayer et al., 2002 ^64^ | 146 | 12 weeks | Fluoxetine 20–40 | 49.3 vs. 75 | 40.3 vs. 59.4 | Fair
| | | Venlafaxine 75–150 | P = 0.001 | P = 0.028
Dierick et al., 1996 ^65^ | 314 | 8 weeks | Fluoxetine 20 | 60 vs. 72 | NR | Fair
| | | Venlafaxine 75–150 | P = 0.023
| | | | (at week 6)
Nemeroff and Thase, 2005 ^66^ | 308 | 6 weeks | Fluoxetine 20–60 | 45 vs. 53 | 28 vs. 32 | Fair
| | | Venlafaxine 75–225 | P = 0.034 | P = 0.250
Rudolph and Feiger, 1999 ^67^ | 301 | 8 weeks | Fluoxetine 20–60 | 50 vs. 57 | 22 vs. 37 | Fair
| | | Venlafaxine XR 75–225 | P = 0.07 | P < 0.05
Silverstone and Ravindran, 1999 ^68^ | 368 | 12 weeks | Fluoxetine 20–60 | 62 vs. 67 | NR | Fair
| | | Venlafaxine XR 75–225 | P < 0.05
Tzanakaki et al., 2000 ^69^ | 109 | 6 weeks | Fluoxetine 60 | 66 vs. 70 | 36 vs. 41 | Fair
| | | Venlafaxine 225 | P = NR | P = NR
Tylee et al., 1997 ^70^ | 341 | 12 weeks | Fluoxetine 20 | 62.8 vs. 55.1 | 34.1 vs. 35.4 | Fair
| | | Venlafaxine 75 | P = NR | P = NR (ns)
Detke et al., 2004 ^71^ | 367 | 8 weeks | Paroxetine 20 | 74 vs. 65 vs. 71 | 44 vs. 46 vs. 52 | Fair
| | | Duloxetine 80 | P = NR (ns) | P = NR (ns)
| | | Duloxetine 120
Benkert et al., 2000 ^72^ | 275 | 6 weeks | Paroxetine 20–40 | 53.7 vs. 58.3 | 34.1 vs. 40.9 | Fair
| | | Mirtazapine 15–45 | P = NR (ns) | P = NR (ns)
| | | | Faster onset of mirtazapine
Schatzberg et al., 2002 ^73^ | 255 | 8 weeks | Paroxetine 20–40 | 56.7 vs. 64.0 | NR | Fair
| | | Mirtazapine 15–45 | P = NR (ns)
| | | | Faster onset of mirtazapine
Ballus et al., 2000 ^74^ | 84 | 12 weeks | Paroxetine 20–40 | NR | 33 vs. 57 | Fair
| | | Venlafaxine 75–150 | P = NR (ns) | P = 0.011
| | 24 weeks | Paroxetine 20–40 | 49 vs. 59 | NR
| | | Venlafaxine 75–150 | P = NR (ns) | P = NR (ns)
McPartlin et al., 1998 ^75^ | 361 | 12 weeks | Paroxetine 20 | 76 vs. 76 | 46 vs. 48 | Fair
| | | Venlafaxine XR 75 | P = NR (ns) | P = NR (ns)
Behnke et al., 2003 ^76^ | 345 | 8 weeks | Sertraline 50–150 | NR | NR | Fair
| | | Mirtazapine 30–45 | P = NR (ns)
| | | | Faster onset of mirtazapine
Mehtonen et al., 2000 ^77^ | 147 | 8 weeks | Sertraline 50–100 | 68 vs. 83 | 45 vs. 68 | Good
| | | Venlafaxine 75–150 | P = 0.05 | P = 0.008
Sir et al., 2005 ^78^ | 163 | 8 weeks | Sertraline 50–150 | 70.9 vs. 70.9 | 59.5 vs. 54.4 | Good
| | | Venlafaxine XR 75–225 | P = 0.95 | P = 0.47
SSRIs vs. other second-generation antidepressants
Coleman et al., 2001 ^79^ | 456 | 8 weeks | Fluoxetine 20–60 | 57 vs. 56 | 40 vs. 47 | Fair
| | | Bupropion SR 150–400 | P = NR (ns) | P = NR (ns)
Feighner et al., 1991 ^80^ | 123 | 6 weeks | Fluoxetine 20–80 | 58 vs. 63 | NR | Fair
| | | Bupropion 225–450 | P = NR (ns)
Rush et al., 1998 ^81^ | 85 | 8 weeks | Fluoxetine 20–40 | 45 vs. 47 | NR | Fair
| | | Nefazodone 200–500 | P = NR (ns)
Beasley et al., 1991 ^82^ | 126 | 6 weeks | Fluoxetine 20–60 | 62 vs. 69 | 51 vs. 42 | Fair
| | | Trazodone 100–400 | P = NR (ns) | P = NR (ns)
Perry et al., 1989 ^83^ | 40 | 6 weeks | Fluoxetine 20–60 | NR | NR | Fair
| | | Trazodone 50–400
Weihs et al., 2000 ^84^ | 100 | 6 weeks | Paroxetine 10–40 | 77 vs. 71 | NR | Fair
| | | Bupropion SR 100–300 | P = NR (ns)
Baldwin et al., 1996 ^85^ | 206 | 8 weeks | Paroxetine 20–40 | 60 vs. 58 | NR | Fair
| | | Nefazodone 200–600 | P = NR (ns)
Hicks et al., 2002 ^86^ | 40 | 8 weeks | Paroxetine 20–40 | P = NR (ns) | NR | Fair
| | | Nefazodone 400–600
Kasper et al., 2005 ^87^ | 108 | 6 weeks | Paroxetine 20–40 | 91 vs. 87 | 68 vs. 69 | Fair
| | | Trazodone 150–450 | P = NR (ns) | P = NR (ns)
Coleman et al., 1999 ^88^ | 364 | 8 weeks | Sertraline 50–200 | 61 vs. 66 | NR | Fair
| | | Bupropion SR 150–400 | P = NR (ns)
Croft et al., 1999 ^89^ | 360 | 8 weeks | Sertraline 50–200 | 68 vs. 66 | NR | Fair
| | | Bupropion SR 150–400 | P = NR (ns)
Kavoussi et al., 1997 ^90^ | 248 | 16 weeks | Sertraline 50–200 | NR | NR | Fair
Rush et al., 2001 ^91^ | | | Bupropion SR 100–300
Feiger et al., 1996 ^92^ | 160 | 6 weeks | Sertraline 50–200 | 57 vs. 59 | NR | Fair
| | | Nefazodone 100–600 | P = NR (ns)
SSNRIs and SNRIs vs. SNRIs
Guelfi et al., 2001 ^93^ | 157 | 8 weeks | Mirtazapine 45–60 | 62 vs. 52 | NR | Fair
| | | Venlafaxine 225–375 | P = NR (ns)
SNRIs vs. other second-generation antidepressants
Halikas, 1995 ^94^ | 150 | 6 weeks | Mirtazapine 5–35 | 51 vs. 41 | NR | Fair
| | | Trazodone 40–280 | P = NR (ns)
van Moffaert et al., 1995 ^95^ | 200 | 6 weeks | Mirtazapine 24–72 | 61 vs. 51 | NR | Fair
| | | Trazodone 150–450 | P = NR
Cunningham et al., 1994 ^96^ | 225 | 6 weeks | Venlafaxine 75–200 | 72 vs. 60 | NR | Fair
| | | Trazodone 150–400 | P = NR (ns)
Other second-generation antidepressants vs. other second-generation antidepressants
Weisler et al., 1994 ^97^ | 124 | 6 weeks | Bupropion 225–450 | 55.9 vs. 40.4 | 46 vs. 31 | Fair
| | | Trazodone 150–400 | P = NR | P = NR

NR, not reported; ns, not significant.

Note: Venlafaxine not otherwise specified refers to the immediate-release formulation (given twice a day), venlafaxine XR is the extended-release formulation.

In general, studies enrolled patients according to a criteria-based diagnosis of MDD relating to the Diagnostic and Statistical Manual of Mental Disorders (DSM, either revised third edition or fourth edition [DSM-III-R, DSM-IV]) and a predefined cutoff point of a widely used depression scale (i.e., Hamilton Rating Scale for Depression [HAM-D] = 18 or Montgomery-Asberg Depression Rating Scale [MADRS] = 19). Most patients had moderate to severe depression as measured by a variety of scales. Most studies excluded patients who had additional Axis I disorders, high suicidal risk, or progressive medical diseases or who used psychotherapy, electroconvulsive therapy, or psychotropic medications.

Of 66 possible comparisons of included second-generation antidepressants (51 involving SSRIs, 15 more involving non-SSRI agents), we found direct head-to-head evidence for only 35 comparisons (30 and 5, respectively). Tables 9 and 10 depict possible comparisons and the numbers of available head-to-head trials for each comparison (shown in italics). For those with fewer than three head-to-head trials, we conducted indirect comparisons. Appendix E presents placebo-controlled studies included for indirect comparisons; Appendix F lists studies excluded from indirect comparisons because of poor internal validity.

Table 9 Possible comparisons of second-generation antidepressants involving SSRIs and number of included head-to-head trials

Comparison | Number of Studies
SSRIs vs. SSRIs
Citalopram vs. Escitalopram | 4
Citalopram vs. Fluoxetine | 1
Citalopram vs. Fluvoxamine | 1
Citalopram vs. Paroxetine | 0
Citalopram vs. Sertraline | 1
Escitalopram vs. Fluoxetine | 1
Escitalopram vs. Fluvoxamine | 0
Escitalopram vs. Paroxetine | 0
Escitalopram vs. Sertraline | 0
Fluoxetine vs. Fluvoxamine | 2
Fluoxetine vs. Paroxetine | 10
Fluoxetine vs. Sertraline | 8
Fluvoxamine vs. Paroxetine | 1
Fluvoxamine vs. Sertraline | 2
Paroxetine vs. Sertraline | 4
SSRIs vs. SSNRIs
Citalopram vs. Duloxetine | 0
Escitalopram vs. Duloxetine | 0
Fluoxetine vs. Duloxetine | 1
Fluvoxamine vs. Duloxetine | 0
Paroxetine vs. Duloxetine | 1
Sertraline vs. Duloxetine | 0
SSRIs vs. SNRIs
Citalopram vs. Mirtazapine | 1
Citalopram vs. Venlafaxine | 1
Escitalopram vs. Mirtazapine | 0
Escitalopram vs. Venlafaxine | 2
Fluoxetine vs. Mirtazapine | 3
Fluoxetine vs. Venlafaxine | 9
Fluvoxamine vs. Mirtazapine | 0
Fluvoxamine vs. Venlafaxine | 0
Paroxetine vs. Mirtazapine | 2
Paroxetine vs. Venlafaxine | 2
Sertraline vs. Mirtazapine | 1
Sertraline vs. Venlafaxine | 2
SSRIs vs. Other Second-Generation Antidepressants
Citalopram vs. Bupropion | 0
Citalopram vs. Nefazodone | 0
Citalopram vs. Trazodone | 0
Escitalopram vs. Bupropion | 0
Escitalopram vs. Nefazodone | 0
Escitalopram vs. Trazodone | 0
Fluoxetine vs. Bupropion | 2
Fluoxetine vs. Nefazodone | 1
Fluoxetine vs. Trazodone | 2
Fluvoxamine vs. Bupropion | 0
Fluvoxamine vs. Nefazodone | 0
Fluvoxamine vs. Trazodone | 0
Paroxetine vs. Bupropion | 1
Paroxetine vs. Nefazodone | 2
Paroxetine vs. Trazodone | 1
Sertraline vs. Bupropion | 3
Sertraline vs. Nefazodone | 1
Sertraline vs. Trazodone | 0

Table 10 Possible comparisons of second-generation antidepressants involving SSNRIs, SNRIs, and other antidepressants and number of included head-to-head trials

Comparison | Number of Studies
SSNRIs and SNRIs vs. SNRIs
Duloxetine vs. Venlafaxine | 0
Duloxetine vs. Mirtazapine | 0
Mirtazapine vs. Venlafaxine | 1
SSNRIs vs. Other Second-Generation Antidepressants
Duloxetine vs. Bupropion | 0
Duloxetine vs. Nefazadone | 0
Duloxetine vs. Trazodone | 0
SNRIs vs. Other Second-Generation Antidepressants
Mirtazapine vs. Bupropion | 0
Mirtazapine vs. Nefazodone | 0
Mirtazapine vs. Trazodone | 2
Venlafaxine vs. Bupropion | 0
Venlafaxine vs. Nefazadone | 0
Venlafaxine vs. Trazodone | 1
Other Second-Generation Antidepressants vs. Other Second-Generation Antidepressants
Bupropion vs. Nefazadone | 0
Bupropion vs. Trazodone | 1
Nefazadone vs. Trazodone | 0

Investigators rarely assessed quality of life and functional capacity; if they did, they typically considered these as only secondary outcomes. Most studies employed both physician-rated scales (e.g., HAM-D, MADRS, Clinical Global Impressions Scale [CGI]) and patient-rated scales (e.g., Hospital Anxiety and Depression Rating Scale [HAD-A], Battelle Quality of Life Scale [BQOLS]). All studies used physician-rated scales to assess the main outcome measures.

In the majority of studies, the primary endpoints were either changes from baseline or rates of response or remission on investigator-rated diagnostic depression scales such as the HAM-D or MADRS. Changes on such diagnostic depression scales are generally viewed as intermediate outcomes rather than health outcomes, and they are not always reliably related to changes in health outcomes. Response or remission, even when deducted from such a scale (e.g., response is defined as a 50 percent improvement of scores on HAM-D or MADRS), could be seen as proxies to health outcomes. Therefore, we focused on differences in response or remission rates rather than differences in changes of scores.

Most studies received a fair rating for internal validity. The applicability of the results was hard to determine and might often be limited. Most trials (70 percent) were of short (6 weeks to 8 weeks) or medium (9 weeks to 11 weeks) duration; 30 percent reported followup of 12 weeks or more. Short-term studies may be limited in their ability to account appropriately for response rates and long-term adverse events. In addition, reviewed studies were conducted over a time span of 2 decades. Therefore, study populations might vary with respect to cotreatment, prior exposures to other second-generation antidepressants, and other factors.

Trial reporting was often incomplete. Most articles did not report the method of randomization or allocation concealment. Last-observation-carried-forward methods (or LOCF analysis, which means that the last observed measurement serves as the substitute for missing values because of the drop out of patients at different time points) were a frequent approach to ITT analysis. Few authors, however, reported the overall number of patients lost to followup from randomization to the end of the trial. In addition, many studies did not report the ethnic backgrounds of participants.

Loss to followup (number of patients randomized who did not proceed to endpoint), a potential source of bias, was a frequent problem for internal validity. Only 14 trials (17.5 percent) reported a loss to followup of less than 20 percent. The high drop-out rates for many studies may be attributable to specific characteristics of a psychiatric outpatient population and a high rate of adverse events in the examined drug class.

### Major Depressive Disorders: Key Points

Seventy-two head-to-head comparisons (Table 9) were available for a total of 35 potential comparisons between the 12 second-generation antidepressants addressed in this report. Of these, only five trials ^93^ – ^97^ directly compared any non-SSRI second-generation antidepressant to any other non-SSRI agent (Table 10); of these, only one comparison was evaluated in more than one trial. The strength of evidence, overall for comparative efficacy and effectiveness, was rated moderate. Overall, 38 percent of patients did not achieve a treatment response during 6 weeks to 12 weeks of treatment with second-generation antidepressants; 54 percent did not achieve remission.

Direct evidence was considered sufficient to conduct meta-analyses for four drug-drug comparisons:

- Citalopram vs. escitalopram (four published studies ^24^ – ^27^ and one FDA review; ^98^ 1,545 patients): Patients on escitalopram had an additional treatment effect of a 1.25 point reduction (95% CI, 0.10–2.39; P = 0.02) on the MADRS compared with patients on citalopram. The relative risk of response was statistically significantly greater for escitalopram than for citalopram (RR, 1.14; 95% CI, 1.04–1.26). The number needed to treat (NNT) to gain one additional responder at week 8 with escitalopram was 14 (95% CI, 7–111). Both drugs are produced by the same manufacturer, which funded all available studies.
- Fluoxetine vs. paroxetine (seven studies; ^35^ – ^41^ 950 patients): We did not find any statistically significant differences in either effect sizes on HAM-D or response rates between fluoxetine and paroxetine. Fluoxetine had an additional reduction of 0.55 (95% CI, -1.4–0.36; P = 0.23) points on HAM-D compared with paroxetine; paroxetine led to a higher rate of responders than fluoxetine (RR, 1.09; 95% CI, 0.99–1.21).
- Fluoxetine vs. sertraline (four studies; ^41,^ ^42,^ ^44,^ ^46^ 940 patients): Patients on sertraline had an additional, statistically nonsignificant treatment effect of a 0.75 point reduction (95% CI, -0.45–1.95) on the HAM-D scale compared with patients on fluoxetine. The relative risk of response was statistically significantly greater for sertraline than for fluoxetine (RR, 1.11; 95% CI, 1.01–1.21). The NNT to gain one additional responder at 6 to 12 weeks with sertraline was 14 (95% CI, 8–22).
- Fluoxetine vs. venlafaxine (eight studies; ^62^ – ^67,^ ^69,^ ^70^ 1,814 patients): Patients on venlafaxine had an additional, statistically nonsignificant treatment effect of a 1.31 point reduction (95% CI, 0.10–2.39; P = 0.13) on the HAM-D scale compared with patients on fluoxetine. The relative risk of response was statistically significantly greater for venlafaxine than for fluoxetine (RR, 1.12; 95% CI, 1.01–1.24). The NNT to gain one additional responder at 6 to 12 weeks with venlafaxine was 12 (95% CI, 7–50). All studies were funded by the makers of venlafaxine.

Very few comparative effectiveness trials were available; their findings were generally consistent with efficacy trials. ^30,^ ^46,^ ^49^

Findings from indirect comparisons yielded no statistically significant differences in response rates among other potential comparisons. Although the precision of some estimates was low, leading to inconclusive results, treatment effects are similar across all comparisons.

Eighteen studies (N = 4,050) comparing one second-generation antidepressant with another indicated no differences in health-related quality of life. ^24,^ ^43,^ ^45,^ ^46,^ ^53,^ ^54,^ ^56,^ ^60,^ ^61,^ ^66,^ ^75,^ ^78,^ ^82,^ ^84,^ ^93,^ ^99^ – ^101^ Quality of life, however, was rarely assessed as a primary outcome measure. The strength of evidence is moderate.

Seven studies, all funded by the maker of mirtazapine, reported that mirtazapine has a significantly faster onset of action than citalopram, fluoxetine, paroxetine, and sertraline (Table 11). ^54,^ ^59^ – ^61,^ ^72,^ ^73,^ ^76^ The NNT to yield one additional responder after 1 or 2 weeks of treatment is 7 (95% CI, 5–12). This treatment effect was consistent across all studies. The strength of evidence is moderate.

Table 11 Characteristics of trials comparing mirtazapine to SSRIs on onset of action (response rate)

Study | Sample Size | Comparison | Effect Size | P-value | Comments
Leinonen et al., 1999 ^54^ | 270 | Citalopram | Significantly greater reduction of HAM-D scores with mirtazapine at day 14 (difference: -2.3) | P = 0.002 | No statistically significant differences in response and remission rates at endpoint
Hong et al., 2003 ^59^ | 133 | Fluoxetine | At day 28 significantly more responders with mirtazapine (53.3% vs. 39.0%) | P = NR (ns) | No statistically significant differences in overall response rate at week 6; more responders in the mirtazapine group (58% vs. 51%)
| | | RRR, 0.23
| | | RD: 0.14
| | | NNT: 7
Versiani et al., 2005 ^60^ | 297 | Fluoxetine | Significantly more responders at day 7 with mirtazapine (data NR) | P = 0.002 | No statistically significant differences in response and remission at endpoint (day 42)
| | | Higher rate of remitters for mirtazapine at days 14 (6.2 % vs. 2.0%), 28 (18.6% vs. 12.9%), and 42 (29.0% vs. 21.1%) | P = NR (ns)
Wheatley et al., 1998 ^61^ | 133 | Fluoxetine | Significantly more responders at day 28 with mirtazapine (data NR) | P = 0.006 | Statistically significantly greater decrease of HAM-D scores for mirtazapine at days 21 and 28. No statistically significant differences in response and remission at endpoint (day 56)
Benkert et al., 2000 ^72^ | 275 | Paroxetine | Significantly more responders (23.2% vs. 8.9%) and remitters (8.8% vs. 2.4%) at day 7 with mirtazapine. | Response: | More responders and remitters in the mirtazapine group throughout the study. No statistically significant difference at endpoint (response: 58.3% vs. 53.7%; remission: 40.9% vs. 34.8%)
| | | RRR, 0.15 0.07 | P = 0.002
| | | RD: 0.14 0.07 | Remission:
| | | NNT: 8 15 | P = 0.03
Schatzberg et al., 2002 ^73^ | 255 | Paroxetine | Significantly more responders at day 14 with mirtazapine (27.8% vs. 13.3%) | P = 0.005 | No statistically significant differences in overall response rate at week 8; more responders in the mirtazapine group (51% vs. 8%) at endpoint
| | | RRR, 0.17 | P < 0.01 (day 7, 14)
| | | RD: 0.14 | P = 0.024 (day 21)
| | | NNT: 7 | Kaplan-Mayer:
| | | Significantly greater decrease of HAM-D scores from day 7 to day 21 with mirtazapine | P = 0.016
| | | Median time to response:
| | | Mirtazapine: 26 days
| | | Paroxetine: 40 days
Behnke et al., 2003 ^76^ | 346 | Sertraline | Significantly higher response rates at days 7, 10, and 14 with mirtazapine (data NR) | day 7: P < 0.05 | No statistically significant differences in response and remission at endpoint (day 56)
| | | | day 10: P < 0.01
| | | | day 14: P < 0.05

HAM-D, Hamilton Rating Scale for Depression; NNT, number needed to treat; NR, not reported; ns, not significant; RD, risk difference; RRR, relative risk reduction.

Five trials provide evidence that bupropion leads to greater satisfaction with sexual activity than sertraline ^88^ – ^90^ and fluoxetine (Table 12). ^79,^ ^80^ The NNT to yield one additional person with a high overall satisfaction of sexual functioning is 7. This treatment effect was consistent across all studies.

Table 12 Characteristics of trials comparing bupropion to SSRIs on sexual functioning and satisfaction

Study | Sample Size | Comparison | Effect Size | P-value | Comments
Feighner et al., 1991 ^80^ | 61 | Fluoxetine | Higher rates for fluoxetine of impotence (4.7% vs. 0%) anorgasmia (1.7% vs. 0%) libido decrease (1.7% vs. 0%) | NR | Self-reporting of sexual adverse events
Coleman et al., 2001 ^79^ | 456 | Fluoxetine, placebo | Significantly more bupropion SR patients were satisfied with overall sexual functioning (analysis only for patients satisfied at baseline; no data reported) | P < 0.05 | DSM-IV criteria for sexual dysfunction disorders
| | | | | No statistically significant differences in efficacy outcome measures at endpoint (week 8)
Coleman et al., 1999 ^88^ | 364 | Sertraline | Beginning at day 21, significantly more patients on bupropion SR were satisfied with their sexual functioning (endpoint: 85% vs. 62%) | P < 0.05 | DSM-IV criteria for sexual dysfunction disorders
| | | Endpoint: | | No statistically significant differences in efficacy outcome measures at endpoint (week 8)
| | | RRR, 0.59
| | | RD: 0.22
| | | NNT: 5
Croft et al., 1999 ^89^ | 360 | Sertraline, placebo | Beginning at day 7 through day 42 significantly more bupropion SR patients were satisfied with overall sexual functioning; difference was not statistically significant at endpoint (75% vs. 65%) endpoint: | P < 0.05 | Sexual function assessed in investigator-conducted structured interview
| | | RRR, 0.29 | | No statistically significant differences in efficacy outcome measures at endpoint (week 8)
| | | RD: 0.10
| | | NNT: 10
Kavoussi et al., 1997 ^90,^ ^102^ | 248 | Sertraline | Significantly more patients on sertraline experienced orgasm delays and/or failure | P < 0.01 | Sexual function assessed in investigator-conducted structured interview
| | | Women: 41% vs. 7% | P < 0.001 | No statistically significant differences in efficacy outcome measures at endpoint (week 16)
| | | RRR, 0.85
| | | RD: 0.38
| | | NNT: 3
| | | Men: 61% vs. 10%
| | | RRR, 0.84
| | | RD: 0.51
| | | NNT: 2
| | | Higher overall satisfaction with sexual functioning with bupropion SR at endpoint (79% vs. 58%)
| | | RRR, 0.50
| | | RD: 0.21
| | | NNT: 5

DSM-IV, Diagnostic and Statistical Manual of Mental Disorders, 4th edition; NNT, number needed to treat; NR, not reported; RD, risk difference; RRR, relative risk reduction.

We did not find any efficacy evidence addressing Key Question 1b.

### Major Depressive Disorder: Detailed Analysis

Head-to-head evidence: SSRIs vs. SSRIs. Citalopram vs. escitalopram. Four published trials ^24^ – ^27^ and one unpublished ^98^ trial compared the efficacy of citalopram and escitalopram. Four studies were conducted over 8 weeks ^24,^ ^26,^ ^27,^ ^98^ and one over 24 weeks. ^25^ One study was a flexible dose trial. ^26^ Table 13 summarizes study characteristics and differences in effect sizes of studies comparing citalopram with escitalopram.

Table 13 Characteristics and effect sizes of studies comparing citalopram with escitalopram

Study | N | Duration | Dosage Cit. - Esc. mg/d | Response (%) | Remission (%) | Quality Rating
Burke et al., 2002 ^24^ | 491 | 8 weeks | 40 vs. 20 | 45.6 vs. 51.2 | NR | Fair
| | | | P = NR (ns)
| | | 40 vs. 10 | 45.6 vs. 50 | NR
| | | | P = NR (ns)
Colonna et al., 2005 ^25^ | 357 | 8 weeks | 20 vs. 10 | 55 vs. 63 | NR | Fair
| | | | P < 0.05
| | 24 weeks | 20 vs. 10 | 78 vs. 80 | NR
| | | | P = NR (ns)
Lepola et al., 2003 ^26^ | 471 | 8 weeks | 20–40 vs. 10–20 | 52.6 vs. 63.7 | 42.8 vs. 52.1 | Fair
| | | | P = 0.021 | P = 0.036
Moore et al., 2005 ^27^ | 280 | 8 weeks | 40 vs. 20 | 61.5 vs. 76.1 | 43.6 vs. 56.1 | Fair
| | | | P = 0.009 | P = 0.04
Unpublished Study SCT MD-02 ^98^ | 375 | 8 weeks | 20–40 vs. 10–20 | 51 vs. 46 | NR | Fair
| | | | P = NR

NR, not reported; ns, not significant.

Overall, results of individual studies favored escitalopram over citalopram. In three studies, differences in response rates reached statistical significance at 8 weeks. ^25^ – ^27^ The flexible dose trial was a European-Canadian study that compared efficacy and harms of citalopram (20–40 mg/day), escitalopram (10–20 mg/day), and placebo in 471 depressed outpatients attending primary care centers. ^26^ ITT results showed that the escitalopram group had significantly more patients responding (63.7 percent vs. 52.6 percent; P = 0.021) and achieving remission (52.1 percent vs. 42.8 percent; P < 0.036) than the citalopram group. Escitalopram was numerically better at all time points on three scales (MADRS, Clinical Global Impressions Improvement Scale [CGI-I], Clinical Global Impressions Severity Scale [CGI-S]). The study did not assess health outcomes.

The 24-week study was a fixed-dose trial (escitalopram 10 mg/day, citalopram 20 mg/day) of 357 European primary care patients over 24 weeks. ^25^ Escitalopram patients had significantly higher response rates at week 8 (63 percent vs. 55 percent; P < 0.05) but not at week 24 (80 percent vs. 78 percent; P = NR). Escitalopram had significantly lower CGI-S scores (1.75 vs. 2.00) and significantly fewer withdrawals (12.7 percent vs. 22.4 percent) than citalopram at week 24.

We conducted two meta-analyses of these studies comparing the effects of citalopram with those of escitalopram on MADRS scores at week 8. The outcome of the first meta-analysis was the relative risk of being a responder on the MADRS scale at week 8 (Figure 3). In addition to the four published trials, we included data from one unpublished study from the FDA Center for Drug Evaluation and Research (CDER) database. ^98^ A “response” was defined as an improvement of 50 percent or more on the MADRS. Pooled results included 1,545 patients and yielded a statistically significant additional treatment effect for escitalopram. The relative risk that a patient would respond was 1.14 (95% CI, 1.04–1.26) for escitalopram relative to citalopram. Both random effects and fixed effects models presented similar, statistically significant results. The NNT to gain one additional responder based on the pooled risk difference is 14 (95% CI, 7–111).

Figure 3. Relative risk meta-analysis of MADRS response rates comparing citalopram with escitalopram

The second meta-analysis was an effect size meta-analysis of all five studies assessing the pooled difference of points on the MADRS (Figure 4). Overall, this analysis included data on 1,545 patients. The weighted mean difference (WMD) presented an additional treatment effect of a 1.13 point reduction (95% CI, 0.18–2.09; P = 0.02) for escitalopram compared with citalopram. Although the difference was statistically significant, the clinical implications remain to be clarified. A 1.13 point change on the MADRS represents about one-fifth to one-quarter of a standard deviation. A recent methods study concluded that, in general, a change of about one-half of a standard deviation on a health-related scale reflects a minimally important difference for a patient. ^103^

Figure 4. Effect size meta-analysis comparing citalopram with escitalopram on the MADRS

Both citalopram and escitalopram are produced by the same manufacturer, which funded all available studies. Generic brands of citalopram are available in the United States; escitalopram is still under patent protection.

Citalopram vs. fluoxetine. In a French trial, 397 outpatients with MDD attending general practices were randomly assigned to citalopram (20 mg/day) or fluoxetine (20 mg/day) over 8 weeks. ^28^ Citalopram had a faster onset of efficacy than fluoxetine; significantly more patients were rated as responding (35 percent vs. 24 percent; P = 0.048) or completely recovered (27 percent vs. 16 percent; P = 0.034) on the MADRS after 2 weeks. At 8 weeks, however, response rates for the citalopram and the fluoxetine group were similar (78 percent vs. 76 percent; P = NR).

Citalopram vs. fluvoxamine. A Dutch study (N = 217) did not find any differences in efficacy (HAM-D, CGI, Zung self-rating depression scale at 6 weeks) between citalopram (20–40 mg/day) and fluvoxamine (100–200 mg/day). ^29^ Remission rates did not differ significantly between citalopram and fluvoxamine treatments (14 percent vs. 8 percent; P = NR).

Citalopram vs. sertraline. A Swedish study rated good quality assessed the effectiveness of citalopram (20–60 mg/day) and sertraline (50–150 mg/day) in 400 patients in general practice during 24 weeks of treatment. ^30^ The majority of patients suffered recurrent depression (sertraline, 56 percent; citalopram, 65 percent) and used other medications for medical illnesses (sertraline, 55 percent; citalopram, 44.5 percent). The investigators found no significant differences between treatment groups in any outcome measures at any point in time (MADRS, CGI-S, CGI-I). Also, in a subgroup analysis of patients with recurrent depression and single episode depression, they did not report any differences in effectiveness between drugs. Response rates were similar at week 24 (citalopram, 81.0 percent; sertraline, 75.5 percent; P = NR). This study was one of only a few trials not funded by the pharmaceutical industry; it can be considered an effectiveness trial.

Escitalopram vs. fluoxetine. A multinational RCT enrolled patients older than 65 years (n = 518) in general-practice and psychiatric-specialist settings to assess the comparative efficacy of escitalopram (10 mg/day) and fluoxetine (20 mg/day). ^31^ Both treatment groups had no greater efficacy than the placebo control group after 8 weeks of treatment. Response and remission rates did not differ significantly between the active treatment groups.

Fluoxetine vs. fluvoxamine. Two studies evaluated the comparative efficacy and safety of fluoxetine and fluvoxamine in 284 outpatients with MDD. ^32,^ ^33^ A 7-week flexible-dose study (fluoxetine: 20–80 mg/day; fluvoxamine 100–150 mg/day) did not identify any statistically or clinically significant differences in efficacy between the two treatment groups (HAM-D, HAM-A, CGI-S, Raskin-Covi Scale, Hopkins Symptoms Checklist [HSCL-D20]). ^33^ Both treatment regimens significantly improved scores on assessment scales over 7 weeks.

In a 6-week fixed-dose European trial (fluoxetine 20 mg/day; fluvoxamine 100 mg/day) in 184 outpatients with MDD, ^32^ results are consistent with those of the flexible-dose study; scores on the primary outcome measure (HAM-D) were not significantly different at any time. At endpoint, the drugs were equally effective for secondary outcome measures such as suicidal ideation, sleep, anxiety, and severity of illness (CGI, Clinical Anxiety Scale [CAS], the Irritability, Depression, and Anxiety Scale [IDAS], Beck's Scale for Suicide Ideation [Beck's SSI]). Fluvoxamine had significantly more responders on the CGI-S (29 percent vs. 16 percent; P < 0.05) and a greater reduction of CGI-S scores (P < 0.05) at week 2 but not at weeks 4 or 6.

Fluoxetine vs. paroxetine. Ten studies compared fluoxetine to paroxetine. ^34^ – ^41,^ ^48,^ ^49^ Most studies lasted from 6 to 12 weeks. Efficacy measures included HAM-D, HAM-A, MADRS, CGI-S, CGI-I, Covi Anxiety Scale, and others. Overall, these studies did not indicate substantial differences in outcome measures between fluoxetine and paroxetine. The largest study was a Canadian RCT (n = 203) with a study duration of 12 weeks. ^35^ At study endpoint, fluoxetine (20–80 mg/day) and paroxetine (20–50 mg/day) presented similar response (68 percent vs. 67 percent; P = 0.93) and remission rates (59 percent vs. 58 percent; P = 0.84).

One study was conducted in an inpatient population. ^40^ Results were consistent with findings of the other studies.

We conducted a meta-analysis of these seven studies (excluding three that did not report data ^34,^ ^48,^ ^49^ ) using HAM-D scores at the end of followup. ^35^ – ^41^ We defined “response” as an improvement of 50 percent or more on the HAM-D. The statistical analysis included 950 patients. The pooled estimate of the random effects model, presented in Figure 5, indicates that fluoxetine and paroxetine do not differ significantly in efficacy (RR, 1.09; 95% CI, 0.99–1.21). Removing the study conducted in an inpatient population ^40^ from the analysis did not change the point estimate. An effect size meta-analysis (Figure 6) also did not detect a statistically significant difference between fluoxetine and paroxetine (-0.55; 95% CI, -1.46–0.36).

Figure 5. Relative risk meta-analysis of response rates comparing fluoxetine with paroxetine on the HAM-D

Figure 6. Effect size meta-analysis comparing fluoxetine with paroxetine on the HAM-D

Two RCTs were conducted in a population older then 60 years. ^34,^ ^39^ An Italian study lasting 1 year enrolled 242 patients to compare the effects of fluoxetine (20–60 mg/day) and paroxetine (20–40 mg/day) on depressive symptoms, mood, and cognitive function in nondemented persons (65 years or older). ^34^

In both trials, paroxetine-treated patients achieved higher response rates than patients in the fluoxetine group. In one study, differences in response rates reached statistical significance (37.5 percent vs. 17.5 percent; P = 0.04). ^39^ In the long-term Italian study, treatment groups did not differ significantly at study endpoint on CGI scores or most cognitive scales (Blessed Information and Memory Test [BIMT], Mini-Mental State Examination [MMSE], Clifton Assessment Schedule [CLAS]). ^34^

Five studies did not detect differences between fluoxetine and paroxetine in improvement of anxiety in patients with depression (HAM-A, Covi Anxiety Scale). ^34,^ ^35,^ ^37,^ ^38,^ ^41^

Fluoxetine vs. sertraline. Eight studies compared fluoxetine with sertraline. ^41^ – ^49^ The best evidence consisted of two effectiveness trials ^46,^ ^49^ and one efficacy trial ^43^ with long periods of followup.

Two multicenter trials in France comparing fluoxetine (20–60 mg/day) and sertraline (50–150 mg/day) were conducted in office settings (private psychiatrists and general physicians [GPs]). ^43,^ ^46^ The psychiatrist study ^46^ randomized 238 patients for 24 weeks; the GP study ^43^ randomized 242 patients for nearly 26 weeks (180 days). The majority of patients had concomitant medical conditions. Both studies assessed quality of life as a secondary outcome measure (Sickness Impact Profile [SIP], Functional Status Questionnaire [FSQ]). Exclusion criteria were less stringent in the GP trial than the psychiatrist trial. Loss to followup was 4.5 percent in the GP trial and 29.8 percent in the psychiatrist trial. In the GP trial, researchers conducted outcome assessments only at day 120 and day 180, but patients could choose to consult the physician at any time. ITT analyses in both studies did not reveal any statistically significant differences in any primary (MADRS, HAM-D, CGI) or secondary (Covi Anxiety Scale, HAD, SIP, Leeds Sleep Evaluation) efficacy measures or in the incidence of adverse events.

The ARTIST (A Randomized Trial Investigating SSRI Treatment) trial was an open-label RCT designed as an effectiveness study and carried out in primary care physician settings over 9 months. ^49^ This study did not meet our eligibility criteria because it was an open-label trial; we present it because it is one of only a few effectiveness trials. This study enrolled 601 patients at 76 sites. Initial diagnosis for enrollment was not based on diagnostic criteria but rather on the judgment of the treating physician. Criteria-based evaluation classified 74 percent of patients as having MDD, 18 percent dysthymia, and 8 percent minor depression. Patients' treatments could be switched among study drugs or to other antidepressive medications as needed. ITT analysis maintained the original randomization. Outcome measures assessing changes in depression and health-related quality of life measures (work, social and physical functioning, concentration and memory, and sexual functioning) were administered over the telephone by a blinded third party. Range of dosage and loss to followup were incompletely reported.

Results of the ARTIST trial did not reveal any significant differences among drugs in any outcome measures at either 3 or 9 months. ^49^ Compared with baseline measures, all treatment groups significantly improved during the study. Subgroup analyses did not show different effectiveness for patients with MDD or for those older than 60 years.

Four additional trials did not find any significant differences in primary outcome measures (HAM-D, MADRS, CGI-S). ^41,^ ^42,^ ^44,^ ^45,^ ^47^ Studies lasted from 6 weeks to 16 weeks. One study was conducted in 236 participants older than 60 years. ^44,^ ^45^ In this RCT, outcome measures also included quality of life (Q-LES-Q) and cognitive assessments (Shopping List Task [SLT], MMSE, Digital Symbol Substitution Test). Results on these health outcome measures were similar for both drugs. A subgroup analysis of 75 patients 70 years of age or older showed a greater response rate for sertraline than fluoxetine (59 percent vs. 42 percent; P = 0.027). ^45^

We conducted two meta-analyses of four studies ^41,^ ^42,^ ^44,^ ^46^ comparing the effects of fluoxetine and sertraline at study endpoint. The outcome of the first meta-analysis was the relative risk (benefit) of being a responder on the HAM-D (improvement of 50 percent or more) at study endpoint (Figure 7).

Figure 7. Relative risk meta-analysis of response rates comparing fluoxetine with sertraline on the HAM-D

Pooled results included 940 patients and yielded a statistically significant additional treatment effect for sertraline. The relative risk of being a responder was 1.11 (95% CI, 1.01–1.21) for sertraline relative to fluoxetine. Both random effects and fixed effects models presented similar, statistically significant results. The NNT to gain one additional responder based on the pooled risk difference is 14 (95% CI, 8–22).

The second meta-analysis was an effect size meta-analysis assessing the pooled difference of points on the HAM-D scale (Figure 8). Because of lack of reported data, we limited the analysis to three studies. ^41,^ ^44,^ ^46^ We found no statistically significant difference in points on the HAM-D scale between fluoxetine and sertraline. Relative to fluoxetine, sertraline had an additional treatment effect of a 0.75 point reduction in HAM-D (95% CI, -0.45–1.95).

Figure 8. Effect size meta-analysis comparing fluoxetine with sertraline on the HAM-D

Fluvoxamine vs. paroxetine. One 7-week RCT compared the efficacy and safety of fluvoxamine (50–150 mg/day) and paroxetine (20–50 mg/day) in 60 outpatients with MDD. ^50^ Results presented no statistically significant differences on HAM-D, HAM-A, CGI, and SCL-56 (Hopkins Symptom Checklist - 56 item). This study did not assess response and remission rates.

Fluvoxamine vs. sertraline. Two 7-week studies compared the depression scores and harms of fluvoxamine (50–150 mg/day) and sertraline (50–200 mg/day). ^51,^ ^52^ One trial was conducted in a mixed (84 percent unipolar, 16 percent bipolar depression) inpatient population. ^52^

In both studies, efficacy did not differ significantly between treatment groups. Both regimens led to significant improvements in depression scores from baseline (HAM-D, CGI). In one study, significantly more patients withdrew because of adverse events in the fluvoxamine group (19 percent) than in the sertraline group (2 percent; P = 0.016). ^51^ Sertraline-treated patients reported a significantly greater rate of sexual dysfunction than patients on fluvoxamine (28 percent vs. 10 percent; P = 0.047).

Paroxetine vs. sertraline. A Swedish RCT compared paroxetine (20–40 mg/day) with sertraline (50–150 mg/day) in a 24-week study involving 353 patients. ^53^ Outcome measures included MADRS, CGI, and Battelle Quality of Life Measure (BQOL). LOCF analysis yielded no significant differences in primary outcome measures (MADRS, CGI) at any point in time. Clinically significant improvement occurred over baseline among all quality of life factors. Treatment groups did not differ significantly on BQOL factors. Diarrhea was more frequent in the sertraline group (35.2 percent vs. 15.2 percent; P < 0.01). By contrast, patients in the paroxetine group had higher rates of fatigue (45.8 percent vs. 21.0 percent; P < 0.01), decreased libido in females (8.8 percent vs. 1.8 percent; P < 0.05), micturition problems (6.2 percent vs. 0.6 percent; P < 0.05), and constipation (16.4 percent vs. 5.7 percent; P < 0.01).

Head-to-head evidence: SSRIs vs. SSNRIs and SNRIs. Citalopram vs. mirtazapine. A 8-week European study (n = 270) determined the comparative efficacy of citalopram (20–60 mg/day) and mirtazapine (15–60 mg/day) on depression and anxiety symptoms in a mixed inpatient and outpatient population. ^54^ At study endpoint, results on efficacy measures (MADRS, HAM-A, CGI-S, Leeds Sleep Evaluation Questionnaire) and a quality of life measure (Q-LES-Q) were similar between treatment groups. Response rates on MADRS reached 88 percent in the citalopram and 85 percent in the mirtazapine group (P = 0.54). Mirtazapine, however, had a faster onset of action with significantly greater response rates on MADRS, HAM-A, CGI-S, and Q-LES-Q at day 14. Mirtazapine led to weight gain in significantly more patients than citalopram (15.3 vs. 4.5 percent; P < 0.05); citalopram had a significantly higher rate of nausea than mirtazapine (20 percent vs. 10.2 percent; P < 0.05) Overall discontinuation rates because of adverse events did not differ significantly between the two groups.

Citalopram vs. venlafaxine. A 6-month European study compared citalopram (10–30 mg/day) with venlafaxine XR (75–150 mg/day) for the treatment of depression in elderly outpatients (mean age 73 years). ^55^ No statistical differences in any outcome measures (MADRS, CGI-S, CGI-I) could be detected at study endpoint. The remission rates were 19 percent for venlafaxine and 23 percent for citalopram (P = NR). Both treatment groups reached a 93 percent response rate.

Escitalopram vs. venlafaxine. Two 8-week studies assessed the comparative effectiveness of escitalopram and venlafaxine XR. ^56,^ ^57^ One study assigned 293 patients to escitalopram (10–20 mg/day) or venlafaxine XR (75–150 mg/day). ^57^ The groups did not differ significantly in response (escitalopram: 77.4 percent; venlafaxine XR: 79.6 percent; P = NR) or remission (escitalopram: 69.9 percent; venlafaxine XR: 69.7 percent; P = NR). Survival analysis of the ITT population indicated that escitalopram-treated patients achieved sustained remission 6.6 days earlier than patients on venlafaxine XR (P < 0.01). Significantly fewer patients on escitalopram than on venlafaxine XR reported nausea (17 percent vs. 26 percent; P < 0.05), sweating (6 percent vs. 12.5 percent; P < 0.05), and constipation (2 percent vs. 6 percent; P < 0.05).

The second trial also reported that no statistically significant differences were apparent between escitalopram (20 mg/day) and venlafaxine XR (225 mg/day) in response (61 percent vs. 48 percent; P = NR) and remission rates. ^56^ Significantly fewer patients in the escitalopram group withdrew because of adverse events (4 percent vs. 16 percent; P < 0.01) or reported nausea (24 percent vs. 6 percent; P < 0.05). This study, however, compared a medium dose of escitalopram to a high dose of venlafaxine XR. Some differences in adverse events might be attributable to the high, fixed-dose regimen of venlafaxine XR.

Fluoxetine vs. duloxetine. A 8-week RCT assigned 173 patients to duloxetine (40–120 mg/day), fluoxetine (20 mg/day), or placebo. ^58^ Results revealed no statistically significant differences between fluoxetine and duloxetine in response rates (45 percent vs. 49 percent; P = 0.39). Remission rates at study endpoint favored duloxetine but did not reach statistical significance (43 percent vs. 30 percent; P = 0.82). However, the fixed-dose design for fluoxetine but not for duloxetine introduces equivalency issues and reduces the validity of this direct comparison.

Fluoxetine vs. mirtazapine. oxetine and mirtazapine. ^59^ – ^61^ Two studies enrolled either exclusively ^60^ or a large percentage ^61^ of inpatients and outpatients with severe depression (HAM-D > 25). In both of these trials, treatments did not differ on any efficacy measures (MADRS, HAM-D, CGI) or quality of life measures (Q-LES-Q) at endpoint (6 and 8 weeks). Both trials reported a faster onset of mirtazapine but no differences in remission rates at endpoint. These findings are consistent with results from the third study, which was conducted in Taiwanese outpatients with moderate depression. ^59^

In all three studies, patients treated with mirtazapine gained weight; by contrast, those treated with fluoxetine lost weight. In two studies, the differences reached statistical significance. ^60,^ ^61^ In one trial, 10.3 percent of patients in the mirtazapine group experienced an increase in body weight of more than 7 percent from baseline as did 0.9 percent of patients on fluoxetine. ^60^

Fluoxetine vs. venlafaxine. Nine studies compared the efficacy of fluoxetine to venlafaxine. ^62^ – ^70^ One study was conducted in inpatient populations. ^69^ One trial was conducted in outpatients with concomitant anxiety (minimum score of 8 on Covi Anxiety Scale). ^64^ The studies lasted from 6 weeks to 12 weeks. Except in one study, ^70^ results consistently presented greater efficacy of venlafaxine than fluoxetine; in three studies, this difference reached statistical significance. ^62,^ ^64,^ ^65^

We conducted a meta-analysis of eight studies comparing fluoxetine to venlafaxine. ^62^ – ^67,^ ^69,^ ^70^ All studies were financially supported by the manufacturer of venlafaxine. We excluded one study because of missing data. ^68^ The main outcome measure was the relative risk (benefit) of being a responder on the HAM-D scale at study endpoint.

Results (Figure 9), based on 1,814 patients, present a modest additional treatment effect for venlafaxine, just reaching statistical significance (RR, 1.12; 95% CI, 1.01–1.24). The NNT to achieve one additional responder was 12 (95% CI, 7–50) for the random effects model; the fixed effects model yielded similar significant results. An effect size meta-analysis (Figure 10) yielded a statistically nonsignificant additional reduction of 1.31 points (95% CI, -0.28–2.91) for venlafaxine compared with fluoxetine on the HAM-D scale. The clinical significance of this difference is questionable.

Figure 9. Relative risk meta-analysis of response rates comparing fluoxetine with venlafaxine on the HAM-D

Figure 10. Effect size meta-analysis comparing fluoxetine with venlafaxine on the HAM-D

In a sensitivity analysis, we limited studies to those with outpatients only. Results did not differ substantially from findings of analyses that combined inpatient and outpatient subjects. Patients in the venlafaxine group had statistically significantly higher response rates than did patients in the fluoxetine group (RR, 1.12; 95% CI, 1.00–1.25). Again, the additional effect size is modest, just reaching statistical significance.

These findings are consistent with results of a meta-analysis reported by Smith et al. ^104^ Compared with fluoxetine, venlafaxine yielded a modest but statistically significantly greater standardized effect size (-0.14; 95% CI, -0.22 – -0.06) and a significantly greater odds ratio (OR) for remission (OR, 1.42; 95% CI, 1.17–1.73). The OR for response was numerically greater for venlafaxine but not significant (OR, 1.17; 95% CI, 0.99–1.38).

Paroxetine vs. duloxetine. An 8-week, fixed-dose trial assessed the comparative efficacy of paroxetine (20 mg/day), duloxetine (80 mg/day), duloxetine (120 mg/day), and placebo. ^71^ These are comparisons between a low-to-medium dose of paroxetine (20 mg) and a medium dose (80 mg) and high dose (120 mg) of duloxetine. Patients in the three active drug groups did not differ significantly in either response (74 percent; 65 percent; 71 percent; P = NR) or remission (44 percent; 46 percent; 52 percent; P = NR). The Patient Global Impression of Improvement (PGI-I) score was significantly better in patients on paroxetine than on 80 mg/day duloxetine.

Paroxetine vs. mirtazapine. Two trials, one conducted in Germany ^72^ and one in the United States, ^73^ assessed the efficacy of paroxetine (20–40 mg/day) and mirtazapine (15–45 mg/day). The US study was conducted in depressed patients 65 years or older. ^73^ In both trials, paroxetine and mirtazapine were equally effective in reducing HAM-D scores at the endpoint. Mirtazapine led to a faster response in both trials. In the German study, 23.2 percent of mirtazapine-treated patients and 8.9 percent of paroxetine-treated patients responded to the treatment at week 1 (P < 0.002). A Kaplan-Meier analysis in one trial showed a significantly faster time to response for mirtazapine than for paroxetine (mean 26 days vs. mean 40 days; P = 0.016). ^73^ No significant difference in response rates on the CGI scale was noted. Both trials reported weight gain in significantly more patients treated with mirtazapine than with paroxetine (P < 0.05). Paroxetine-treated patients in the US study reported significantly higher rates of nausea, tremor, and flatulence (P < 0.05). The NNT to yield one additional patient responding with mirtazapine at weeks 1 or 2 is 7.

Paroxetine vs. venlafaxine. Two studies compared paroxetine with venlafaxine. ^74,^ ^75^ A Spanish study compared the effects of paroxetine (20–40 mg/day) with venlafaxine (75–150 mg/day) in outpatients (N = 84) with either MDD or dysthymia over 24 weeks. ^74^ The majority of patients (88 percent) were female. The percentage of dysthymic patients was not reported, and the authors did not differentiate between dysthymia and mild or moderate depression. Loss to followup was 32 percent, with a substantially higher loss to followup in the venlafaxine group (39 percent vs. 26 percent). Response and remission rates favored venlafaxine at all time points. The difference in remission rates reached statistical significance at week 12 (57 percent vs. 33 percent; P = 0.011). ITT analysis yielded no significant differences between treatment groups on any primary outcome measures (HAM-D, MADRS, CGI) at 24 weeks.

A British fixed-dose trial lasting 12 weeks randomized 361 mainly moderately ill patients (based on CGI severity score) treated in 43 general practices to either paroxetine (20 mg/day) or venlafaxine XR (75 mg/day). ^75^ Study groups did not differ significantly in efficacy measures, quality of life scores, or adverse events.

Sertraline vs. mirtazapine. One European study examined the onset of efficacy of sertraline (50–150 mg/day) compared with that of mirtazapine (30–45 mg/day) in 346 outpatients. ^76^ Onset of action was faster for the mirtazapine group than for the sertraline group on HAM-D and MADRS. Significantly more patients achieved response and remission on mirtazapine than on sertraline after the first 2 weeks (data not reported in the article; P < 0.05) No significant difference could be detected at endpoint. Subgroup analysis in patients with severe depression (HAM-D > 25) led to similar findings. A significantly higher number of patients withdrew because of adverse events in the mirtazapine group (12.5 percent vs. 3 percent; P = NR), and significantly more patients on mirtazapine than on sertraline had an increase in body weight of more than 7 percent (14.6 percent vs. 0 percent; P = 0.01).

Sertraline vs. venlafaxine. Two 8-week trials, both rated good quality, compared the efficacy of sertraline to venlafaxine; they yield mixed results regarding differences in efficacy. ^77,^ ^78^ In a Scandinavian study (N = 147), venlafaxine (75–150 mg/day) was significantly more efficacious than sertraline (50–100 mg/day) on the HAM-D (response: 83 percent vs. 68 percent; P = 0.05, remission: 68 percent vs. 45 percent; P = 0.008). ^77^ The other study (N = 163) assessed quality of life as the primary outcome measure (Q-LES-Q). ^78^ LOCF results at 8 weeks did not detect significant differences in quality of life and response and remission rates between treatment groups. Subgroup analyses in this trial, focused on patients with anxious or severe depression, indicated that response and remission rates did not differ significantly between sertraline (50–150 mg/day) and venlafaxine XR (75–225 mg/day).

Head-to-head evidence: SSRIs vs. other second-generation antidepressants. Fluoxetine vs. bupropion. Two trials compared the efficacy and harms of fluoxetine and bupropion. ^79,^ ^80^ Both studies reported similar response rates at endpoint; efficacy measures (changes of HAM-D, HAM-A, CGI-S, CGI-I scores) did not differ significantly. In the larger trial (N = 456), bupropion SR (150–400 mg/day) treatment yielded a higher rate than fluoxetine (20–60 mg/day) of patients achieving remission, but this difference was not significant (47 percent vs. 40 percent; P = NR). ^79^ From week 1 until endpoint (week 8), significantly more patients on fluoxetine than on bupropion SR were dissatisfied with their overall sexual function (data not reported; P < 0.05).

Fluoxetine vs. nefazodone. Two studies with identical protocols examined the effects of antidepressive treatments with either fluoxetine or nefazodone in outpatients with MDD and insomnia. ^105,^ ^106^ Data from these trials and an unpublished study also employing the same protocol were pooled into one analysis. ^81^

A total of 125 patients with MDD and sleep disturbance were enrolled for 8 weeks. Effects on sleep were measured by the HAM-D Sleep Disturbance subscale, Inventory for Depressive Symptomatology-Clinician Rated (IDS-C), Inventory for Depressive Symptomatology-Self Rated (IDS-SR), and electroencephalogram measurements. Fluoxetine and nefazodone were similarly efficacious in producing response on the HAM-D scale (45 percent vs. 47 percent; P = NR). Nefazodone led to significantly greater improvements of sleep quality than fluoxetine as assessed by clinician ratings and self-reported evaluations (P < 0.01).

Fluoxetine vs. trazodone. Two 6-week trials compared the efficacy and harms of fluoxetine (20–60 mg/day) and trazodone (50–400 mg/day). ^82,^ ^83^ The groups did not differ significantly in any outcome measures (HAM-D, CGI-I, CGI-S, PGI-I). Remission rates in the larger study (N = 126), however, favored fluoxetine over trazodone at study endpoint (51 percent vs. 42 percent; P = NR). ^82^ Moreover, significantly fewer patients on fluoxetine than on trazodone experienced sedation or adverse events associated with sedation (22 percent vs. 43 percent; P = 0.11)

Paroxetine vs. bupropion. One RCT examined the efficacy of paroxetine (10–40 mg/day) and bupropion SR (100–300 mg/day) in 100 outpatients ages 60 years or older (range 60–88 years) over 6 weeks. ^84^ Relative to baseline, both groups significantly improved in all outcome measures (HAM-D, HAM-A, CGI-I, CGI-S), but the treatment groups did not differ significantly. Response rates were similar in both groups (paroxetine, 77 percent; bupropion SR, 71 percent; P = NR). Both treatment groups improved significantly in quality of life scales (Quality of life in Depression Scale [QLDS], SF-36) between baseline and endpoint (P < 0.0001); again, the treatment groups did not differ significantly. ^107^

Paroxetine vs. nefazodone. Two studies determined the comparative efficacy of paroxetine and nefazodone on depression and sleep improvement. ^85,^ ^86^ The larger trial enrolled 206 moderately depressed patients to an 8-week, acute-phase trial comparing nefazodone (200–600 mg/day) with paroxetine (20–40 mg/day). ^85^ Both groups showed significant improvements from baseline HAM-A, HAM-D, and MADRS scores. Response rates were similar for paroxetine and nefazodone (60 percent vs. 58 percent; P = NR). The second trial provided consistent results for the comparative antidepressive efficacy. ^86^ Nefazodone, however, led to significantly greater improvements than paroxetine in objective sleep measures.

Paroxetine vs. trazodone. A European study compared paroxetine (20–40 mg/day) with trazodone (150–400 mg/day) in 108 outpatients with MDD. ^87^ Study duration was 6 weeks. No differences in any efficacy outcome measures could be detected (HAM-D, CGI-S, CGI-I, MADRS). Response rates (91 percent vs. 87 percent; P = NR) and remission rates (68 percent vs. 69 percent; P = NR) did not differ significantly between paroxetine and trazodone.

Sertraline vs. bupropion. Three studies compared the efficacy and harms of sertraline and bupropion. ^88^ – ^90,^ ^108^ Studies lasted from 8 weeks to 16 weeks. All three studies reported no statistically significant differences in efficacy on any outcome measure (HAM-D, CGI-I, CGI-S, HAM-A). Response rates in the largest trial (N = 364) were 61 percent for sertraline and 66 percent for bupropion SR (P = NR). ^88^

In all three studies, patients on sertraline had statistically significantly higher rates of sexual dysfunction than patients on bupropion. Two RCTs assessed the incidence of sexual dysfunction during 8 weeks of treatment with sertraline (50–200 mg/day), bupropion SR (150–400 mg/day), or placebo as primary outcome measures using DSM-IV definitions for sexual dysfunction disorders. ^88,^ ^89^ In another study, discontinuation rates because of sexual adverse events were significantly higher in the sertraline group than the bupropion SR group (13.5 percent vs. 3.3 percent, P = 0.004). ^90^ In addition, in this study some adverse events (nausea, diarrhea, somnolence, sweating) were significantly more common among patients treated with sertraline than among those on bupropion SR (P < 0.05).

Sertraline vs. nefazodone. A multicenter European study assessed the efficacy and harms of sertraline (50–200 mg/day) and nefazodone (100–600 mg/day) among 160 outpatients with moderate to severe depression. ^92^ ITT analysis in this 6-week trial did not yield significant differences in efficacy between treatment groups. Response rates were similar between patients treated with sertraline and those treated with nefazodone (57 percent vs. 59 percent; P = NR). Additional outcome measures assessed by questionnaire were sexual function and satisfaction under antidepressant treatment. Overall satisfaction with sexual function was significantly higher in the nefazodone group (P < 0.01). Among men, 67 percent in the sertraline group and 19 percent in the nefazodone group reported difficulty with ejaculation (P < 0.01). Other adverse events did not differ significantly between the two groups.

Head-to-head evidence: SNRIs vs. SNRIs. Mirtazapine vs. venlafaxine. An 8-week European trial evaluated efficacy and harms in hospitalized, severely depressed patients (mean HAM-D 29.3) with melancholic features. ^93^ At study endpoint, no significant differences in any efficacy or quality of life measures were apparent (HAM-D, MADRS, CGI-S, Q-LES-Q, QLDS); however, response rates favored mirtazapine over venlafaxine (62 percent vs. 52 percent; P = NR). During the study, significantly fewer patients on mirtazapine than on venlafaxine dropped out because of adverse events (5.1 percent vs. 15.3 percent; P = 0.037). Mirtazapine led to weight gain in significantly more patients than did venlafaxine (10.3 percent vs. 5.1 percent; P < 0.05). Venlafaxine had significantly lower rates of constipation (17.1 percent vs. 31.1 percent; P = 0.056) and sweating (15.8 percent vs. 35.1 percent; P ≤ 0.05) than venlafaxine.

Head-to-head evidence: SNRIs vs. other second-generation antidepressants. Mirtazapine vs. trazodone. Two studies compared mirtazapine with trazodone in patients with MDD. ^94,^ ^95^ One trial was conducted in depressed patients 55 years of age and older; ^94^ the other was done in hospitalized patients with MDD. ^95^ Efficacy measures in both trials favored mirtazapine, but differences did not reach statistical significance. In the hospitalized patients, response rates at endpoint were 61 percent for mirtazapine and 51 percent for trazodone (P = NR). ^95^

Venlafaxine vs. trazodone. A 6-week study enrolled 225 patients to assess efficacy and harms of venlafaxine (150–400 mg/day), trazodone (75–200 mg/day), and placebo. ^96^ Efficacy outcomes (HAM-D, MADRS, CGI-S) did not differ significantly between active treatment groups. Response rates at endpoint, however, favored venlafaxine over trazodone (72 percent vs. 60 percent; P = NR). Trazodone led to improvements in sleep disturbance that were statistically significantly superior to those with venlafaxine. Significantly more patients on venlafaxine than on trazodone suffered from nausea (44 percent vs. 19 percent; P < 0.05); however, trazodone led to a significantly higher rate of dizziness than venlafaxine (36 percent vs. 17 percent; P < 0.05).

Head-to-head evidence: other second-generation antidepressants vs. other second-generation antidepressants. Bupropion vs. trazodone. In a two-center study, 124 outpatients were randomly assigned to bupropion (225–450 mg/day) or trazodone (150–450 mg/day). ^97^ Because of a statistically significant treatment-by-center interaction, the article reported results separately for each center. Overall, in both centers, efficacy results did not differ significantly between the two treatment groups. A postrandomization exclusion rate of 10 percent and an overall loss to followup of 40 percent might compromise the internal validity of this study.

Indirect comparisons. Of 66 possible comparisons, the evidence was sufficient to pool data in meta-analyses for only four comparisons for MDD (those documented in Figures 3 through Figure 10). For the remaining 62 MDD comparisons, we conducted indirect comparisons, through meta-regression, as outlined in the Methods section. Studies in these meta-regressions can be found in Appendix F; those excluded are listed in Appendix G.

We assessed the relative risk of response to treatment on the HAM-D scale. None of the results of indirect comparisons suggests a statistically significant difference in efficacy between any drugs. However, confidence intervals are often wide and findings do not conclusively demonstrate noninferiority. ^109^

In general, findings from indirect comparisons were consistent with available head-to-head studies. Results of direct (denoted by an asterisk) and indirect comparisons are depicted in Figures 11, 12, and 13.

Figure 11. Relative risks of response rates comparing SSRIs with SSRIs on the HAM-D

Figure 12. Relative risks of response rates comparing SSRIs, SNRIs, SSNRIs, and other second-generation antidepressants with other second-generation antidepressants on the HAM-D

Figure 13. Relative risks of response rates comparing SSRIs with SSNRIs and SSRIs with SNRIs on the HAM-D

### Dysthymia: Overview

We did not find any head-to-head trials on patients with dysthymia. Five placebo-controlled studies (Table 14) assessed effectiveness, efficacy, and harms of fluoxetine, paroxetine, and sertraline in populations with dysthymia. ^99^ – ^101,^ ^110^ – ^113^ Four studies were of fair quality; the fifth was of good quality. Details can be found in Evidence Table 1 in Appendix D.

Table 14 Interventions, numbers of patients, results, and quality ratings of studies in adults with dysthymia

Study | Interventions | N | Results | Quality Rating
Devanand et al., 2005 ^100^ | Fluoxetine vs. placebo | 90 | No difference in response rates and quality of life | Good
Vanelle et al., 1997 ^101^ | Fluoxetine vs. placebo | 111 | Significantly more responders for fluoxetine | Fair
Barrett et al., 2001 ^113^ | Paroxetine vs. placebo vs. behavioral therapy | 656 | In patients older than 60 years, significantly greater improvement in symptom scores for paroxetine than for placebo; in patients younger than 60 years, no difference | Fair
Williams et al., 2000 ^112^
Thase et al., 1996 ^111^ | Sertraline vs. imipramine vs. placebo | 412 | Significantly more responders for sertraline than placebo | Fair
Kocsis et al., 1997 ^110^
Ravindran et al., 2000 ^99^ | Sertraline vs. placebo | 310 | Significantly more responders and remitters for sertraline | Fair

### Dysthymia: Key Points

We identified no head-to-head trials in a population with dysthymia. The significant differences in population characteristics in placebo-controlled trials make the evidence insufficient to identify differences between treatments. The strength of evidence is low.

Five placebo-controlled trials (eight articles) provide mixed evidence on the general efficacy and effectiveness of fluoxetine, paroxetine, and sertraline for the treatment of dysthymia. ^99^ – ^101,^ ^110^ – ^113^ Specifically:

- Two studies provide mixed evidence about the general efficacy of fluoxetine for the treatment of dysthymia. ^100,^ ^101^
- One effectiveness study provides mixed evidence on the effectiveness of paroxetine compared with placebo. ^112,^ ^113^ A subgroup of patients older than 60 years showed a significantly greater improvement than those on placebo; a subgroup of patients younger than 60 years did not show any difference in effectiveness between paroxetine and placebo.
- Two studies indicate that sertraline has a significantly greater efficacy in the treatment of dysthymia than placebo. ^99,^ ^110,^ ^111^

### Dysthymia: Detailed Analysis

Head-to-head evidence. We identified no head-to head trials.

Placebo-controlled evidence. Fluoxetine vs. placebo. Two studies evaluated the efficacy of fluoxetine for treating patients with dysthymia over 12 weeks; the studies provide mixed results. ^100,^ ^101^ An RCT of good quality examined the efficacy and safety of fluoxetine (20–60 mg/day) in patients 60 years of age and older. ^100^ ITT analysis indicated that fluoxetine had limited efficacy. Response rates on the HAM-D favored fluoxetine over placebo, but the two groups did not differ significantly (27.3 percent vs. 19.6 percent; P = 0.4). Likewise, the investigators found no difference in quality of life.

The other study was conducted in patients 18 years of age and older (mean 43 years). ^101^ Significantly more patients on fluoxetine than on placebo were rated as responders (58.3 percent vs. 35.9 percent; P = 0.03). Remission rates favored fluoxetine but did not reach statistical significance (44.4 percent vs. 25.6 percent; P = 0.07).

Paroxetine vs. placebo vs. behavioral therapy. A large, primary-care-based effectiveness study randomized 656 patients with dysthymia or minor depression to 11 weeks of paroxetine (10–40 mg/day), placebo, or behavioral therapy. ^112,^ ^113^ Participants were stratified into patients 60 years of age and older (n = 415) and patients younger than 60 years of age (n = 241) for ITT analysis.

In the 60 or older subgroup, paroxetine-treated patients showed a greater change in HSCL-D-20 scores than placebo-treated patients (P = 0.004). ^112^ Effects were similar for patients with dysthymia and minor depression. For older dysthymia patients with high or intermediate baseline functioning scores, paroxetine significantly improved mental health functioning compared with placebo. Overall, however, improvements of mental health functioning were not statistically significantly different between dysthymia patients receiving paroxetine and those receiving placebo.

Among the younger patients, treatment groups did not differ significantly on the HSCL-D-20. ^113^ For dysthymia only, the remission rate of patients with at least 4 weeks of treatment was significantly higher in the paroxetine group than in the placebo group (80 percent vs. 44 percent; P = 0.008). Paroxetine was not more efficacious than placebo in patients with minor depression.

Sertraline vs. placebo. Two RCTs assessed the efficacy of sertraline (50–200 mg/day) for the treatment of dysthymia over 12 weeks. ^99,^ ^110,^ ^111^ In both studies, only patients who had had the diagnosis of dysthymia for more than 5 years were eligible; outcomes included quality of life and measures of functional capacity. In both studies, patients on sertraline had significantly greater antidepressant responses than those on placebo (64 percent vs. 44 percent; P < 0.001 ^111^ and 51.9 percent vs. 33.8 percent; P = 0.001 ^99^ ). Likewise, in both studies, sertraline was more efficacious than placebo on psychosocial and quality of life instruments (Global Assessment of Functioning Scale, Social Adjustment Scale [SAD], Quality of Life Enjoyment and Satisfaction Questionnaire [QLSQ], BQOLS).

### Subsyndromal Depressive Disorders: Overview

We found no head-to-head RCTs on patients with subsyndromal depressive disorders. The only head-to-head evidence was a nonrandomized, single-blinded trial comparing citalopram with sertraline. ^114^ Because of the lack of head-to-head evidence, we briefly summarize this study (Table 15), although it did not meet eligibility criteria. In addition, two placebo-controlled studies, both rated fair quality, assessed the efficacy and tolerability of fluoxetine ^115^ and paroxetine ^112,^ ^113^ in patients with dysthymia (Table 15). Details can be found in Evidence Table 1 in Appendix D.

Table 15 Interventions, numbers of patients, results, and quality ratings of studies in adults with subsyndromal depressive disorders

Study | Interventions | N | Results | Quality Rating
Rocca et al., 2005 ^114^ | Citalopram vs. sertraline | 138 | No difference | NA
Judd et al., 2004 ^115^ | Fluoxetine vs. placebo | 162 | Greater improvements on depression scales for fluoxetine than for placebo; no difference in psychosocial outcomes | Fair
Barrett et al., 2001 ^113^ | Paroxetine vs. placebo vs. behavioral therapy | 656 | In patients older than 60 years, significantly greater improvement in symptom scores for paroxetine than for placebo; in patients younger than 60 years, no difference | Fair
Williams et al., 2000 ^112^

NA, not applicable.

### Subsyndromal Depressive Disorders: Key Points

We identified no head-to-head RCTs in a population with subsyndromal depression. A nonrandomized, open-label trial did not detect any differences in efficacy between citalopram and sertraline. ^114^

In placebo-controlled trials, significant differences in population characteristics make the evidence insufficient to identify differences between treatments. ^112,^ ^113,^ ^115^ In one effectiveness study, effectiveness did not differ significantly between paroxetine and placebo for the treatment of minor depression. ^112,^ ^113^ The strength of evidence is low.

### Subsyndromal Depressive Disorders: Detailed Analysis

Head-to-head evidence. We did not find any head-to-head RCTs. A nonrandomized, single-blinded trial (n = 138) lasting 1 year assessed the comparative efficacy and safety of citalopram and sertraline in patients with late-life minor depression or other subsyndromal depressive disorders. ^114^ Overall, both treatments improved depressive symptoms. No significant differences in efficacy could be detected at any time point. At the end of the study, remission was achieved by 53 percent of patients on citalopram and 42 percent on sertraline (P = 0.25). Likewise, no differences in psychosocial functioning emerged.

Placebo-controlled evidence. Two studies were conducted in populations with minor depression.

Fluoxetine vs. placebo. A 12-week trial (N = 162) evaluated the efficacy of fluoxetine in patients with minor depression. ^115^ Improvements on depression scales (HAM-D, Beck Depression Inventory [BDI], IDS-C) were statistically significantly greater for patients receiving fluoxetine than for those receiving placebo. Likewise, the overall severity of illness (CGI-S) improved statistically significantly more in the fluoxetine than in the placebo group (P = 0.002). No significant differences could be detected in psychosocial outcomes.

Paroxetine vs. placebo. A large primary-care-based effectiveness study randomized 656 patients with dysthymia or minor depression to 11 weeks of paroxetine (10–40 mg/day), placebo, or behavioral therapy. ^112,^ ^113^ Participants were stratified into patients 60 years and older (n = 415) and patients younger than 60 years (n = 241) for ITT analysis.

In the 60 or older subgroup, patients receiving paroxetine showed a greater change in HSCL-D-20 scores than those receiving placebo (P = 0.004), but those on paroxetine did not demonstrate more change than patients on behavioral therapy (P = 0.17). ^112^ Effects were similar for patients with dysthymia and minor depression. Paroxetine was not more efficacious than placebo in patients with minor depression in the younger subgroup. ^113^

## Key Question 2: Efficacy or effectiveness for maintaining remission or for treating patients with unresponsive or recurrent disease

This section deals with two issues on efficacy or effectiveness of medications:

2a For adults with a depressive syndrome, do antidepressants differ in their efficacy or effectiveness for maintaining response/remission (i.e., preventing relapse or recurrence)?
2b For adults receiving antidepressant treatment for a depressive syndrome that either has not responded (acute phase) or has relapsed (continuation phase) or recurred (maintenance phase), do alternative antidepressants differ in their efficacy or effectiveness for treating those with treatment-resistant or recurrent depression?

### Overview

In all, we had 27 studies relating to these two questions (Table 16). Three head-to-head RCTs compared the efficacy of one second-generation antidepressant with another for preventing relapse or recurrence. ^47,^ ^96,^ ^116,^ ^117^ Comparisons included fluoxetine vs. sertraline, ^47^ fluvoxamine vs. sertraline, ^116,^ ^117^ and trazodone vs. venlafaxine (shown in italics in Table 16). ^96^ Another 21 RCTs ^118^ – ^138^ provide additional placebo-controlled evidence to support the general efficacy of bupropion, citalopram, escitalopram, fluoxetine, fluvoxamine, mirtazapine, nefazodone, paroxetine, sertraline, trazodone, and venlafaxine for maintaining remission in patients with depressive disorders (Table 16). No trial assessed the efficacy of duloxetine for preventing relapse or recurrence. Two effectiveness studies ^139,^ ^140^ and one efficacy trial ^141^ compared one second-generation antidepressant with another for treating patients who had not responded or could not tolerate at least one previous treatment.

Table 16 Number of head-to-head comparisons and placebo-controlled studies for assessment of relapse and recurrence

Relapse Prevention | | Recurrence Prevention
(Continuation Treatment ≤ 9 months) | | (Maintenance Treatment)
Comparison | Number of Studies | Comparison | Number of Studies
Head-to-Head Trials
Fluoxetine vs. sertraline | 1 | Fluvoxamine vs. sertraline | 1
| | Trazodone vs. venlafaxine | 1
Placebo-Controlled Trials
Bupropion vs. placebo | 1 | Bupropion vs. placebo | 0
Citalopram vs. placebo | 2 | Citalopram vs. placebo | 2
Duloxetine vs. placebo | 0 | Duloxetine vs. placebo | 0
Escitalopram vs. placebo | 1 | Escitalopram vs. placebo | 0
Fluoxetine vs. placebo | 2 | Fluoxetine vs. placebo | 1
Fluvoxamine vs. placebo | 0 | Fluvoxamine vs. placebo | 1
Mirtazapine vs. placebo | 1 | Mirtazapine vs. placebo | 0
Nefazodone vs. placebo | 1 | Nefazodone vs. placebo | 1
Paroxetine vs. placebo | 1* | Paroxetine vs. placebo | 2*
Sertraline vs. placebo | 1 | Sertraline vs. placebo | 3
Trazodone vs. placebo | 0 | Trazodone vs. placebo | 1^†^
Venlafaxine vs. placebo | 1 | Venlafaxine vs. placebo | 2^†^

* One trial reported continuation-phase and maintenance-phase results.

† Includes placebo comparison from a head-to-head trial of trazodone and venlafaxine.

Using the management framework depicted in the introduction (Figure 1), we characterized studies that assessed continuation treatment of patients who had responded or remitted with acute-phase treatment as relapse prevention studies. Relapse prevention studies typically included an open-label, acute-phase treatment and a double-blind, randomized, placebo-controlled continuation-phase treatment. The duration of continuation treatment in these trials ranged from 14 weeks to 72 weeks.

We further denoted studies that assessed maintenance treatment among patients who had remained in remission following acute and continuation treatment as recurrence prevention studies. These studies usually included an open-label acute phase, then an open-label continuation phase for acute-phase responders, followed by a randomized, double-blind, placebo-controlled maintenance phase for patients who had not relapsed. The maintenance phase in these trials lasted from 36 weeks to 100 weeks.

Studies that compared one second-generation antidepressant with another in treating resistant depressive disorders varied in design, although all studies randomized patients with MDD, dysthymia, or minor depression to an alternative treatment after they had either failed or could not tolerate a previous treatment. We characterized patients with treatment-resistant depressive disorder as those who had failed initial acute-phase treatment. We searched for studies specifically assessing treatment of relapse (i.e., loss of response during continuation treatment) and recurrence (i.e., a new distinct episode), but studies addressing this population included relapsing patients and/or those with recurrent depression among those studied in acute-phase treatment trials (i.e., KQ 1).

Investigators generally determined the initial inclusion of patients on a criteria-based diagnosis (e.g., DSM-III-R, DSM-IV) and a predefined cutoff point of a universally used depression scale (e.g., HAM-D ≥ 18 or MADRS ≥ 19). Subsequent inclusion criteria varied. Some studies randomized patients who had demonstrated a clinically significant response to open-label treatment (e.g., ≥ 50 percent improvement from baseline on the HAM-D or MADRS). Other studies used a predefined cutoff point on a depression scale to identify and randomize those who were in remission (e.g., HAM-D ≤ 9, MADRS ≤ 12, CGI-I ≤ 2). Most studies assessed relapse or recurrence using a predefined cutoff point on a depression rating scale (e.g., HAM-D > 18, MADRS > 19, CGI-S ≥ 4), but the specific cutoff point varied widely.

Because most studies received a fair rating for quality (internal validity), we denote quality in this section only for those rated good or poor. Trial reporting was often incomplete. Most articles did not report their methods of randomization or allocation concealment. Even though investigators frequently used ITT analysis, few authors reported the overall number of patients lost to followup from randomization to the end of the trial. Because some studies defined reasons for attrition such as withdrawals because of lack of efficacy or adverse events as endpoints, we did not use loss to followup as an exclusion criteria for these studies.

Data were insufficient to use placebo-controlled trials for making indirect comparisons between drugs.

Detailed information on all studies reviewed for KQs 2a and 2b can be found in Evidence Table 2 in Appendix D.

### Maintaining Remission: Key Points

In three head-to-head trials, ^47,^ ^96,^ ^116,^ ^117^ the overall efficacy for maintaining remission does not differ between fluoxetine and sertraline, ^47^ fluvoxamine and sertraline, ^116,^ ^117^ and trazodone and venlafaxine. ^96^ We rated the strength of head-to-head evidence as moderate.

Ten placebo-controlled relapse prevention trials provide consistent efficacy evidence in favor of active treatment over placebo. ^118^ – ^127,^ ^142^ Eleven placebo-controlled recurrence prevention trials provide consistent evidence in favor of active treatment over placebo. ^119,^ ^128^ – ^138^ Effect sizes generally were consistent across drugs in placebo-controlled efficacy trials. One placebo-controlled recurrence prevention study ^136^ rated good quality provides general evidence of the effectiveness of sertraline for maintaining remission in patients with recurrent major depression.

### Maintaining Remission: Detailed Analysis

Head-to-head evidence. Three head-to-head trials compared one second-generation antidepressant with another for maintaining remission (Table 17). ^47,^ ^96,^ ^116,^ ^117^

Table 17 Head-to-head studies of relapse prevention and recurrence prevention

Study | Phase | Duration (Weeks) | N | Comparison and Dose (mg/d) | Relapse or Recurrence N (%) | | Quality Rating
Van Moffaert et al., 1995 ^47^ | Acute | 8 | 82 | Fluoxetine 20–40 | NA | | Fair
| | | 83 | Sertraline 50–100 | NA
| Continuation | 24 | 56 | Fluoxetine 20–40 | 7 (13) | P = NR (ns)
| | | 49 | Sertraline 50–100 | 5 (10)
Franchini et al., 1997 ^116^ | Acute | NR | NR | NR | NA | | Fair
| Continuation | 16 | NR | NR | NA
Franchini et al., 2000 ^117^ | Maintenance (2 years) ^116^ | 104 | 32 | Fluvoxamine 200 | 6 (19) | P = 0.88
| | | 32 | Sertraline 100 | 7 (22)
| Maintenance (4 years) ^117^ | 208 | 25 | Fluvoxamine 200 | 5 (20) | P = 0.92
| | | 22 | Sertraline 100 | 3 (14)
Cunningham et al., 1994 ^96^ | Acute | 6 | 77 | Trazodone 150–400 | NA | | Fair
| | | 72 | Venlafaxine 75–200 | NA
| | | 76 | Placebo | NA
| Continuation/Maintenance | 52 | 30 | Trazodone 150–400 | 4 (13) | P = NR (ns)
| | | 37 | Venlafaxine 75–200 | 3 (8)
| | | 29 | Placebo | 4 (14)

NA, not applicable; NR, not reported; ns, not statistically significant.

Fluoxetine vs. sertraline. One trial compared the efficacy of fluoxetine and sertraline for preventing relapse during a 24-week continuation phase. ^47^ A total of 165 patients with major depression were randomized to fluoxetine 20–40 mg/day or sertraline 50–100 mg/day. At 8 weeks, 56 responders (≥ 50 percent reduction in HAM-D or MADRS) in the fluoxetine group and 49 responders in the sertraline group entered the continuation phase, continuing the same dose attained at the end of the acute phase. Relapse rates were similar in the two groups (13 percent and 10 percent, respectively; P = NR), but this design may be prone to bias and confounding because patients had not been rerandomized at the start of the continuation phase.

Fluvoxamine vs. sertraline. One trial compared the efficacy of fluvoxamine and sertraline for maintaining remission over 2 years ^116^ and 4 years. ^117^ This relatively small Italian study included 64 patients with recurrent depression. After at least 4 months of remission with tricyclic antidepressants (N = 49), SSRIs (N = 4), monoamineoxidase inhibitors (N = 2), or combination treatment (N = 9), investigators randomized patients to fluvoxamine 200 mg/day or sertraline 100 mg/day and followed them for up to 4 years. Recurrence rates (HAM-D > 15) for fluvoxamine and sertraline were similar at 2 years (19 percent vs. 22 percent, respectively; P = 0.88) and 4 years (20 percent vs. 14 percent, respectively; P = 0.92).

Trazodone vs. venlafaxine. One randomized trial compared the efficacy and safety of trazodone and venlafaxine over a 1-year continuation/maintenance phase. ^96^ A total of 225 patients with major depression received acute treatment with trazodone 150–400 mg/day (N = 77), venlafaxine 75–200 mg/day (N = 72), or placebo (N = 76). After 6 weeks, 30 responders in the trazodone group and 37 in the venlafaxine group (CGI-I score of 1 or 2) were allowed to continue into the long-term phase. Relapse rates were similar in the three groups (13 percent, 8 percent, and 14 percent, respectively; P = NR). Fewer patients treated with venlafaxine than with either trazodone (P ≤ 0.05) or placebo (P = NR) withdrew from treatment for any reason; this difference reached statistical significance during the long-term phase.

Placebo-controlled evidence. Ten placebo-controlled trials (11 publications) assessed relapse prevention ^118^ – ^127,^ ^142^ and 11 trials (12 publications) assessed recurrence prevention. ^119,^ ^128^ – ^138^ Because the duration of acute, continuation, and maintenance phase treatment is not consistent in all patients, and because the definition of these treatment phases is not universal, some studies described below (Table 18) can be categorized as addressing both relapse and recurrence prevention.

Table 18 Placebo-controlled studies of relapse prevention and recurrence prevention

Study | Phase | Duration (Weeks) | N | Comparison and Dose (mg/d) | Relapse or Recurrence N (%) | | Quality Rating
Weihs et al., 2002 ^118^ | Acute | 8 | 816 | Bupropion SR 300 | NA | | Fair
| Continuation | 44 | 210 | Bupropion SR 300 | 78 (37) | P = 0.004
| | | 213 | Placebo | 111 (52)
Hochstrasser et al., 2001 ^128^ | Acute | 6–9 | 427 | Citalopram 20–60 | NA | | Fair
| Continuation | 16 | 327 | Citalopram 20–60 | NA
| Maintenance | 48 | 132 | Citalopram 20–60 | 24 (18) | P < 0.001
| | | 137 | Placebo | 59 (43)
Klysner et al., 2002 ^129^ | Acute | 8 | 230 | Citalopram 20–40 | NA | | Fair
| Continuation | 16 | 172 | Citalopram 20–40 | NA
| Maintenance | 48 | 60 | Citalopram 20–40 | 19 (32) | P = NR
| | | 61 | Placebo | 41 (67)
Montgomery et al., 1992 ^144^ | Acute | 6 | NR | Citalopram 20–40 | NA | | Fair
| Continuation | 24 | 48 | Citalopram 20 | 4 (8) | P < 0.02*
| | | 57 | Citalopram 40 | 7 (12)
| | | 42 | Placebo | 13 (31)
Robert and Montgomery, 1995 ^120^ | Acute | 8 | 391 | Citalopram 20–60 | NA | | Fair
| Continuation | 24 | 152 | Citalopram 20–60 | 21 (14) | P = 0.04
| | | 74 | Placebo | 18 (24)
Rapaport et al., 2004 ^121^ | Acute | 8 | 502 | Escitalopram 10–20 | NA | | Fair
| Continuation | 36 | 181 | Escitalopram 10–20 | 47 (26) | P = 0.01
| | | 93 | Placebo | 37 (40)
Gilaberte et al., 2001 ^130^ | Acute | 8 | 253 | Fluoxetine 20–40 | NA | | Fair
| Continuation | 24 | 179 | Fluoxetine 20–40 | NA
| Maintenance | 52 | 70 | Fluoxetine 20 | 14 (20) | P = 0.01
| | | 70 | Placebo | 28 (40)
Schmidt et al., 2000 ^123^ | Acute | 13 | 932 | Fluoxetine 20 | NA | | Fair
Dinan, 2001 ^142^ | Continuation | 25 | 189 | Fluoxetine 20 | 49 (26) | P < 0.01*
| | | 190 | Fluoxetine 90/week | 70 (37)
| | | 122 | Placebo | 61 (50)
Reimherr et al., 1998 ^122^ | Acute | 12–14 | 839 | Fluoxetine 20 | NA | | Fair
Michelson et al., 1999 ^145^ | Continuation | 14 | 299 | Fluoxetine 20 | 77 (26) | P < 0.001
| | | 95 | Placebo | 46 (49)
| Continuation | 38 | 105 | Fluoxetine 20 | 9 (9) | P < 0.04
| | | 52 | Placebo | 12 (23)
| Continuation | 50 | 28 | Fluoxetine 20 | 3 (11) | P = 0.54
| | | 34 | Placebo | 6 (16)
Terra and Montgomery, 1998 ^131^ | Acute | 6 | 436 | Fluvoxamine 100 | NA | | Fair
| Continuation | 18 | 283 | Fluvoxamine 100 | NA
| Maintenance | 52 | 110 | Fluvoxamine 100 | 14 (13) | P < 0.001
| | | 94 | Placebo | 33 (35)
Thase et al., 2001 ^124^ | Acute | 8–12 | 410 | Mirtazapine 15–45 | NA | | Fair
| Continuation | 40 | 76 | Mirtazapine 15–45 | 15 (20) | P = 0.001
| | | 80 | Placebo | 35 (44)
Gelenberg et al., 2003 ^132^ | Acute | 12 | 681 | Nefazodone 300–600 | NA | | Fair
| Continuation | 16 | 269 | Nefazodone 300–600 | NA
| Maintenance | 52 | 76 | Nefazodone 300–600 | 23 (30) | P = 0.043
| | | 84 | Placebo | 40 (48)
Feiger et al., 1999 ^125^ | Acute | 16 | 467 | Nefazodone 400–600 | NA | | Fair
| Continuation | 36 | 65 | Nefazodone 400–600 | 1 (2) | P = 0.009
| | | 66 | Placebo | 12 (18)
Claghorn and Feighner, 1993 ^133^ | Acute | 6 | 240 | Paroxetine 10–50 | NA | | Fair
| | | 237 | Imipramine 65–275 | NA
| | | 240 | Placebo | NA
| Continuation | 52 | 94 | Paroxetine 10–50 | 11 (12) | P = NR
| | | 79 | Imipramine 65–275 | 3 (4)
| | | 46 | Placebo | 10 (22)
Montgomery and Dunbar, 1993 ^119^ | Acute | 8 | 172 | Paroxetine 20–30 | NA | | Fair
| Continuation | 16 | 68 | Paroxetine 20–30 | 2 (3) | P < 0.01
| | | 67 | Placebo | 13 (19)
| Maintenance | 36 | 66 | Paroxetine 20–30 | 9 (14) | P < 0.05
| | | 54 | Placebo | 16 (30)
Lepine et al., 2004 ^136^ | Remission Stability | 8 | 371 | Placebo | NA | | Good
| Maintenance | 72 | 189 | Sertraline 50–100 | 32 (17) | P = 0.002
| | | 99 | Placebo | 33 (33)
Doogan and Caillard, 1992 ^126^ | Acute | 8 | 480 | Sertraline 50–200 | NA | | Fair
| Continuation | 44 | 185 | Sertraline 50–200 | 24 (13) | P < 0.001
| | | 110 | Placebo | 48 (46)
Keller et al., 1998 ^134^ | Acute | 12 | 426 | Sertraline 50–200 | NA | | Fair
Kocsis et al., 2002 ^135^ | Continuation | 16 | 209 | Sertraline 50–200 | NA
| Maintenance | 76 | 77 | Sertraline 50–200 | 5 (6) | P = 0.002
| | | 84 | Placebo | 19 (23)
Wilson et al., 2003 ^137^ | Acute | 8 | 318 | Sertraline 50–200 | NA | | Fair
| Continuation | 16–20 | 254 | Sertraline 50–200 | NA
| Maintenance | 100 | 56 | Sertraline 50–100 | 25 (45) | P = 0.21
| | | 57 | Placebo | 31 (54)
Montgomery et al., 2004 ^138^ | Acute/Continuation | 26 | 495 | Venlafaxine 100–200 | NA | | Fair
| Maintenance | 52 | 109 | Venlafaxine 100–200 | 24 (22) | P < 0.001
| | | 116 | Placebo | 64 (55)
Simon et al., 2004 ^127^ | Acute | 8 | 490 | Venlafaxine 75–225 | NA | | Fair
| Continuation | 26 | 161 | Venlafaxine XR 75–225 | 45 (28) | P < 0.001
| | | 157 | Placebo | 82 (52)

NA, not applicable; SR, slow release.

* Active treatment vs. placebo.

Bupropion vs. placebo. One trial assessed relapse prevention with bupropion. ^118^ Patients with recurrent major depression (N = 816) were treated openly for 8 weeks with bupropion SR 300 mg/day. Those who responded (CGI-I score of 1 or 2 during the last 3 weeks of the acute phase) were randomized to placebo (N = 213) or continuation treatment with the same dose of bupropion SR (N = 210). After 44 weeks, relapse rates were statistically significantly lower for patients on bupropion than for those on placebo (37 percent vs. 52 percent, respectively; P = 0.004). The median time to relapse, as defined by the need for treatment intervention after randomization into the double-blind phase, was 24 weeks for placebo and at least 44 weeks for bupropion.

Citalopram vs. placebo. Two trials assessed relapse prevention ^120,^ ^143^ and two other trials assessed recurrence prevention. ^128,^ ^129^ Both relapse prevention trials randomized patients who responded in the acute phase (MADRS ≤ 12) to placebo or continuation treatment with citalopram. Statistically significantly fewer patients on citalopram than on placebo relapsed after 24 weeks in both trials. Relapse rates were 14 percent and 24 percent, respectively (P = 0.04), in one trial, and 11 percent (pooled) and 31 percent, respectively (P < 0.02), in the other trial. Both recurrence prevention trials included open-label, acute-phase treatment with citalopram 20–60 mg/day (6 weeks to 9 weeks), followed by 16 weeks of open-label continuation treatment at the same dose for responders (MADRS ≤ 11). ^128,^ ^129^ Patients who had not relapsed (MADRS ≤ 22) during the continuation phase were randomized to 48 weeks of double-blind maintenance treatment with citalopram or placebo. Recurrence rates were lower for citalopram-treated patients than for placebo-treated patients in both trials (18 percent vs. 43 percent, respectively; P < 0.001, ^128^ and 32 percent vs. 67 percent, respectively; P = NR ^129^ ).

Escitalopram vs. placebo. One trial treated MDD patients (N = 502) openly with escitalopram 10–20 mg/day for 8 weeks. ^121^ Patients who responded (MADRS ≤ 12) were randomized to 36 weeks of double-blind continuation treatment with escitalopram (N = 181) or placebo (N = 93). Relapse rates (MADRS ≥ 22) were statistically significantly lower for escitalopram-treated patients than for placebo-treated patients (26 percent vs. 40 percent, respectively; P = 0.01), and the time to depressive relapse was significantly longer in patients who received escitalopram than in patients who received placebo (P = 0.013).

Fluoxetine vs. placebo. Two trials (three publications) assessed relapse prevention, ^122,^ ^123,^ ^142^ and one trial assessed recurrence prevention. ^130^ Of the relapse prevention studies, one trial sought to determine the optimal length of continuation treatment by randomizing patients who were in remission (HAM-D < 7 for 3 consecutive weeks) during 12 weeks to 14 weeks of acute-phase treatment with fluoxetine 20 mg/day to 14 weeks, 38 weeks, or 50 weeks of continuation treatment with fluoxetine or placebo. ^122^ Relapse rates were significantly lower for fluoxetine-treated patients than for placebo-treated patients at 14 weeks (26 percent vs. 49 percent, respectively; P < 0.001) and 38 weeks (9 percent vs. 23 percent, respectively; P = 0.04), but not at 50 weeks (11 percent vs. 16 percent, respectively; P = 0.54). The second trial openly treated 932 patients with MDD for 13 weeks with fluoxetine. ^123,^ ^142^ Responders (HAM-D ≤ 9 and CGI-I ≤ 2) were randomized to 25 weeks of continuation treatment with fluoxetine 20 mg/day (N = 189), fluoxetine 90 mg/week (N = 190), or placebo (N = 122). Relapse rates were statistically significantly lower for both the daily and the weekly doses of fluoxetine than for placebo (26 percent and 37 percent vs. 50 percent, respectively; P < 0.01 for placebo comparisons).

The recurrence prevention trial randomized patients who continued to meet remission criteria (HAM-D ≤ 8) during a 6-month continuation period to 1 year of double-blind maintenance treatment with either fluoxetine 20 mg/day (N = 70) or placebo (N = 70). ^130^ Recurrence rates were statistically significantly lower for fluoxetine-treated patients than for placebo-treated patients (20 percent vs. 40 percent, respectively; P = 0.01).

Fluvoxamine vs. placebo. One trial assessed recurrence prevention with fluvoxamine 100 mg/day. ^131^ Of 436 patients with major depression treated openly with fluvoxamine for 6 weeks, 283 responders (MADRS < 10 and CGI-I ≤ 2) entered 18 weeks of continuation treatment. Patients who sustained their response (MADRS < 12 and no CGI-I score > 2) were randomized to 1 year of double-blind treatment with fluvoxamine (N = 110) or placebo (N = 94). Recurrence rates were statistically significantly lower for fluvoxamine-treated patients than for placebo-treated patients (13 percent vs. 35 percent, respectively; P < 0.001).

Mirtazapine vs. placebo. One trial of relapse prevention openly treated patients with recurrent or chronic major depression (N = 410) with mirtazapine 15–45 mg/day for 8 weeks to 12 weeks. ^124^ Those in remission (HAM-D ≤ 7 and CGI-I ≤ 2) were randomized to 40 weeks of continuation treatment with mirtazapine (N = 76) or placebo (N = 80). Relapse rates were statistically significantly lower for mirtazapine-treated patients than for placebo-treated patients (20 percent vs. 44 percent, respectively; P = 0.001).

Nefazodone vs. placebo. Two trials, both rated fair, evaluated nefazodone. ^125,^ ^132^ In the relapse prevention study, investigators randomized patients in remission (HAM-D ≤ 10) to 36 weeks of double-blind treatment with nefazodone 400–600 mg/day (N = 65) or placebo (N = 66). ^125^ Statistically significantly fewer nefazodone-treated than placebo-treated patients relapsed (2 percent vs. 18 percent, respectively; P = 0.009). The recurrence prevention study openly treated 681 patients with chronic or recurrent major depression for 12 weeks with nefazodone 300–600 mg/day. ^132^ Patients who responded (≥ 50 percent improvement in HAM-D score from baseline) continued open-label nefazodone for an additional 16 weeks, and patients who maintained a response after this 16 weeks of continuation treatment were randomly assigned to 1 year of double-blind treatment with nefazodone (N = 76) or placebo (N = 84). The rate of recurrence was statistically significantly lower for patients on nefazodone than for those on placebo (30 percent vs. 48 percent, respectively; P = 0.043).

Paroxetine vs. placebo. One UK trial ^119^ and one US trial ^133^ assessed long-term treatment with paroxetine. Both trials randomized patients who had responded to acute-phase paroxetine therapy to 1 year of paroxetine or placebo. The UK study assessed relapse prevention after 16 weeks of double-blind treatment and recurrence prevention after an additional 36 weeks of continued double-blind treatment. ^119^ After 16 weeks, significantly fewer paroxetine-treated patients had relapsed than placebo-treated patients (3 percent vs. 19 percent, respectively; P < 0.01). Of the patients who maintained a response through the continuation phase and entered the maintenance phase, recurrence rates were lower for paroxetine-treated patients than for placebo-treated patients (14 percent vs. 30 percent, respectively; P < 0.05).

The US study was an extension of a 6-week acute-phase trial that compared paroxetine, imipramine, and placebo. ^133^ Investigators invited patients who had responded in the 6-week trial to continue flexible-dose, double-blind treatment for up to 1 year. Treatment allocation in the long-term extension was not randomized; the authors reported only aggregated relapse rates. More placebo-treated patients withdrew from the long-term trial because of “lack of efficacy” ^133^ , page 25S (n = 10; 22 percent) than did patients treated with either paroxetine (n = 11; 12 percent) or imipramine (n = 3; 4 percent).

Sertraline vs. placebo. One study assessed relapse prevention; ^126^ three other studies assessed recurrence prevention. ^134,^ ^136,^ ^137^ In the relapse prevention study, 295 patients who had responded in the acute phase were randomized to 44 weeks of double-blind treatment with sertraline 50–200 mg/day (N = 185) or placebo (N = 110). ^126^ Statistically significantly fewer sertraline-treated patients than placebo-treated patients experienced a relapse (13 percent vs. 46 percent, respectively; P < 0.001).

The good-quality relapse/recurrence prevention trial addressed potential methodological biases by including patients with recurrent depression who had been successfully treated for at least 4 months with any antidepressant other than sertraline. ^136^ Treatment was substituted with placebo for 2 months to identify patients truly in remission; patients who continued to remain in remission were randomized to sertraline 50 mg/day (N = 95), sertraline 100 mg/day (N = 94), or placebo (N = 99) and followed for 18 months. Patients treated with sertraline were statistically significantly less likely to have a recurrent depressive episode than patients treated with placebo (17 percent vs. 33 percent, respectively, for the pooled comparison; P = 0.002).

Similarly, the other two recurrence prevention studies found that patients treated with sertraline had fewer recurrences than did those on placebo. ^134,^ ^137^ In a 76-week maintenance phase, 6 percent of sertraline-treated and 23 percent of placebo-treated patients had a recurrent depressive episode (P = 0.002). ^134^ Differences did not reach statistical significance in a 100-week maintenance treatment of community residents 65 years of age and older with major depression; 45 percent of sertraline-treated patients and 54 percent of placebo-treated patients had a recurrent episode (P = 0.21). ^137^

Venlafaxine vs. placebo. Two trials studied venlafaxine. ^127,^ ^138^ The relapse prevention study openly treated 490 patients with major depression with venlafaxine XR 75–225 mg/day for 8 weeks. ^127^ Patients who responded (CGI-S ≤ 3 and HAM-D ≤ 10) were randomized to 26 weeks of double-blind treatment with venlafaxine (N = 161) or placebo (N = 157). Statistically significantly fewer venlafaxine-treated patients than placebo-treated patients experienced a relapse (28 percent vs. 52 percent, respectively; P < 0.001).

The recurrence prevention study openly treated 495 patients with recurrent major depression for 6 months with venlafaxine 100–200 mg/day. ^138^ After 6 months, those who had responded (HAM-D ≤ 12) were randomized to 12 months of venlafaxine (N = 109) or placebo (N = 116). The recurrence rate was statistically significantly lower for venlafaxine-treated patients than for placebo-treated patients (22 percent vs. 55 percent, respectively; P < 0.001).

### Treating Treatment-Resistant Depression or Relapse or Recurrence: Key Points

One head-to-head trial indicated that venlafaxine and paroxetine differ in their efficacy for treating major depression that has not responded to previous antidepressants. ^141^ This trial followed patients who were resistant to at least two previous antidepressant treatments; it found statistically significantly higher response and remission rates with venlafaxine than with paroxetine. Two studies yielded evidence of the effectiveness of one second-generation antidepressant compared with another for the treatment of depressive disorders in patients who had not responded to initial treatment. ^140^ ^146^ One trial of good quality indicates that the compared treatments do not differ in their effectiveness as second-line agents. ^146^ An open-label Spanish study contradicts this finding; it reported statistically significant differences in effectiveness between compared treatments. ^140^ The contradictions between the one good-quality study and the two fair-quality studies led us to rate the overall strength of this evidence as moderate.

### Treating Treatment-Resistant Depression or Relapse or Recurrence: Detailed Analysis

Head-to-head evidence. Three studies assessed differences among alternative antidepressants in patients who had either not responded or could not tolerate an acute-phase treatment (Table 19). ^140,^ ^141,^ ^146^ They covered a range of antidepressants; the common element was venlafaxine.

Table 19 Head-to-head studies of treatment-resistant and recurrent depression

Study | Duration (Weeks) | N | Comparison and Dose (mg/d) | Response N (%) | | Remission N (%) | | Quality Rating
Baldomero et al., 2005 ^140^ | 24 (open) | 1,465 | Conventional therapy (pooled) | 1,034 (71) | P < 0.001 | 754 (52) | P < 0.001 | Fair
| | 294 | Citalopram 20–40 | 209 (71) | P = 0.024 | 153 (52) | P = 0.02
| | 248 | Fluoxetine 20–40 | 174 (70) | P = 0.012 | 128 (52) | P = 0.03
| | 116 | Mirtazapine 30–45 | 75 (65) | P = 0.004 | 52 (45) | P = 0.003
| | 312 | Paroxetine 20–40 | 226 (73) | P = 0.078 | 161 (52) | P = 0.015
| | 279 | Sertraline 50–150 | 197 (71) | P = 0.014 | 147 (53) | P = 0.04
| | 1,632 | Venlafaxine 75–225 | 1,262 (78) | | 963 (59)
Poirier and Boyer, 1999 ^141^ | 4 | 62 | Paroxetine 30–40 | 18 (36) | P = 0.07 | 11 (18) | P = 0.02 | Fair
| | 61 | Venlafaxine 200–300 | 27 (45) | | 22 (37)
Rush et al., 2006 ^146^ | 14 | 239 | Bupropion 150–400 | 62 (26) | P = NR (ns) | 51 (21) | P = 0.16 | Good
| | 238 | Sertraline 50–200 | 63 (27) | | 42 (18)
| | 250 | Venlafaxine 37.5–375 | 62 (25) | | 62 (25)

NR, not reported; ns, not statistically significant.

Bupropion SR vs. sertraline vs. venlafaxine XR. One effectiveness trial rated good quality assessed differences in effectiveness in patients with MDD who had not gone into remission (Quick Inventory of Depressive Symptomatology - Clinician version [QIDS-C-16] ≤ 5) or could not tolerate citalopram during acute-phase treatment. ^146^ Participants eligible for second-step treatment had the option of switching to an alternative medication, cognitive behavioral therapy, or augmentation therapy. To mimic clinical practice, patients could opt to exclude certain second-step treatment options, and they were then randomized to an acceptable treatment option. The investigators compared only the treatments for which patients had accepted randomization. Of the 727 patients randomized to a second-generation antidepressant, 239 received bupropion SR 150–400 mg/day, 238 received sertraline 50–200 mg/day, and 250 received venlafaxine XR 37.5–375 mg/day. Doses were adjusted based on clinical judgment and side effect rating scales. Second-step treatment was continued for up to 14 weeks.

At endpoint, response and remission rates were not statistically significantly different among bupropion SR, sertraline, and venlafaxine XR. For response, the figures were 26 percent, 27 percent, and 28 percent, respectively; (P = NR [ns]); for remission, the figures were 21 percent, 18 percent, and 25 percent, respectively (P = 0.16). Treatments also differed only minimally with respect to tolerability and adverse events.

Although several comparative studies included patients who had relapsed or who were experiencing a recurrent depressive episode in acute-phase management studies, no study specifically randomized patients to one second-generation antidepressant or another upon relapse or recurrence. The good-quality trial provides the most direct evidence relative to the second part of KQ 2; 75 percent of patients in this trial had failed acute treatment of a recurrent depressive episode. Among all patients in this trial, the investigators found no differences among bupropion SR, sertraline, and venlafaxine XR as an alternative treatment.

Venlafaxine vs. paroxetine or numerous other antidepressants. One effectiveness trial randomized 3,502 patients with major depression, dysthymia, or minor depression who had shown inadequate response or intolerance to at least 4 weeks of previous antidepressant treatment with venlafaxine XR 75–225 mg/day or with some other conventional antidepressant therapy. ^140^ Conventional therapy selection was at the discretion of the treating psychiatrist; it included citalopram 20–40 mg/day (N = 333), fluoxetine 20–40 mg/day (N = 292), mirtazapine 30–45 mg/day (N = 133), paroxetine 20–40 mg/day (N = 361), sertraline 50–150 mg/day (N = 299), and other miscellaneous drug treatments (N = 254).

After 24 weeks of treatment, venlafaxine-treated patients had a statistically significantly better rates of response and remission than patients treated with conventional therapy. (For response, the figures were 78 percent vs. 71 percent, respectively; P < 0.001; for remission, the figures were 59 percent vs. 52 percent, respectively; P < 0.001.) Response and remission rates for venlafaxine XR were statistically significantly better than each of the individual drugs characterized as conventional therapy, except for paroxetine.

The response and remission rates in this study were much higher than in the good-quality effectiveness trial just described. ^146^ Although differences in measurement scales may partially explain response rates, the reason that remission rates differed remains unclear because both trials used a HAM-D cutoff point ≤ 7 to classify persons in remission.

One efficacy trial assessed differences between paroxetine and venlafaxine in patients with major depression who either had not responded or could not tolerate at least two previous treatments for their current depressive episode. ^141^ Patients were to be no more than minimally improved (CGI-I ≥ 3) with their second treatment. The investigators enrolled 123 patients in the study—61 on venlafaxine 200–300 mg/day and 62 on paroxetine 30–40 mg/day—and followed them for 4 weeks. At endpoint, statistically significantly more venlafaxine-treated patients than paroxetine-treated patients were classified as having responded to treatment (≥ 50 percent improvement in HAM-D from baseline; 45 percent vs. 36 percent, respectively; P = 0.07) and being in remission (HAM-D < 10; 37 percent vs. 18 percent, respectively; P = 0.02). The incidence of adverse events was comparable between treatment groups.

## Key Question 3: Efficacy or effectiveness for treating symptoms accompanying depression

### All Symptoms: Overview

For this issue, we focus on the comparative benefit of medications for patients with depression and an accompanying symptom cluster. We identified studies addressing six symptom clusters: anxiety, insomnia, pain, psychomotor change (retardation or agitation), melancholia (a depressive subtype that is a severe form of MDD with characteristic somatic symptoms), and somatization (physical complaints that are manifestations of depression rather than of an underlying physical illness). This set does not represent a complete list of symptoms commonly accompanying depression. For example, we did not identify any studies addressing fatigue, loss of energy, or appetite change—some of the more common accompanying symptoms reported by depressed patients. ^147^

For each symptom cluster, we arrange our summary by how the data address two subquestions:

3a Do medications differ in their efficacy and effectiveness in treating the depressive episode?
3b Do medications differ in their efficacy and effectiveness in treating the accompanying symptoms?

We identified 28 relevant trials (29 articles) (Tables 19–23); one trial was reported in two separate articles. ^91,^ ^148^ Twenty-two studies were head-to-head trials; one assessed three symptom subgroups. ^149^ We identified 11 head-to-head trials (12 articles) on anxiety, ^35,^ ^37,^ ^38,^ ^54,^ ^64,^ ^78,^ ^85,^ ^91,^ ^108,^ ^148^ – ^150^ six on insomnia, ^41,^ ^60,^ ^81,^ ^82,^ ^96,^ ^151^ three on melancholia, ^69,^ ^149,^ ^152^ two on pain, ^71,^ ^153^ and one each on psychomotor changes ^149^ and somatization. ^49^ One trial addressing somatization was an open-label effectiveness trial. ^49^ It did not meet our eligibility criteria because of the lack of double-blinding; however, we report on its results because it was a well-conducted randomized controlled effectiveness trial and comprises the only evidence for somatization in depressed patients. The remaining six studies were placebo-controlled trials. Three addressed pain, ^154^ – ^156^ two addressed anxiety, ^157,^ ^158^ and one addressed melancholia. ^159^

Table 23 Studies of adults with major depressive disorders and accompanying pain

Study | Interventions | N | Results | Quality Rating
Brannan et al., 2005 ^154^ | Duloxetine | 282 | KQ 3a. Improvement in depression scores (P = 0.544), depression response rates (P = 0.901), and remission rates (P = 0.887) was similar | Fair
| Placebo | | KQ 3b. Improvement in pain scores was similar (P = 0.066)
Goldstein et al., 2004 ^153^ | Duloxetine | 353 | KQ 3b. Improvement in pain scores was similar between active medications (P = NR), between paroxetine and placebo (P = 0.088), and between duloxetine 40 mg and placebo (P = 0.172); improvement in pain for duloxetine 80 mg was superior to placebo (P = 0.005). | Poor
| Paroxetine
| Placebo
Detke et al., 2002 ^155^ | Duloxetine | 245 | KQ 3b. Pain score improvement was slightly greater for duloxetine than placebo (P = 0.019) | Fair
| Placebo
Detke et al., 2002 ^156^ | Duloxetine | 267 | KQ 3b. Pain score improvement was slightly greater for duloxetine than placebo (P = 0.037) | Fair
| Placebo
Detke et al., 2004 ^71^ | Duloxetine | 367 | KQ 3b. Improvement in pain scores was similar between duloxetine 80 mg and placebo (P = 0.063), and between duloxetine 120 mg and placebo (P = 0.086); improvement in pain for paroxetine was superior to placebo (P = 0.035) | Fair
| Paroxetine
| Placebo

NR, not reported.

All but two studies ^38,^ ^64^ either were funded by or involved authors funded by pharmaceutical companies.

We rated all studies as fair quality with three exceptions (noted below). The fair rating was nearly universally a result of inadequate description of randomization and allocation concealment. A second common weakness was failure to report attrition rates, which occurred in 26 percent of trials. ^149,^ ^150,^ ^154,^ ^155,^ ^157^ – ^159^

We rated the quality of the one effectiveness trial as not applicable as it did not meet our initial selection criteria. ^49^ In addition, we have two poor-quality studies, one on melancholia ^152^ and the other on pain. ^153^ Both of the poor studies had high attrition; one had high differential attrition between treatment groups, ^152^ and the other had high overall attrition. ^153^ We comment on data from these two studies because the evidence base for pain and melancholia is otherwise very weak. Poor studies were included only if the available evidence was very limited. For any poor studies retained for use in this report, we required, at a minimum, that investigators had employed a randomization scheme and applied ITT analysis.

Detailed information on these studies can be found in Evidence Table 3 in Appendix D. Evidence Table 4 provides information on systematic reviews and meta-analyses related to treating depression and accompanying symptoms.

### Anxiety: Key Points

For KQ 3a, on the treatment of depression in patients with accompanying anxiety symptoms, we identified six head-to-head trials ^64,^ ^78,^ ^91,^ ^108,^ ^148^ – ^150^ and one placebo-controlled trial. ^157^ For KQ 3b, treatment of accompanying anxiety symptoms in patients with MDD, we included 10 head-to-head trials ^35,^ ^37,^ ^38,^ ^54,^ ^64,^ ^78,^ ^85,^ ^108,^ ^148,^ ^150^ and two placebo-controlled trials. ^157,^ ^158^ Six of these trials, in seven articles, addressed both key questions. ^64,^ ^78,^ ^91,^ ^108,^ ^148,^ ^150,^ ^157^ Of these 13 trials, five compared various SSRIs with each other or placebo, six compared an SSRI with an SNRI or another second-generation drug, and one each compared an SSRI or another second-generation drug only with placebo (Table 20). We rated the strength of evidence for both of these questions as moderate.

Table 20 Studies of adults with major depressive disorders and accompanying anxiety

Study | Interventions | N | Results | Quality Rating
SSRIs vs. SSRIs
Chouinard et al., 1999 ^35^ | Fluoxetine | 203 | KQ 3b. Improvement in anxiety scores was similar for both treatment groups (P = NR) | Fair
| Paroxetine
Fava et al., 1998 ^37^ | Fluoxetine | 128 | KQ 3b. Improvement in anxiety scores was similar for both treatment groups and placebo (P = NR) | Fair
| Paroxetine
| Placebo
Fava et al., 2000 ^150^ | Fluoxetine | 128 (all with anxiety) | KQ 3a. Improvement in depression scores (P = 0.323), depression response rates (P = 0.405) and remission rates were similar for all groups (P = 0.588) | Fair
| Paroxetine | | KQ 3b. Improvement in anxiety scores were similar for all 3 treatment groups (P = 0.199)
| Sertraline
Flament et al., 1999 ^149^ | Fluoxetine | 286 overall; 131 with anxiety | KQ 3a. Improvement in depression scores and depression response rates were similar for both treatment groups (P = NR) | Fair
| Sertraline
Gagiano, 1993 ^38^ | Fluoxetine | 90 | KQ 3b. Improvement in anxiety scores was similar for both treatment groups (P = NR) | Fair
| Paroxetine
SSRI vs. SNRI or other second-generation antidepressant
Baldwin et al.,1996 ^85^ | Paroxetine | 206 | KQ 3b. Improvement in anxiety scores was similar for both treatment groups (95% CI for difference, -0.7–3.8) | Fair
| Nefazodone
DeNayer et al., 2002 ^64^ | Fluoxetine | 146 (all with anxiety) | KQ 3a. Improvement in depression scores was greater and response rates were higher for venlafaxine compared with fluoxetine (P < 0.05) | Fair
| Venlafaxine | | KQ 3b. Improvement in anxiety scores was greater for venlafaxine compared with fluoxetine (P = 0.0004)
Leinonen et al., 1999 ^54^ | Citalopram | 270 | KQ 3b. Improvement in anxiety scores was similar for both treatment groups (P = 0.75) | Fair
| Mirtazapine
Rush et al., 2001 ^108^ | Sertraline Bupropion SR | 248 overall; top quartile of HAM-A score with anxiety (number not provided) | KQ 3a. Depression response and remission rates were similar for both treatment groups (P = NR) | Fair
| | | KQ 3b. Improvement in anxiety scores was similar for both treatment groups (P = NR)
Sir et al., 2005 ^78^ | Sertraline | 163 overall; 120 with anxiety | KQ 3a. Improvement in depression scores (P = 0.70), depression response rates (P = 0.26), and remission rates (P = 0.44) were similar for both groups | Fair
| Venlafaxine XR | | KQ 3b. Improvement in anxiety scores was similar for both treatment groups (P = 0.32)
Trivedi et al., 2001 ^148^ and Rush et al., 2001 ^91^ | Sertraline Bupropion SR | 724 overall; top quartile of HAM-A score with anxiety (number not provided) | KQ 3a. Depression response and remission rates were similar for both active groups and placebo (P = NR) | Fair
| Placebo | | KQ 3b. Improvement in anxiety scores was similar for treatment groups (P > 0.41)
SSRI or SNRI vs. Placebo
Joliat et al., 2004 ^157^ | Fluoxetine (weekly vs. daily) | 799 overall; 374 with anxiety | KQ 3a. Depression relapse rates were similar for both medication groups and appeared better than those for placebo, but no statistical comparisons were reported (P = NR) | Fair
| Placebo | | KQ 3b. Worsening of anxiety scores appeared better for medication groups than for placebo, but there were no statistical comparisons (P = NR)
Khan et al., 1998 ^158^ | Venlafaxine (3 doses) | 403 overall; 346 with anxiety | KQ 3b. Improvement in anxiety scores for all 3 venlafaxine groups was superior to placebo group (P < 0.05); improvement was similar for the 3 venlafaxine dose groups | Fair
| Placebo

NR, not reported; SR, slow release.

Efficacy: KQ 3a: Depressive episode in patients with anxiety. Overall, six head-to-head studies and one fair placebo-controlled study indicated that antidepressant medications do not differ in treatment efficacy for depressed patients with accompanying anxiety symptoms. All seven trials analyzed a subgroup with identified high anxiety. However, only three used the same definition criteria (a HAM-D anxiety-somatization factor of 7 or more). ^78,^ ^150,^ ^157^

The head-to-head trials compared SSRIs with each other, ^149,^ ^150^ with bupropion SR, ^91,^ ^108,^ ^148^ and with SNRIs. ^64,^ ^78^ Studies appeared to compare similar doses of antidepressant medications. Two studies comparing SSRIs (including fluoxetine, paroxetine, and sertraline) found no statistically significant differences in depressive improvement, response rates, or remission rates. ^149,^ ^150^ Two studies comparing bupropion SR and sertraline found no significant differences in response or remission rates. ^91,^ ^148^ Two studies comparing an SSRI and venlafaxine showed mixed results. One found a greater decrease in depressive severity and higher response rates with venlafaxine than with fluoxetine, ^64^ and one found no statistically significant difference in depressive severity change, response rates, or remission rates between venlafaxine XR and sertraline. ^78^

One placebo-controlled trial of patients whose MDD had already responded to treatment tested the efficacy of fluoxetine against placebo in preventing a relapse of depression during continuation-phase treatment. ^157^ Fluoxetine appeared to be more efficacious than placebo in preventing a relapse of a depressive episode, but statitistical comparsions were not reported.

Efficacy: KQ 3b: Anxiety in depressed patients. Overall, results from 10 head-to-head studies and two placebo-controlled studies suggested that antidepressant medications do not differ in treatment efficacy for treating anxiety associated with MDD. Seven of these 12 trials analyzed a subgroup with high anxiety. ^64,^ ^78,^ ^108,^ ^148,^ ^150,^ ^157,^ ^158^ Only three used identical definitions to identify the high anxiety group. ^78,^ ^150,^ ^157^ In addition, outcome definitions for anxiety varied. The studies compared similar doses of antidepressants.

The head-to-head trials compared SSRIs with each other, with SNRIs, and with other second-generation drugs (bupropion, nefazodone). Four studies comparing SSRIs (including fluoxetine, sertraline, and paroxetine) found no statistically significant differences for treatment of patients' anxiety symptoms. ^35,^ ^37,^ ^38,^ ^150^ Two studies comparing sertraline and bupropion SR found no difference in anxiety reduction. ^108,^ ^148^ Two studies comparing an SSRI (fluoxetine, sertraline) with venlafaxine found mixed results; venlafaxine produced a greater decrease in anxiety severity than fluoxetine in one study, ^64^ whereas the other study reported similar anxiety reduction for venlafaxine XR and sertraline. ^78^ One study comparing paroxetine and nefazodone found no difference in anxiety reduction. ^85^ A final head-to-head study comparing citalopram to mirtazapine found no difference in anxiety reduction. ^54^

One placebo-controlled study comparing fluoxetine with placebo during continuation-phase treatment reported that anxiety worsened to a lesser degree with fluoxetine treatment, but the authors gave no statistical information. ^157^ A second placebo-controlled trial reported that venlafaxine treatment produced a statistically greater reduction in anxiety scores than placebo. ^158^

Effectiveness: KQ 3a and KQ 3b. We identified no effectiveness trial relating to treatment of depression with accompanying anxiety symptoms. We expect, however, that if any such study were to be done, it would be less likely than the efficacy trials to show any differences between medications for this population.

### Anxiety: Detailed Analysis

Head-to-head evidence. We identified 11 head-to head trials comparing the efficacy of specific medications treating depressed patients with coexisting anxiety symptoms. One study addressed only improvement in depression as an outcome (i.e., KQ 3a). ^149^ Five studies addressed only improvement in anxiety as an outcome (i.e., KQ 3b). ^35,^ ^37,^ ^38,^ ^54,^ ^85^ The remaining six articles addressed both questions.

Fluoxetine vs. paroxetine. Two studies compared the efficacy of low-to-high doses of fluoxetine with similar doses of paroxetine for treatment of anxiety. ^35,^ ^38^ Neither study required high anxiety for inclusion in the analysis.

One trial compared fluoxetine (20–80 mg/day) and paroxetine (20–50 mg/day) in a 12-week trial involving 203 patients with severe MDD. ^35^ Improvements on multiple measures of anxiety did not substantially differ between the two treatment groups.

A second study compared fluoxetine (20–60 mg/day) and paroxetine (20–40 mg/day) over 6 weeks in 90 patients with severe MDD. ^38^ Mean baseline anxiety severity was comparable, with each group having a moderate to severe degree of anxiety. Improvements in HAM-A scores were similar between the two groups.

Fluoxetine vs. paroxetine vs. placebo. One study compared low-to-high doses of fluoxetine, low-to-medium doses of paroxetine, and placebo in a pooled analysis of two multicenter trials, which were each 12 weeks in duration. ^37^ Patients had MDD of at least moderate severity. The analysis pooled data from five sites (not all) in the two trials; no explanation was provided for the limited inclusion. The outcome addressed was the effect of medications on co-occurring anxiety symptoms. Inclusion in the analysis did not require a high anxiety score; baseline mean Covi Anxiety Scale scores were similar (< 7) in all groups, consistent with patients not being anxious. Improvement in anxiety symptoms on the Covi Anxiety Scale did not differ among the three groups.

Fluoxetine vs. paroxetine vs. sertraline. One RCT compared low-to-high dose fluoxetine (20–60 mg/day), low-to-high dose paroxetine (20–60 mg/day), and low-to-high dose sertraline (50–200 mg/day) over 10 to 16 weeks in patients with MDD of at least moderate severity and high anxiety (as defined by a score on the six-item HAM-D anxiety-somatization scale ≥ 7 [range 0–18]). ^150^ Analyses were performed in the subgroup with high anxiety (n = 108 patients from a trial with 284 participants overall); the outcomes included both depressive measures and anxiety measures. Depressive outcomes between the three medications were similar, as measured by improvement in HAM-D total scores, by response rates (≥ 50 percent reduction in HAM-D score; fluoxetine, 73 percent, paroxetine, 77 percent; and sertraline, 86 percent, P = 0.405), and by remission rates (HAM-D endpoint ≤ 7; fluoxetine, 53 percent; paroxetine, 50 percent; and sertraline, 62 percent; P = 0.588). Likewise, authors reported no difference between the three groups with respect to anxiety outcomes (measured by overall change on HAM-D anxiety-somatization score).

Fluoxetine vs. sertraline. One study compared low-to-medium doses of fluoxetine (20–40 mg/day) and sertraline (50–100 mg/day) over 6 weeks in patients with MDD of at least moderate severity who also had high anxiety as defined by a Covi Anxiety Scale score ≥ 7. ^149^ The outcome was depression response. Authors reported that response rates (defined by ≥ 50 percent reduction in HAM-D total score) did not differ between the fluoxetine-treated group (48 percent) and the sertraline-treated group (47 percent).

Citalopram vs. mirtazapine. One study compared the efficacy of low-to-high dose citalopram (20–60 mg/day) and low-to-high dose mirtazapine (15–60 mg/day) over 8 weeks in 270 patients with MDD of at least moderate severity. ^54^ The outcome was treatment effect on anxiety as measured by HAM-A scores. However, patients were not categorized by anxiety level, and the analysis included all patients with MDD, not merely those with anxiety. The improvement in anxiety symptoms did not differ between citalopram and mirtazapine (mean HAM-A change in both groups was approximately -13 points).

Fluoxetine vs. venlafaxine. One trial compared low-to-medium doses of fluoxetine (20–40 mg/day) with low doses of venlafaxine (75–150 mg/day) over 12 weeks in 146 moderately depressed patients with MDD who had a Covi Anxiety Scale score ≥ 8 (consistent with clinically relevant anxiety). ^64^ Both depression and anxiety outcomes were reported. The improvement in depressive severity on the HAM-D was significantly greater in the venlafaxine-treated group than the fluoxetine-treated group (-14.4 points vs. -10.4 points, P = 0.0048). Similarly, the mean reduction on the Covi Anxiety Scale was greater for venlafaxine than for fluoxetine (-5.7 points vs. -3.9 points, P = 0.0004).

Sertraline vs. bupropion SR. One efficacy trial compared low-to-high dose sertraline with low-dose Bupropion SR over 16 weeks in 248 patients with MDD of moderate severity. ^108^ High anxiety patients were defined as those with scores in the top quartile on HAM-A (≥ 19, consistent with at least moderate anxiety). Outcomes included both depression (HAM-D-21) and anxiety (HAM-A) measures. For the subgroup with high anxiety, depression response rates (≥ 50 percent reduction in total score, approximately 70 percent in each group) and remission rates (endpoint ≤ 8, approximately 70 percent in each group) were similar. Likewise, in the high-anxiety subgroup, authors reported no difference in anxiety reduction (measured by mean change in HAM-A) between patients treated with sertraline (-10.0) and bupropion (-9.7).

Sertraline vs. bupropion SR vs. placebo. One pooled analysis of two 8-week RCTs compared the efficacy of low-to-high dose sertraline (50–200 mg/day), low-to-high dose Bupropion SR (150 mg-400 mg/day), and placebo in 724 patients with MDD of at least moderate severity. ^91,^ ^148^ One set of investigators reported on depressive outcomes; ^91^ the other set reported on anxiety outcomes. ^148^

The two sets of investigators defined high anxiety in slightly different ways. In the study on depressive outcomes, ^91^ the high anxiety subgroup comprised patients with a HAM-A score in the top quartile of enrolled patients (HAM-A ≥ 25). For this subgroup, rates of depression response (defined as HAM-D-21 reduction of ≥ 50 percent; estimated by us from the figure in the article to be approximately 60 percent to 70 percent for each of three arms) and of remission (HAM-D-21 ≤ 8; estimated to be 25 percent to 35 percent for each arm) did not differ by treatment group. Furthermore, the authors did not report any significant relationship between quartile of baseline anxiety and antidepressant response for any of the three treatment arms.

In the study on anxiety outcomes, ^148^ investigators defined baseline anxiety as minimal (HAM-A ≤ 14), moderate (HAM-A 15–19), or severe (HAM-A ≥ 20). They reported no differences in mean HAM-A reduction between patients treated with bupropion SR and those treated with sertraline for any of the anxiety severity subgroups (severe, bupropion SR ~ -15 points vs. sertraline ~ -13 points; moderate, bupropion SR ~ -8 vs. sertraline ~ -9; minimal, bupropion SR ~ -6 vs. sertraline ~ -5; all data estimated from figures in the paper).

Sertraline vs. venlafaxine XR. One efficacy study compared low-to-high dose sertraline (50–150 mg/day) with low-to-high dose venlafaxine XR (75–225 mg/day) over 8 weeks in a subgroup of 120 patients with MDD of at least moderate severity and accompanying anxiety, defined as a HAM-D anxiety-somatization score of ≥ 7. ^78^ Outcomes included both depressive (HAM-D-17) and anxiety (HAM-A) measures. Authors reported no difference between treatment groups in mean depressive severity reduction (-17.3 for sertraline vs. -14.8 for venlafaxine XR, P = 0.7), depression response rates (≥ 50 percent reduction in total score, 79.6 percent for sertraline vs. 68.9 percent for venlafaxine XR, P = 0.26), or depression remission rates (endpoint ≤ 7, 63.0 percent for sertraline vs. 54.1 percent with venlafaxine XR, P = 0.44).

Anxiety symptom outcomes did not differ between treatment groups for the overall study population (N = 163) or for the high anxiety subgroup (n = 120). In the overall study population, the mean reduction in HAM-A was -14.1 for the sertraline-treated group and -12.9 for the venlafaxine XR-treated group (P = 0.32). In the high anxiety subgroup, response on the HAM-D anxiety-somatization subscale (criteria not described) was similar for both treatment arms (83.3 percent for sertraline vs. 70.5 percent for venlafaxine XR, P = 0.12).

Paroxetine vs. nefazodone. One RCT compared the low-to-medium dose paroxetine (20–40 mg/day) with low-to-high dose nefazodone (200–600 mg/day) for treatment of accompanying anxiety symptoms over 8 weeks in patients with moderate to severe MDD. ^85^ Inclusion in the analysis did not require high anxiety, and patients were not categorized based on anxiety level; the outcome was the mean difference between treatment groups in HAM-A improvement. Authors reported similar improvement in HAM-A for the treatment groups (-8.0 for paroxetine vs. -6.5 for nefazodone, P = NS, 95% CI for difference between groups, -0.7–3.8).

Placebo-controlled evidence. Two trials compared efficacy of a second-generation antidepressant only against placebo. One involved an SSRI (for both KQ 3a and 3b), the other examined an SNRI (for only KQ 3b).

Fluoxetine vs. placebo. One study compared the efficacy of two different preparations of fluoxetine and placebo in preventing depression relapse in patients whose depression had been successfully treated. ^157^ The study involved continuation-phase treatment, where the clinical goal was to prevent relapse of a successfully treated depressive episode.

The authors pooled data from two 25-week RCTs. Patients who were in remission (from study 1) or who responded (from study 2) to approximately 3 months of open-label fluoxetine treatment were randomly assigned to placebo, continued treatment with 20 mg/day fluoxetine, or (in study 2 only) 90 mg/week delayed-release fluoxetine. High anxiety patients were defined as those with a HAM-D-17 anxiety-somatization subscale score of ≥ 7 at baseline.

In the high anxiety subgroup (n = 374), depression relapse rates appeared to be lower in the fluoxetine daily and fluoxetine weekly groups (27.8 percent and 28.5 percent, respectively) than in the placebo group (53.3 percent); the authors did not provide statistical information.

Anxiety levels increased (worsened) for all treatment arms in the high anxiety subgroup. This increase appeared less in the fluoxetine daily and weekly groups (1.92 and 1.93) than in the placebo group (3.12), but again statistical significance was not reported.

Venlafaxine vs. placebo. One 12-week study randomly assigned patients with severe MDD to one of three doses of immediate-release venlafaxine—75 mg/day (low), 150 mg/day (low), or 200 mg/day (medium)—or to placebo. ^158^ Inclusion did not require a high anxiety score. Treatment effects on anxiety were analyzed in a subgroup of 346 patients with accompanying anxiety (defined as a score of ≥ 2 [at least moderate] on the HAM-D-17 anxiety-psychic item, range 0–4). Each treatment arm had an equivalent number of patients with high anxiety. All four treatment arms experienced a reduction in anxiety. Patients in all three venlafaxine groups had statistically significant greater improvement in HAM-D anxiety-psychic and anxiety-somatization scores compared with the placebo group. The three venlafaxine groups did not differ from each other in anxiety outcomes.

### Insomnia: Key Points

We identified six head-to-head studies that compared the effects of medications on treatment of depression and accompanying insomnia (Table 21). ^41,^ ^60,^ ^81,^ ^82,^ ^96,^ ^151^ Three of these trials required insomnia for inclusion in the analysis, although the definitions used varied by study and consisted of brief 1- or 3-item measures. ^41,^ ^81,^ ^151^ Three other trials did not require insomnia for inclusion but rather assessed sleep for all subjects. ^60,^ ^82,^ ^96^ The three studies that identified an insomnia group provided data addressing both KQ 3a (effects on depressive symptoms) and KQ 3b (effects on insomnia). ^41,^ ^81,^ ^151^ The other studies provided information solely on insomnia outcomes. We rated the strength of evidence for both depression outcomes in patients with accompanying insomnia (KQ 3a) and insomnia outcomes in patients with depression (KQ 3b) as low. All studies were of fair quality.

Table 21 Studies of adults with major depressive disorders and accompanying insomnia

Study | Interventions | N | Results | Quality Rating
Fava et al., 2002 ^41^ | Fluoxetine | 284 overall; 125 with insomnia | KQ 3a. Improvement in depression scores was similar for all groups (P = 0.853) | Fair
| Paroxetine | | KQ 3b. Improvement in sleep was similar for all groups (P = 0.852)
| Sertraline
Lader et al., 2005 ^151^ | Citalopram | 1,321 overall; 638 with insomnia | KQ 3a. Improvement in depression scores for escitalopram was superior to citalopram and placebo (P < 0.05) | Fair
| Escitalopram | | KQ 3b. Improvement in sleep for escitalopram was superior to citalopram and placebo (P < 0.01)
| Placebo
Rush et al., 1998 ^81^ | Fluoxetine | 125 (all with insomnia) | KQ 3a. Improvement in depression scores (95% CI for difference between groups, -1.7–2.8) and depression response rates (P = NR) were similar for both groups | Fair
| Nefazodone | | KQ 3b. Improvement in sleep for nefazodone was superior to fluoxetine (P < 0.05)
Beasley et al., 1991 ^82^ | Fluoxetine | 126 | KQ 3b. Improvement in sleep scores was greater for trazodone than for fluoxetine (P = 0.001) | Fair
| Trazodone
Cunningham et al., 1994 ^96^ | Venlafaxine | 227 | KQ 3b. Improvement in sleep scores was greater for trazodone than venlafaxine (P < 0.05) | Fair
| Trazodone
Versiani et al., 2005 ^60^ | Fluoxetine | 299 | KQ 3b. Sleep quality improved similarly for both groups (overall score not reported) | Fair
| Mirtazapine

Efficacy: KQ 3a: Depressive episode in patients with insomnia. Three head-to-head studies provide mixed evidence regarding comparative efficacy of medications for treatment of depression in patients with accompanying insomnia. ^41,^ ^81,^ ^151^ One study found a slightly greater reduction in depressive severity for escitalopram than for citalopram or placebo. ^151^ The other two studies showed no statistically significant differences in depressive outcomes for fluoxetine compared with paroxetine and sertraline ^41^ and for fluoxetine compared with nefazodone. ^81^

Efficacy: KQ 3b: Insomnia in depressed patients. Six head-to-head studies provided mixed evidence about the effects of antidepressants on insomnia in patients with depression. Two studies reported greater improvement in sleep scores for trazodone than for fluoxetine ^82^ and venlafaxine. ^96^ However, neither of these trials analyzed a subgroup of patients with insomnia. One study each reported better sleep outcomes for escitalopram than for citalopram ^151^ and for nefazodone than for fluoxetine. ^81^ The clinical meaning of the small sleep outcome differences reported in these studies is unclear. One study each found no statistically significant differences between fluoxetine, paroxetine, and sertaline ^41^ and between fluoxetine and mirtazapine. ^60^

Effectiveness. We identified no effectiveness studies concerning depression and insomnia.

### Insomnia: Detailed Analysis

Head-to-head evidence. Six head-to-head trials addressed this issue.

Citalopram vs. escitalopram vs. placebo. One study compared low-to-medium dose citalopram (20–40 mg/day) with low-to-medium dose escitalopram (10–20 mg/day) in a pooled secondary analysis of three 8-week RCTs of patients with MDD of at least moderate severity as measured by the MADRS (10 items, individual score range 0–6, total score range 0–60). ^151^ Insomnia was defined as a score of 4 or greater on the single MADRS sleep item (range 0–6). Among 638 patients meeting insomnia criteria, depressive symptoms improved (i.e., MADRS scores declined) for all three treatment arms. Improvement was greater for escitalopram than for citalopram and placebo (escitalopram, -16.47; citalopram, -14.02; placebo, -12.2; P < 0.01 for escitalopram vs. citalopram, P < 0.001 for escitalopram vs. placebo; P = NR, not significant for citalopram vs. placebo).

Insomnia results also favored escitalopram. Mean improvement on the MADRS sleep item was better in the escitalopram group than in the citalopram and placebo groups (escitalopram, -1.65; citalopram, -1.31; placebo, -1.26; P < 0.01 for escitalopram vs. citalopram, P < 0.01 for escitalopram vs. placebo, P = NS for citalopram vs. placebo). Escitalopram-treated patients were more likely than others to achieve improvement in insomnia, defined as a score of 0 or 1 on the MADRS sleep item at week 8 (43.6 percent for escitalopram, 28.4 percent for citalopram, 24.4 percent for placebo, overall P < 0.001).

Fluoxetine vs. paroxetine vs. sertraline. One study compared low-to-high doses of fluoxetine (20–60 mg/day), paroxetine (20–60 mg/day), and sertraline (50–200 mg/day) in a study of MDD patients with at least a moderate degree of depression that lasted between 10 and 16 weeks. ^41^ A secondary analysis evaluated depression outcomes in patients with insomnia, defined as a score of at least 4 points on the HAM-D sleep disturbance subscale (a 0 to 6 scale consisting of a summed score of three HAM-D-17 sleep items [assessing initial, middle, and terminal insomnia], where higher scores indicated worse insomnia). For the 125 patients in this subgroup, the three SSRIs did not differ significantly on the HAM-D score (overall P = 0.853).

This study also assessed the effect of medications on insomnia. Again, treatment groups did not differ. Insomnia (measured as above on the 6-point scale) improved to a similar degree for all three groups (fluoxetine, -3.1; paroxetine, -2.9; sertraline, -3.1; overall P = 0.852).

Fluoxetine vs. trazodone. One study compared low-dose fluoxetine (95 percent of participants took 20 mg/day) with low-to-medium dose trazodone (50–400 mg/day, median 250 mg) over 6 weeks in patients with major depression. ^82^ Investigators did not require insomnia symptoms for inclusion and did not analyze an insomnia subgroup. Overall HAM-D sleep disturbance scores improved more in the trazodone group than in the fluoxetine group (-2.7 vs. -1.6; P = 0.001).

Fluoxetine vs. nefazodone. One study compared low-to-moderate dose fluoxetine (20–40 mg/day) and nefazodone (200–500 mg/day) in a pooled analysis of three 8-week RCTs of patients with MDD of at least moderate severity, as measured by HAM-D-17. ^81^ The analysis was conducted on a subgroup of 122 patients with insomnia, defined by patient self-report at study entry of difficulty falling asleep each night, waking up during the night, or being unable to fall asleep again after getting out of bed. Depressive outcomes did not differ between treatment groups. The mean improvement in HAM-D was 12.2 points for fluoxetine and 11.4 for nefazodone (95% CI for difference, -1.7–2.8). Response rates, defined as HAM-D < 10, were essentially identical (45 percent for fluoxetine, 47 percent for nefazodone).

Sleep outcomes from the same study favored nefazodone. Patients receiving nefazodone had a mean improvement of -2.3 points on the HAM-D sleep disturbance items (range 0–6); the improvement for patients receiving fluoxetine was -1.6 (P < 0.05). Nefazodone-treated patients also had greater improvement on a secondary sleep measure, the Inventory for Depressive Symptomatology sleep items relating to early, middle, and late insomnia and hypersomnia (range 0–12, scored such that higher scores are better); patients receiving nefazodone improved by 2.4 points on this measure, compared with 1.7 points for patients treated with fluoxetine (P < 0.01).

Fluoxetine vs. mirtazapine. One study compared low-to-medium doses of fluoxetine (20–40 mg/day) with low-to-high doses of mirtazapine in an 8-week study of patients with severe MDD. ^60^ The investigators did not categorize subgroups of patients by the presence or absence of insomnia. They compared outcomes on the Leeds Sleep Evaluation Questionnaire for all trial participants. Total scores were not reported; efficacy on individual items did not differ in any substantial or consistent way between treatment groups.

Venlafaxine vs. trazodone vs. placebo. One study compared low-to-medium doses of venlafaxine (75–200 mg/day) and trazodone (150–400 mg/day) over 6 weeks in patients with major depression. ^96^ Investigators did not require insomnia symptoms for inclusion and did not analyze an insomnia subgroup. HAM-D sleep disturbance scores were better (lower) at endpoint in patients receiving trazodone than in those receiving either venlafaxine or placebo (score 1.42 for trazodone, 2.22 for venlafaxine, 1.95 for placebo; P < 0.05). HAM-D sleep disturbance factor scores at endpoint did not differ between venlafaxine and placebo (P = NR).

Placebo-controlled evidence. We identified no placebo-controlled trials for depression and insomnia.

### Melancholia: Key Points

We identified three head-to-head studies ^69,^ ^149,^ ^152^ and one placebo-controlled study ^159^ (Table 22). All addressed KQ 3a: whether, for patients with melancholia, medications differed in their effect on depressive symptoms. All but one study was rated fair quality; one was rated poor. We rated the strength of evidence for the comparative efficacy and effectiveness of second-generation antidepressants for treating depression in patients with melancholia as low.

Table 22 Studies of adults with major depressive disorders and accompanying melancholia

Study | Interventions | N | Results | Quality Rating
Flament et al., 1999 ^149^ | Fluoxetine | 286 overall; 197 with melancholia | KQ 3a. Depression response rates for sertraline were superior to fluoxetine (P < 0.05); improvement in depression scores was similar for both groups (P = NR) | Fair
| Sertraline
Clerc et al., 1994 ^152^ | Fluoxetine | 68 (all with melancholia) | KQ 3a. Improvement in depression scores was better for venlafaxine than fluoxetine (P = 0.027); response rates did not differ (P = 0.08) | Poor
| Venlafaxine
Tzanakaki et al., 2000 ^69^ | Fluoxetine | 109 (all with melancholia) | KQ 3a. Depression response and remission rates were similar for both groups (P = NR) | Fair
| Venlafaxine
Mallinckrodt et al., 2005 ^159^ | Duloxetine | 2,342 overall; 1,572 with melancholia | KQ 3a. Improvement in depression scores was better for duloxetine than placebo (P < 0.001) | Fair
| Placebo

NR, not reported.

We found no evidence addressing the comparative efficacy and effectiveness of second-generation antidepressants for the treatment of accompanying melancholic symptoms (KQ 3b).

Efficacy: KQ 3a: Depressive episode in patients with melancholia. Three head-to-head studies compared fluoxetine with sertraline ^149^ or venlafaxine. ^69,^ ^152^ One study found a greater response rate in patients receiving sertraline than fluoxetine. ^149^ Another found no difference between the fluoxetine and venlafaxine groups in response and remission rates. ^69^ One poor-quality study found a greater decrease in depressive severity for venlafaxine than for fluoxetine but only a nonsignificant tendency toward a greater rate of response (a more robust outcome). ^152^

One placebo-controlled study, a pooled data analysis of duloxetine trials, found a greater decrease in depressive severity for duloxetine than for placebo. ^159^

Efficacy: KQ 3b: Melancholia in depressed patients. We identified no efficacy trials addressing treatment of melancholic symptoms.

Effectiveness: KQ 3a and KQ 3b. We identified no effectiveness trials for depressed patients with accompanying melancholia.

### Melancholia: Detailed Analysis

Head-to-head evidence. We identified two fair-quality studies ^69,^ ^149^ and one poor-quality study, ^152^ all 6 weeks in length.

Fluoxetine vs. sertraline. One study enrolled patients who were at least moderately depressed (either MDD or the depressed phase of bipolar disorder); patients were randomized to low-to-medium dose fluoxetine (20–40 mg/day) or sertraline (50–100 mg/day) for 6 weeks. ^149^ In the subgroup with melancholia by DSM-III-R criteria, depression response rates (≥ 50 percent decrease in HAM-D-17) were significantly better for sertraline than for fluoxetine (59 percent vs. 44 percent, P < 0.05).

Fluoxetine vs. venlafaxine. Two studies provided mixed results on the relative efficacy of moderate-to-high doses of fluoxetine and venlafaxine. One trial involved severely depressed hospitalized patients or outpatients with MDD and melancholia per DSM-IV criteria; patients were randomized to either 60 mg/day of fluoxetine or 225 mg/day of venlafaxine. ^69^ Authors reported no statistically significant difference in response rates (≥ 50 percent decrease in HAM-D-21 or MADRS and CGI improvement score of 1 or 2) between groups (58 percent for fluoxetine, 65 percent for venlafaxine). Similarly, remission rates (final HAM-D-21 score < 7) did not differ significantly (fluoxetine, 35.8 percent; venlafaxine, 40.7 percent).

The other study (rated poor) involved severely depressed hospitalized patients with MDD and melancholia per DSM-III-R criteria; investigators randomized patients to either 200 mg/day of venlafaxine or 40 mg/day of fluoxetine. ^152^ Using ITT approaches, the investigators determined that the improvement in depressive severity (mean decrease in HAM-D-21 score) was significantly greater in the venlafaxine group than in the fluoxetine group (-18 points vs. -12.4 points, P = 0.027). Response rates (≥ 50 percent decrease in HAM-D severity) did not differ significantly between groups (73 percent venlafaxine vs. 50 percent fluoxetine; P = 0.08).

Placebo-controlled evidence. Duloxetine vs. placebo. One study compared low-to-high doses of duloxetine (40–120 mg/day) with placebo for MDD patients with at least moderate depressive severity. ^159^ The authors pooled results of eight RCTs of 9 weeks' duration (all part of the New Drug Application to the FDA for duloxetine) and identified a subgroup of patients (n = 1,572) with melancholia, per DSM-IV criteria, on whom to conduct this secondary analysis. Accordingly, the randomization was not stratified by a melancholic designation. Mean reductions in HAM-D-17 score were 8.97 for patients receiving duloxetine and 6.57 for those receiving placebo (P < 0.001), suggesting a benefit for duloxetine, on average, of slightly more than 2 points.

### Pain: Key Points

We included two head-to-head trials ^71,^ ^153^ and three placebo-controlled trials ^154^ – ^156^ that assessed the efficacy of antidepressants for treatment of depression and accompanying pain symptoms (Table 23). One placebo-controlled trial required baseline pain for inclusion; this study provided data addressing both KQ 3a (depression outcomes in patients with accompanying pain) and KQ 3b (pain outcomes in MDD patients). ^154^ The other four trials did not require pain for inclusion, but rather assessed pain symptoms for all subjects; these trials provided information for KQ 3b (pain outcomes) only. ^71,^ ^153,^ ^155,^ ^156^ All but one study was rated fair quality; one was rated poor. We rated the strength of evidence for both questions as low.

Efficacy: KQ 3a: Depressive episode in patients with pain. One study found no difference in efficacy between duloxetine and placebo for treatment of depression in patients with mild to moderate pain. ^154^

Efficacy: KQ 3b: Pain in depressed patients. One fair-quality trial and one poor-quality trial reported similar efficacy for duloxetine and paroxetine for treating pain symptoms in MDD patients. ^71,^ ^153^ Five placebo-controlled studies provided mixed evidence for efficacy of active drugs compared to placebo for treatment of accompanying pain. Five trials compared duloxetine with placebo; ^71,^ ^153^ – ^156^ three of these reported statistically greater pain improvement in at least one duloxetine treatment arm. ^153,^ ^155,^ ^156^ Two studies compared paroxetine with placebo; ^71,^ ^153^ one found a statistically greater improvement for paroxetine. ^71^ Overall, mean differences in pain scores between groups were small and may not be clinically meaningful.

No studies evaluated the efficacy of antidepressants in a subgroup of patients with moderate to severe pain. For outcome measures, all five studies used a visual analog scale (VAS) for overall pain (0 mm to 100 mm scale, where higher scores indicate worse pain); one trial also used the Brief Pain Inventory (BPI) severity scale (0 to 10 scale, where higher scores indicate worse pain). ^154^ No study reported percentages of patients with clinically important improvement in pain. All studies were funded by the maker of duloxetine.

Effectiveness: KQ 3a: Depressive episode and KQ 3b: Accompanying symptoms. We identified no effectiveness trials for treatment of patients with depression and accompanying pain.

### Pain: Detailed Analysis

Head-to-head evidence. Duloxetine vs. paroxetine vs. placebo. Two multicenter trials compared the efficacy of duloxetine, paroxetine, and placebo. Pain symptoms were not required for inclusion in either study. Moreover, baseline pain severity was mild in both trials.

One trial compared two high doses of duloxetine (80 mg/day and 120 mg/day) to low-dose paroxetine (20 mg/day) and placebo. ^71^ Improvement in overall pain (decrease in 100 mm VAS) was similar for both duloxetine formulations and paroxetine (duloxetine 80 mg/day, -11.2 mm; duloxetine 120 mg/day, -12.2 mm; paroxetine, -16.0 mm; P = 0.77 for duloxetine 80 mg vs. paroxetine; P = 0.66 for duloxetine 120 mg vs. paroxetine). Mean pain improvement was statistically significantly superior to placebo for paroxetine (P = 0.035) but not for either duloxetine formulation (P = 0.063 for duloxetine 80 mg vs. placebo; P = 0.086 for duloxetine 120 mg vs. placebo).

One multicenter trial (rated poor quality) compared the efficacy of low-dose duloxetine (40 mg/day), high-dose duloxetine (80 mg/day), and low-dose paroxetine (20 mg/day) for treatment of accompanying pain in patients with MDD over 8 weeks. ^153^ Statistical comparisons between active treatment groups were not reported, but median change from baseline to endpoint in VAS overall pain was minimal and similar for all groups (-4 mm for duloxetine 40 mg, -7.5 mm for duloxetine 80 mg, -3.0 mm for paroxetine, 0 mm for placebo). Pain improvement in the duloxetine 80 mg group was small but statistically significantly better than placebo (P = 0.005). Median improvement in pain scores did not differ between duloxetine 40 mg and placebo (P = 0.172) or between paroxetine and placebo (P = 0.088).

Placebo-controlled evidence. Duloxetine vs. placebo. One multicenter trial compared high-dose duloxetine (60 mg/day) with placebo over 7 weeks for treating patients with MDD and pain symptoms. ^154^ Participants were 282 outpatients who met DSM-IV criteria for major depression and reported accompanying pain, with a BPI average pain score of 2 or more at baseline. Patients who had “a primary pain complaint with a diagnosis such as arthritis, fibromyalgia, migraine headache or acute injury” were excluded. Mean baseline pain severity was moderate (BPI average: 4.85 for duloxetine, 4.62 for placebo). The authors found no statistically significant difference between duloxetine and placebo on either depression or pain outcomes. Mean HAM-D-17 improvement was similar for the groups (duloxetine, -10.9; placebo, -10.3; P = 0.544). Depression response and remission rates did not differ between duloxetine and placebo (response 42 percent vs. 40 percent, P = 0.901; remission 23 percent vs. 24 percent, P = 0.887). Mean reduction in BPI average pain was similar for duloxetine and placebo (-2.32 vs. -1.80; P = 0.066). Mean changes in BPI worst pain, least pain, and current pain intensity did not differ between treatment groups (P > 0.10 for all comparisons). Mean changes in VAS overall pain did not differ between treatment groups (values NR, P = NR).

Two trials compared the efficacy of high-dose duloxetine (60 mg/day) to placebo over 9 weeks for treatment of pain in patients with depression. ^155,^ ^156^ Inclusion criteria were similar in both studies: participants met DSM-IV criteria for MDD but were not required to have pain symptoms. Mean baseline pain severity was mild (VAS for overall pain: 29.0 and 25.4 for duloxetine, 28.2 and 26.2 for placebo). Both studies reported small but statistically significant differences in VAS overall pain improvement favoring duloxetine over placebo: -8.5 mm vs. -1.3 mm (P = 0.019) ^155^ and -11.0 mm vs. -6.4 mm (P = 0.037). ^156^

### Psychomotor Change: Key Points

One head-to-head trial addressed KQ 3a on depression response in subgroups with psychomotor retardation or psychomotor agitation (Table 24). ^149^ We rated the strength of evidence for this issue as low. We found no evidence for the comparative efficacy and effectiveness of second-generation antidepressants for the treatment of accompanying psychomotor symptoms (KQ 3b).

Table 24 Studies of adults with major depressive disorders and accompanying psychomotor change

Study | Interventions | N | Results | Quality Rating
Flament et al., 1999 ^149^ | Fluoxetine | 286 | KQ 3a. In patients with psychomotor retardation, depression scores and response rates were similar for both groups (P = NR) | Fair
| Sertraline | | In patients with psychomotor agitation, depression scores (P = 0.02) and response rates (P = 0.04) were superior for sertraline

NR, not reported.

Efficacy: KQ 3a: Depressive episode in patients with psychomotor changes. One study provided evidence that fluoxetine and sertraline have similar efficacy for treatment of depression in patients with psychomotor retardation. The same study reported that sertraline was more efficacious than fluoxetine for treatment of depression in patients with psychomotor agitation. ^149^

Efficacy: KQ 3b: Psychomotor changes in depressed patients. We identified no efficacy trials addressing treatment of psychomotor change symptoms.

Effectiveness: KQ 3a: Depressive episode and KQ 3b: Accompanying symptoms. We found no effectiveness trials concerning patients with depression and accompanying psychomotor problems.

### Psychomotor Change: Detailed Analysis

Head-to-head evidence. Fluoxetine vs. sertraline. One 6-week trial compared low-to-medium doses of fluoxetine and sertraline for treating depression in subgroups of patients with MDD or the depressed phase of bipolar disorder and psychomotor retardation or psychomotor agitation. ^149^ The subgroup with psychomotor retardation comprised 47 patients with a score of 2 or more on HAM-D item 8 (retardation) and 1 or less on item 9 (agitation). In this subgroup, mean HAM-D scores improved similarly for fluoxetine- and sertraline-treated patients (-10.7 vs. -9.1 points, P = NR). Response rates (≥ 50 percent improvement on HAM-D-17 total score) were also similar for fluoxetine and sertraline (46 percent vs. 48 percent, P = NR). The same study evaluated depression response in a subgroup of 78 patients with psychomotor agitation, defined as a score of 1 or less on HAM-D item 8 and 2 or more on item 9. Among patients with psychomotor agitation, improvement in HAM-D total score was greater in patients receiving sertraline than in those receiving fluoxetine (-12.4 vs. -8.7 points, P = 0.02). Response rates were also significantly better for sertraline than for fluoxetine (62 percent vs. 39 percent, P = 0.04).

Placebo-controlled evidence. We identified no placebo-controlled trials involving this patient population.

### Somatization: Key Points

We identified one open-label, head-to-head effectiveness trial that compared effects of medications on accompanying somatization in depressed primary-care patients (KQ 3b) (Table 25). ^49^ The grade of evidence for the comparative efficacy and effectiveness of medications for the treatment of accompanying somatization (KQ 3b) is low.

Table 25 Studies of adults with major depressive disorders and accompanying somatization

Study | Interventions | N | Results | Quality Rating
Kroenke et al., 2001 ^49^ | Fluoxetine | 601 | KQ 3b. Improvement in somatization scores was similar in all groups (P = NR) | Fair
| Paroxetine
| Sertraline

NR, not reported.

Efficacy: KQ 3a: Depressive episode and KQ 3b: Accompanying symptoms. We identified no efficacy trials that addressed either of these questions in patients with depression and somatization.

Effectiveness: KQ 3a: Depressive episode in patients with somatization. We identified no trials addressing treatment of depression in subgroups of patients with somatization.

Effectiveness: KQ 3b: Somatization in depressed patients. One open-label study provided evidence for the comparative effectiveness of SSRIs for treatment of accompanying somatization in patients with depression. ^49^ This trial found no difference in effectiveness among paroxetine, fluoxetine, and sertraline on a somatization severity scale measure.

### Somatization: Detailed Analysis

Head-to-head evidence. Fluoxetine vs. paroxetine vs. sertraline. One open-label, head-to head trial compared the effectiveness of low-dose fluoxetine, paroxetine, and sertraline for the treatment of depression in primary care over 9 months. ^49^ Somatization severity was measured using the Patient Health Questionnaire Somatization Severity scale (0–28 scale, where higher scores indicate worse severity). The report did not present analyses stratified by levels of somatization severity. The authors reported no statistically significant differences in somatization severity scores among treatment groups (-3.1 for fluoxetine, -3.2 for paroxetine, and -4.1 for sertraline, P = NR).

Placebo-controlled evidence. We identified no placebo-controlled trials addressing efficacy or effectiveness of treating patients with depression and somatization.

## Key Question 4: Comparative harms and adherence for second-generation antidepressants

### Overview

Most of the studies that examined the efficacy of one drug relative to another also determined differences in harms. Methods of adverse events assessment differed greatly. Few studies used objective scales such as the UKU-SES (Utvalg for Kliniske Undersogelser Side Effect Scale) or the adverse reaction terminology from the World Health Organization (WHO). Most studies combined patient-reported adverse events with a regular clinical examination by an investigator. Determining whether assessment methods were unbiased and adequate was often difficult. Rarely were adverse events prespecified and defined. Short study durations and small sample sizes also limited the validity of adverse events assessment in many trials.

Few RCTs were designed to assess adverse events as primary outcomes. Most published studies were post hoc analyses or retrospective reviews of databases. We included observational studies if the sample size was larger than 100 and the study duration was at least 3 months.

Detailed information on included studies can be found in Evidence Table 5 in Appendix D; information on systematic reviews and meta-analyses on this topic appears in Evidence Table 6. Most studies were rated fair quality; for three studies, a quality grade was not applicable because of the nature of the study design. Studies rated other than fair are noted in text.

### Adverse Events and Discontinuation Rates: Key Points

We analyzed adverse events data of 72 head-to-head efficacy studies of 16,780 patients and 39 additional studies of both experimental and observational design. Of these, only five were designed primarily to detect differences in adverse events. The method of adverse events assessment in efficacy trials differed greatly. Few studies used objective scales. Determining whether assessment methods were unbiased and adequate was often difficult.

In efficacy trials, on average, 61 percent of patients experienced at least one adverse event during treatment. Nausea, headache, diarrhea, fatigue, dizziness, sweating, sexual dysfunction, tremor, dry mouth, and weight gain were the commonly reported adverse events. Overall, second-generation antidepressants led to similar adverse events.

However, results from multiple head-to-head RCTs document that the frequencies of specific adverse events can differ among drugs. These findings are generally consistent with results from observational studies. Specifically:

- Venlafaxine was associated with an approximately 10 percent (95% CI, 4–17 percent) higher incidence of nausea and vomiting than SSRIs as a class. In addition, pooled discontinuation rates because of adverse events in efficacy trials were statistically significantly higher for venlafaxine than for SSRIs (RR, 1.50; 95% CI, 1.21–1.84).
- In most studies, sertraline led to higher rates of diarrhea than comparator drugs (bupropion, citalopram, fluoxetine, fluvoxamine, mirtazapine, nefazodone, paroxetine, venlafaxine). ^30,^ ^42,^ ^44^ – ^46,^ ^51,^ ^53,^ ^76,^ ^77,^ ^90,^ ^92,^ ^108,^ ^110,^ ^111,^ ^150^ Incidence was 8 percent (95% CI, 3–11 percent) higher than with comparator drugs. Whether this finding can be extrapolated to comparisons of sertraline with other second-generation antidepressants remains unclear.
- Mirtazapine led to higher weight gains than comparator drugs. ^59^ – ^61,^ ^72,^ ^73,^ ^93,^ ^94^ Mean weight gains relative to pretreatment weights ranged from 0.8 kg to 3.0 kg after 6 weeks to 8 weeks of treatment. Paroxetine had higher weight gains than fluoxetine and sertraline. ^41,^ ^48^
- Trazodone was associated with an approximately 16 percent (3 percent less to 36 percent higher) higher incidence of somnolence than comparator drugs (bupropion, fluoxetine, mirtazapine, paroxetine, venlafaxine). ^82,^ ^83,^ ^87,^ ^94,^ ^96,^ ^97^ Whether this finding can be extrapolated to comparisons of trazodone with other second-generation antidepressants remains unclear.

Discontinuation syndromes (e.g., headache, dizziness, nausea) occurred in 0 percent to 86 percent of patients. Paroxetine and venlafaxine had the highest incidence of this problem, and fluoxetine had the lowest incidence.

Pooled estimates from efficacy trials suggest that these differences do not lead to any statistically significant differences in overall discontinuation rates among SSRIs as a class and other second-generation antidepressants.

### Adverse Events and Discontinuation Rates: Detailed Analysis

Table 26 presents data on the design, interventions, results, and quality ratings of studies we included to examine issues relating to key adverse events and discontinuation. We focused on general tolerability and discontinuation (including nausea and vomiting and selected gastrointestinal problems), weight change, and discontinuation syndrome. We rated the strength of evidence on general adverse events as high or moderate (depending on the specific measure) and on discontinuation rates as high. Table 27 depicts, by specific drug, the mean incidence and 95 percent confidence interval for specific adverse events commonly reported in trials. Statistics are descriptive only. Comparisons across different drugs should be made with caution given differences in assessment and reporting of adverse events across trials.

Table 26 Studies assessing adverse events and discontinuation rates

Study | Design Interventions | N | Results | Quality Rating
General Tolerability and Discontinuation
Brambilla et al., 2005 ^163^ | Systematic review, | NR | No difference in discontinuation rates because of adverse events | Good
| Fluoxetine vs. SSRIs
Greist et al., 2004 ^164^ | Pooled analysis | 2,345 | No differences in nausea between duloxetine and paroxetine or duloxetine and fluoxetine | NA
| Duloxetine vs. paroxetine vs. fluoxetine
Haffmans et al., 1996 ^29^ | RCT | 217 | Significantly more diarrhea and nausea with fluvoxamine | Fair
| Fluvoxamine vs. paroxetine
Mackay et al., 1997, ^160^ 1999 ^161,^ ^165^ | Prescription event monitoring | > 60,000 | Venlafaxine had highest rate of nausea and vomiting; fluvoxamine had the most overall adverse events | NA
| Fluoxetine, fluvoxamine, nefazodone, paroxetine, venlafaxine
Meijer et al., 2002 ^162^ | Observational study | 1,251 | Significantly more diarrhea with sertraline | Fair
| Sertraline vs. SSRIs
Rapaport et al., 1996 ^33^ | RCT | 100 | Significantly more nausea with fluoxetine | Fair
| Fluoxetine vs. fluvoxamine
Changes in Weight
Benkert et al., 2000 ^72^ | RCT | 275 | Higher weight gain with mirtazapine | Fair
| Paroxetine vs. mirtazapine
Croft et al., 2002 ^166^ | RCT | 423 | Small weight loss with bupropion over 44 weeks | Fair
| Bupropion vs. placebo
Fava et al., 2000; ^48^ | RCT | 284 | Highest weight gain with paroxetine | Fair
Fava et al., 2002 ^41^ | Fluoxetine vs. paroxetine vs. sertraline
Goldstein et al.,1997 ^167^ | RCT | 671 | Higher weight loss with fluoxetine in older patients | Fair
| Fluoxetine vs. placebo
Guelfi et al., 2001 ^93^ | RCT | 157 | Higher weight increase with mirtazapine | Fair
| Venlafaxine vs. mirtazapine
Halikas et al., 1995 ^94^ | RCT | 150 | More weight gain with mirtazapine | Fair
| Trazodone vs. Mirtazapine
Harto et al., 1988 ^168^ | RCT | 35 | Higher weight loss with fluoxetine | Fair
| Fluoxetine vs. placebo
Hong et al., 2003 ^59^ | RCT | 133 | Higher weight gain with mirtazapine | Fair
| Fluoxetine vs. mirtazapine
Michelson et al., 1999 ^145^ | RCT | 395 | Fluoxetine and placebo showed a weight gain | Fair
Reimherr et al., 1998 ^122^ | Fluoxetine vs. placebo
Schatzberg et al., 2002 ^73^ | RCT | 255 | Higher weight gain with mirtazapine | Fair
| Paroxetine vs. mirtazapine
Versiani et al., 2005 ^60^ | RCT | 297 | Higher weight gain with mirtazapine | Fair
| Fluoxetine vs. mirtazapine
Wheatley et al., 1998 ^61^ | RCT | 133 | Significantly higher weight gain with mirtazapine | Fair
| Fluoxetine vs. mirtazapine
Discontinuation Syndrome
CSM Expert Working Group, 2004 ^169^ | Systematic review and meta-analysis | NR | No differences in risk among second-generation antidepressants | Good
| Second-generation antidepressants
Judge et al., 2002 ^170^ | Open-label trial Fluoxetine and paroxetine | 150 | Significantly fewer symptoms in the fluoxetine group than the paroxetine group | Fair
Perahia et al., 2005 ^171^ | Pooled analysis | 3,624 | Significantly higher rate of discontinuation syndrome with duloxetine than with placebo (44% vs. 23%) | Fair
| Duloxetine vs. placebo
Zajecka et al., 1998 ^172^ | RCT | 395 | Dizziness significantly less frequent in fluoxetine patients at 4 and 6 weeks | Fair
| Fluoxetine vs. placebo

NA, not applicable; NR, not reported; RCT, randomized controlled trial.

Table 27 Mean incidence of specific adverse events across comparative trials

Drug | Diarrhea | Dizziness | Headache | Insomnia | Nausea | Somnolence
Mean Percentage* (95% confidence interval)
Bupropion | 10.2% | 11.6% | 28.6% | 15.7% | 14.5% | 6.7%
| (3.1%–17.2%) | (2.2%–21.1%) | (23.2%–34.1%) | (10.9%–20.6%) | (8.9%–20%) | (0%–14.2%)
Citalopram | 7.5% | 9.1% | 14.3% | 6.9% | 14.3% | 12.6%
| (4%–11%) | (3.7%–14.4%) | (7.8%–20.7%) | (1.4%–12.5%) | (9.6%–19.1%) | (5.4%–19.9%)
Duloxetine | 16.1% | 41.5% | 15.8% | 16.6% | 42.6% | 36.8%
| (9.5%–22.8%) | (-8.1%–91%) | (3.9%–27.7%) | (14.1%–19.1%) | (7.2%–78%) | (8.4%–65.2%)
Escitalopram | 7.6% | 1.3% | 7.4% | 6.9% | 11.5% | 4.2%
| (0%–16%) | (0%–14.3%) | (3.3%–11.5%) | (1.3%–10.8%) | (7.2%–15.7%) | (0%–12.2%)
Fluoxetine | 10.4% | 7.6% | 21.3% | 13.8% | 18.4% | 7.8%
| (7.5%–13.3%) | (6.2%–9%) | (16.3%–26.3%) | (11.4%–16.2%) | (15.9%–20.9%) | (5.3%–10.3%)
Fluvoxamine | 19.2% | 18.3% | 20.1% | 24.2% | 26% | 8.8%
| (0%–53.5%) | (0%–62.4% | (3.3%–36.8%) | (0.3%–48%) | (14.4%–37.6%) | (0%–32.2%)
Mirtazapine | 3.7% | 8.4% | 12.1% | 8% | 6.3% | 18.7%
| (0%–8.1%) | (4.6%–12.1%) | (10%–14.3%) | (1.8%–14.3%) | (3.8%–8.7%) | (10.3%–27.1%)
Nefazadone | 12% | 21.3% | 32.4% | 13.3% | 21.6% | 25.3%
| (7.3%–16.8%) | (15.6%–27%) | (21.6%–43.2%) | (7%–19.5%) | (12.2%–30.9%) | (11.4%–39.1%)
Paroxetine | 15% | 0.8% | 3.2% | 12.7% | 21.4% | 18.2%
| (11.1%–18.9%) | (0%–2.9%) | (0%–8.1%) | (9.9%–15.4%) | (17.1%–25.7%) | (13.7%–22.7%)
Sertraline | 11.3% | 8.5% | 19.8% | 9.8% | 17.3% | 13.3%
| (7.6%–15%) | (5.9%–11.2%) | (14.9%–24.7%) | (6.1%–13.6%) | (13.7%–20.8%) | (9.8%–16.8%)
Trazodone | 4.3% | 24.1% | 22.1% | 4.8% | 14.4% | 42.4%
| (0%–13.8%) | (11.8%–36.5%) | (11.7%–32.5%) | (1.8%–7.8%) | (4.6%–24.1% | (19.5%–65.2%)
Venlafaxine | 6.4% | 14.3% | 19.3% | 17.8% | 29.3% | 14.5%
| (2.9%–10%) | (8.9%–19.7%) | (13.9%–24.7%) | (12.2%–23.2%) | (24.8%–33.8%) | (9.5%–19.4%)

* Weighted mean incidence calculated from RCTs. Method and extent of adverse event assessment varied among studies. Comparisons across drugs must be made cautiously.

General tolerability. Nausea, headache, diarrhea, fatigue, dizziness, sweating, tremor, dry mouth, and weight gain were commonly reported adverse events. In efficacy trials, on average, 61 percent of patients experienced at least one adverse event during the course of a given study.

Two large observational studies (three articles) examined the comparative rates of adverse events among SSRIs. ^160^ – ^162^ Overall, no substantial differences among examined drugs were apparent. However, not all currently approved SSRIs were investigated in these studies.

A British study pooled data from a cross-sectional study of a prescription-event monitoring study of general practitioners 6 months to 1 year after they had issued prescriptions. ^160,^ ^161^ Included drugs were fluoxetine, fluvoxamine, paroxetine, sertraline, venlafaxine, and nefazodone. The final cohort exceeded 10,000 patients for each drug. Demographics and indications were similar among study groups. Overall, the mean incidence per 1,000 patient-months for SSRIs was highest for fluvoxamine (fluvoxamine, 17.6; fluoxetine, 7.0; paroxetine, 7.6; sertraline, 6.2). Physicians, not patients, reported adverse events; the nonresponse rate was 40 percent. Therefore, measurement bias, selection bias, and potential confounding may compromise these results.

A Dutch prospective observational study followed 1,251 patients for up to 12 months to assess adverse events of sertraline (n = 659) and other SSRIs (fluoxetine, fluvoxamine, paroxetine). ^162^ No exclusion criteria were applied. Psychiatrists recorded adverse events at each patient visit; the investigators used the WHO adverse reaction terminology for outcome assessment. Significantly more sertraline patients than patients on other drugs had a diagnosis of depressive disorder at baseline (P < 0.001). Overall, 74.1 percent of patients reported at least one adverse event.

Nausea and vomiting. In efficacy trials, venlafaxine (an SNRI) had a consistently higher rate of nausea and vomiting than SSRIs. In six studies, the difference reached statistical significance. ^56,^ ^57,^ ^65,^ ^67,^ ^70,^ ^74^ The rate of patients reporting nausea or vomiting ranged from 6 percent to 48 percent.

These findings are consistent with a British prescription-event monitoring study described earlier. ^160,^ ^161^ Nausea and vomiting were the two most frequent clinical reasons for withdrawal in the first month of treatment for all drugs. Venlafaxine had the highest rate of nausea and vomiting per 1,000 patient-months.

Using data from efficacy trials, we compared the pooled relative risk of nausea and vomiting for venlafaxine with that for SSRIs as a class (Figure 14). The RR was 1.50 (95% CI, 1.21–1.84). The corresponding number needed to harm (NNH) was 9 (95% CI, 6–23).

Figure 14. Relative risk of nausea and vomiting of venlafaxine compared with SSRIs

A pooled analysis of published and unpublished trials of duloxetine did not find significant differences in nausea between duloxetine (40–120 mg/day) and paroxetine (20 mg/day) or between duloxetine (120 mg/day) and fluoxetine (20 mg/day). ^164^

Changes in weight. Consistently, studies comparing mirtazapine with other second-generation antidepressants reported higher weight gains for mirtazapine than for the comparator groups. ^59^ – ^61,^ ^72,^ ^73,^ ^93,^ ^94^ In two RCTs, these differences reached statistical significance. ^72,^ ^73^ Mean weight gains ranged from 0.8 kg to 3.0 kg after 6 to 8 weeks of treatment. Standard deviations of these changes, however, were large, suggesting that some patients had substantially higher weight increases.

Three placebo-controlled RCTs specifically assessed weight changes with fluoxetine treatment. ^122,^ ^145,^ ^167,^ ^168^ Findings were mixed. Two studies, one conducted in 671 patients older than 60 years, ^167^ recorded a statistically significant weight loss for fluoxetine compared with placebo. ^167,^ ^168^ The third study reported a weight gain. ^122,^ ^145^

A 32-week acute- and continuation-phase trial assessed differences in weight changes among patients treated with fluoxetine, paroxetine, and sertraline. ^41,^ ^48^ Paroxetine patients showed a significantly greater mean weight change (+3.6 percent) than those taking fluoxetine (-0.2 percent; P = 0.015) and sertraline (+1.0 percent; P < 0.001). With respect to weight gain of more than 7 percent, significantly more patients in the paroxetine group (25.5 percent) than in the fluoxetine group (6.8 percent; P = 0.016) and the sertraline group (4.2 percent; P = 0.003) had weight gains of this magnitude.

A double-blinded, placebo-controlled, 52-week acute- and continuation-phase trial assessed weight changes during bupropion treatment. ^166^ Patients receiving bupropion showed a modest but nevertheless significant decrease in body weight from baseline (-1.15 kg; P < 0.001). The magnitude of weight change was closely related to the patient's body mass index (BMI). Patients with a higher BMI experienced greater weight loss.

Gastrointestinal adverse events. Two RCTs were designed primarily to detect differences in harms between fluvoxamine and citalopram ^29^ and fluvoxamine and fluoxetine. ^33^ A Dutch multicenter trial assessed gastrointestinal side effects from citalopram (20–40 mg/day) and fluvoxamine (100–200 mg/day). ^29^ A total of 217 patients were enrolled for 6 weeks. Overall, 57 percent of patients reported adverse events. Significantly more patients in the fluvoxamine group than in the citalopram group had diarrhea (+13 percent; P = 0.026) or nausea (+16 percent; P = 0.017). However, the authors did not provide a baseline comparison of gastrointestinal illnesses between groups, so differences at baseline could bias results.

Another trial assessed differences in adverse events between fluvoxamine (100–150 mg/day) and fluoxetine (20–80 mg/day) in 100 patients over 7 weeks. ^33^ No significant difference could be detected, except that patients on fluoxetine suffered nausea significantly more often than those on fluvoxamine (42.5 percent vs. NR; P = 0.03).

In a Dutch prospective observational study (N = 1,251), diarrhea occurred more frequently in the sertraline group than in patients on fluoxetine, fluvoxamine, and paroxetine (P < 0.05). ^162^ This finding is consistent with results from head-to-head efficacy studies. In most studies, sertraline led to higher rates of diarrhea than did comparator drugs (bupropion, citalopram, fluoxetine, fluvoxamine, mirtazapine, nefazodone, paroxetine, and venlafaxine). ^30,^ ^42,^ ^44^ – ^46,^ ^51,^ ^53,^ ^76,^ ^77,^ ^90,^ ^92,^ ^108,^ ^110,^ ^111,^ ^150^ Incidence was 8 percent (95% CI, 3–11 percent) higher than with comparator drugs. The NNH is 13 (95% CI, 9–29). Whether this finding can be extrapolated to comparisons of sertraline with other second-generation antidepressants remains unclear.

Discontinuation syndrome. Withdrawal syndromes (e.g., headache, dizziness, lightheadedness, nausea, anxiety) commonly occur following the abrupt discontinuation of second-generation antidepressants. A good systematic review conducted by an Expert Working Group of the UK Committee on Safety in Medicines (CSM) assessed the frequency of discontinuation syndromes in second-generation antidepressants. ^169^ Based on observational studies, spontaneous reporting data, and clinical trials data, discontinuation syndromes occurred in 0 percent to 86 percent of patients. Because of study durations, dosages, and different assessment methods, incidence rates could not be compared directly. Nevertheless, discontinuation syndromes occurred most commonly with paroxetine and venlafaxine and least commonly with fluoxetine.

Three studies not included in the UK systematic review provide consistent results. ^170^ – ^172^ One head-to-head trial compared fluoxetine with paroxetine. ^170^ Treatment interruption led to significantly fewer symptoms in the fluoxetine group than the paroxetine group (P = 0.001) using the Discontinuation-Emergent Signs and Symptoms checklist (DESS). A placebo-controlled trial of fluoxetine did not find any differences in discontinuation syndromes between fluoxetine and placebo. ^172^ A pooled analysis of six trials investigated the effects of abrupt discontinuation of duloxetine and placebo. ^171^ Significantly more patients receiving duloxetine than receiving placebo reported discontinuation syndromes (44.3 percent vs. 22.9 percent; P < 0.05).

Discontinuation rates. In efficacy trials, discontinuation rates because of adverse events were not substantially different. Using data from efficacy studies, we conducted meta-analyses to assess differences in the overall loss to followup, discontinuation rates because of adverse events, and discontinuation rates because of lack of efficacy of SSRIs as a class compared with other second-generation antidepressants (bupropion, duloxetine, mirtazapine, nefazodone, trazodone, and venlafaxine) in adult patients with MDD.

Table 28 summarizes average discontinuation rates. Figures 15 through 17 depict relative risks of discontinuation rates comparing these agents with SSRIs as a class. Three sets of individual meta-analyses for overall discontinuation and for discontinuation from adverse events and lack of efficacy are presented in Appendix H. Available data for duloxetine and trazodone were insufficient to determine discontinuation rates that might be attributed to lack of efficacy.

Table 28 Average rates of overall discontinuation, discontinuation because of adverse events, and discontinuation because of lack of efficacy

| Overall Loss to Followup (%) | Discontinuation Because of Adverse Events (%) | Discontinuation Because of Lack of Efficacy (%)
SSRIs | 20.8 | 8.1 | 4.4
Bupropion | 14.1 | 6.7 | 3.1
Duloxetine | 17.2 | 5.5 | NR
Mirtazapine | 21.6 | 9.5 | 3.4
Nefazodone | 23.6 | 15.0 | 2.0
Trazodone | 20.7 | 7.0 | NR
Venlafaxine | 24.8 | 11.5 | 3.5

Figure 15. Relative risks of overall discontinuation

Figure 17. Relative risk of discontinuation because of lack of efficacy

Overall discontinuation rates did not differ significantly between SSRIs and bupropion, duloxetine, mirtazapine, nefazodone, trazodone, or venlafaxine (Figure 15). A published meta-analysis of 15 RCTs did not find any statistically significant differences in discontinuation rates because of adverse events between fluoxetine and other SSRIs as a class. ^163^ The only statistically significant difference in our pooled estimates of the relative risks of discontinuation because of adverse events was a higher rate for patients on venlafaxine than for patients on SSRIs (RR, 1.42; 95% CI, 1.12–1.82) (Figure 16). Overall, this finding was balanced by lower discontinuation rates because of lack of efficacy for venlafaxine (RR, 0.70; 95% CI, 0.49–1.01) (Figure 17).

Figure 16. Relative risk of discontinuation because of adverse events

Nefazodone and trazodone had rates of discontinuation because of adverse events similar to those of venlafaxine. However, differences with SSRIs did not reach statistical significance because of smaller sample sizes.

### Severe Adverse Events: Key Points

The evidence on the comparative risk of second-generation antidepressants on most severe adverse events is insufficient to draw firm conclusions. In general, trials and observational studies were too small and study durations too short to assess the comparative risk of rare but severe adverse events such as suicidality, seizures, cardiovascular adverse events, serotonin syndrome, hyponatremia, or hepatotoxicity. Long-term observational evidence is often lacking or prone to bias.

Based on five RCTs (N = 1,489), bupropion led to a significantly lower rate of sexual adverse events than fluoxetine and sertraline. ^79,^ ^80,^ ^88,^ ^89,^ ^102^ The NNT to experience one additional person with high overall satisfaction of sexual functioning is 6 (95% CI, 4–9).

Compared with other second-generation antidepressants (fluoxetine, fluvoxamine, nefazodone, and sertraline), paroxetine frequently led to higher rates of sexual dysfunction (16 percent vs. 6 percent). ^37,^ ^41,^ ^50,^ ^86^ Underreporting of absolute rates of sexual dysfunction, however, is likely in these studies. The NNH is 6 (95% CI, 4–9).

Table 29 summarizes studies included for the assessment of severe adverse events: suicidality, sexual dysfunction, cardiovascular events, seizures and other events. ^173^

Table 29 Studies assessing severe adverse events

Study | Design Interventions | N | Results | Quality Rating
Suicidality (Suicidal thoughts and behavior)
CSM Expert Working Group, 2004 ^169^ | Systematic review and meta-analysis | NR | No differences in risk among second-generation antidepressants | Good
| Second-generation antidepressants
Fergusson et al., 2005 ^174^ | Meta-analysis | 87,650 | Higher risk of suicide attempts for SSRI-treated patients | Good
| SSRIs vs. placebo
Khan et al., 2003 ^175^ | Retrospective cohort study | 48,277 | No difference in the rate of suicides | Fair
| Bupropion, citalopram, fluoxetine, mirtazapine, nefazodone, paroxetine, venlafaxine
Gunnell et al., 2005 ^176^ | Meta-analysis | 40,000 | Increased risk of nonfatal suicide attempts compared with placebo; no difference in risk among drugs | Good
| Citalopram, fluoxetine, fluvoxamine, paroxetine, sertraline, all vs. placebo
Martinez et al., 2005 ^177^ | Case-control study | 146,095 | No difference in risk of suicide or nonfatal suicide attempts between SSRIs and TCAs or among individual SSRIs | Good
| Citalopram, fluoxetine, fluvoxamine, paroxetine, sertraline, TCAs
Didham et al., 2005 ^178^ | Retrospective cohort study | 57,000 | Significant association between nonfatal suicide attempts and SSRIs; no difference in risk among drugs | Fair
| Citalopram, fluoxetine, paroxetine
Pedersen, 2005 ^173^ | Retrospective cohort study | 4,091 | Higher rate of nonfatal suicide attempts for escitalopram than for placebo | Fair
| Escitalopram vs. placebo
Jick et al., 1992 ^179^ | Database review | 8,730 | No difference in suicides between fluoxetine and first-generation antidepressants | NA
| Fluoxetine, first-generation antidepressants
Jick et al., 2004 ^180^ | Case-control study | 159,810 | No difference in risk among drugs | Fair
| Fluoxetine, paroxetine
Jick et al., 1995 ^181^ | Retrospective cohort study and nested case-control study | 172,598 | Significantly higher risk of suicide for fluoxetine and mianserin than for dothiepin | Fair
| Fluoxetine, trazodone, first-generation antidepressants
Aursnes et al., 2005 ^182^ | Meta-analysis of unpublished data | 1,466 | Higher rate of suicides for paroxetine than for placebo | Fair
| Paroxetine
Lopez-Ibor, 1993 ^183^ | Database review | 4,686 | No difference in suicidality | NA
| Paroxetine, first-generation antidepressants
Sexual Dysfunction
Clayton et al., 2002 ^184^ | Cross-sectional survey | 6,297 | Highest risk for paroxetine, lowest risk for bupropion | Fair
| Bupropion, citalopram, fluoxetine, fluvoxamine, mirtazapine, nefazodone, paroxetine, venlafaxine
Coleman et al., 2001 ^79^ | RCT | 456 | Significantly more sexual adverse events with fluoxetine | Fair
| Bupropion SR vs. fluoxetine
Feighner et al., 1991 ^80^ | RCT | 61 | Higher rate of sexual dysfunction for fluoxetine | Fair
| Bupropion vs. fluoxetine
Coleman et al., 1999 ^88^ | RCT | 364 | Significantly more sexual adverse events with sertraline | Fair
| Bupropion SR vs. sertraline
Croft et al., 1999 ^89^ | RCT | 360 | No differences | Fair
| Bupropion SR vs. sertraline
Segraves et al., 2000 ^102^ | RCT | 248 | Significantly more sexual adverse events with sertraline | Fair
| Bupropion vs. sertraline
Nieuwstraten and Dolovich, 2001 ^191^ | Meta-analysis | 1,332 | Significantly higher rate of sexual satisfaction in bupropion group | Good
| Bupropion vs. SSRIs
Montejo et al., 2001 ^190^ | Prospective cohort study | 1,022 | Highest incidence of sexual dysfunction for citalopram, paroxetine, and venlafaxine; lowest for mirtazapine and nefazodone | Fair
| Citalopram, fluoxetine, fluvoxamine, mirtazapine, nefazodone, paroxetine, venlafaxine
Landen et al., 2005 ^189^ | Cross-sectional study | 119 | No differences | Fair
| Citalopram vs. paroxetine
Ekselius et al., 2001 ^186^ | RCT | 308 | No differences | Fair
| Citalopram vs. sertraline
Delgado et al., 2005 ^185^ | Pooled analysis | 1,466 | Higher rate of sexual dysfunction for paroxetine | Fair
| Duloxetine vs. paroxetine vs. placebo
Philip et al., 2000 ^192^ | Prospective cohort study | 268 | No difference among SSRIs | Fair
| Fluoxetine, fluvoxamine, paroxetine, sertraline, moclobemide
Fava et al., 1998 ^37^ | Pooled Analysis | 128 | Significantly more sexual adverse events with paroxetine | Fair
| Fluoxetine vs. paroxetine
Kennedy et al., 2000 ^188^ | Prospective cohort study | 174 | No difference | Fair
| Paroxetine, sertraline, venlafaxine
Kavoussi et al., 1997 ^90,^ ^108^ | RCT | 248 | Higher rate of sexual adverse events with sertraline | Fair
| Sertraline vs. bupropion
Nemeroff et al., 1995 ^51^ | RCT | 95 | Higher rate of sexual adverse events with sertraline | Fair
| Sertraline vs. fluvoxamine
Behnke et al., 2003 ^76^ | RCT | 346 | Significantly more sexual adverse events with sertraline | Fair
| Sertraline vs. mirtazapine
Feiger et al., 1996 ^92^ | RCT | 160 | Sertraline had significant adverse effects on sexual function; nefazodone had none | Fair
| Sertralinenefazodone
Aberg-Wistedt et al., 2000 ^53^ | RCT | 353 | Significantly more libido decreases in patients taking sertraline | Fair
| Sertralineparoxetine
Ferguson et al., 2001 ^187^ | RCT | 150 | Higher reemergence rate of sexual dysfunction for sertraline | Fair
| Sertraline vs. trazodone
Seizures
Dunner et al., 1998 ^193^ | Uncontrolled, open-label trial | 3,100 | Rate of seizures for bupropion within reported range of other antidepressants | Fair
| Bupropion
Johnston et al., 1991 ^194^ | Uncontrolled, open-label trial | 3,341 | Rate of seizures for bupropion within range of other antidepressants | Fair
| Bupropion
Whyte et al., 2003 ^195^ | Prospective observational study | 538 | Seizures more common in venlafaxine overdose than in SSRI or TCA overdose | Good
| SSRIs, TCAs, venlafaxine
Cardiovascular Events
Thase et al., 1998 ^196^ | Pooled analysis | 3,744 | Increase in diastolic blood pressure for venlafaxine | Fair
| Venlafaxine
Thase et al., 2005 ^197^ | Post hoc data analysis | 1,873 | Greater change in heart rate for duloxetine than for fluoxetine and paroxetine | NA
| Fluoxetine, paroxetine, duloxetine
Other Adverse Events
Buckley et al., 2002 ^198^ | Database analysis | 47,329 | Highest rate of fatal toxicity for venlafaxine | NA
| Citalopram, fluoxetine, fluvoxamine, mirtazapine, nefazodone, paroxetine, sertraline, trazodone, venlafaxine
Coogan et al., 2005 ^199^ | Case-control | 4,996 | No association between breast cancer and SSRIs | Fair
| SSRIs
Kirby et al., 2002 ^200^ | Retrospective cohort study | 199 | Increased rate of hyponatremia in patients on SSRIs and venlafaxine | Fair
| SSRIs, venlafaxine
Thapa et al., 1998 ^201^ | Retrospective cohort study | 2,428 | No difference in the risk of falls | Fair
| Fluoxetine, paroxetine, sertraline, trazodone

CSM, Committee on Safety in Medicines; NA, not applicable; NR, not reported; RCT, randomized controlled trials; TCAs, tricyclic antidepressants.

### Severe Adverse Events: Detailed Analysis

Suicidality. Eleven studies (12 articles) assessed the risk of suicidality (suicidal thinking or behavior) in patients treated with second-generation antidepressants. ^169,^ ^174^ – ^183^ Data on the comparative risk of suicidality among second-generation antidepressants are sparse. Results from existing studies do not indicate that any particular drug of interest has an excess risk compared with that of other second-generation antidepressants. ^175^ – ^178,^ ^180^ However, these findings are based primarily on retrospective cohort studies, ^175,^ ^177,^ ^178,^ ^180^ and confounding by indication (i.e., patients who are at higher risk for suicide may be prescribed some medications rather than others) may lead to erroneous conclusions.

The largest attempt to determine whether second-generation antidepressants increase the risk of suicidality was conducted in 2004 by the CSM working group. ^169^ The CSM experts investigated ongoing safety concerns about suicidal behavior with some second-generation antidepressants (citalopram, escitalopram, fluoxetine, fluvoxamine, mirtazapine, paroxetine, sertraline, venlafaxine) in patients with MDD. They used data from 477 published and unpublished RCTs on more than 40,000 individuals as well as spontaneous reporting data. However, these data were limited to studies funded by the pharmaceutical industry.

A meta-analysis limited the CSM data to placebo-controlled trials of SSRIs in ~40,000 adults. Results did not yield any evidence that SSRIs either increase or protect against the risk of suicide (OR, 0.85; 95% CI, 0.20–3.40). ^176^ The risk of suicide-related events was similar between second-generation antidepressants and active comparators, although some evidence of an increased risk of nonfatal suicide attempts was detected (OR, 1.57; 95% CI, 0.99–2.55).

Another meta-analysis of published data on more than 87,000 patients in SSRI trials for various conditions reported a significantly higher risk of suicide attempts for SSRI patients than for placebo-treated patients (OR, 2.25; 95% CI, 1.14–4.55). ^174^ Furthermore, an increase in the odds ratio of suicide attempts was observed for SSRIs compared with interventions other than tricyclic antidepressants (TCAs) (OR, 1.94; 95% CI, 1.06–3.57). No significant difference existed in the pooled analysis of SSRIs compared with TCAs (OR, 0.88; 95% CI, 0.54–1.42). The overall rate of suicide attempts was 3.9 (95% CI, 3.3–4.6) per 1,000 patients treated with SSRIs, for an incidence of 18.2 suicide attempts per 1,000 patient years.

In addition, the CSM group commissioned an observational study (i.e., a nested case-control study) using the General Practice Research Database (GPRD) to investigate the association between antidepressants and suicide attempts. This study used data on more than 146,000 patients with a first prescription of an antidepressant for depression. ^177^ It did not find any evidence that the risk of either suicide (OR, 0.57; 95% CI, 0.26–1.25) or nonfatal suicide attempts (OR, 0.99; 95% CI, 0.86–1.14) was greater in patients on second-generation antidepressants than in patients on TCAs.

Findings of other large observational studies and meta-analyses are similar. ^173,^ ^175,^ ^178^ – ^183^ Most detected an increase in nonfatal suicide attempts but no significant difference in suicides. In general, no significant differences in risks regarding suicidality could be detected between second-generation antidepressants and TCAs.

An internal report of all published and unpublished studies on paroxetine conducted by GlaxoSmithKline is consistent with findings from studies described above. ^202^

Sexual dysfunction. Multiple studies assessed the comparative risk of sexual dysfunction among second-generation antidepressants. ^79,^ ^88,^ ^89,^ ^102,^ ^190^ The largest study was a Spanish open-label, prospective observational study using the Psychotropic-Related Sexual Dysfunction Questionnaire (PRSexDQ) in 1,022 outpatients treated with various antidepressants. ^190^ All patients had normal sexual functioning at study onset. Overall, 59 percent of patients experienced some type of sexual dysfunction. Among second-generation antidepressants, citalopram, paroxetine, and venlafaxine had the highest incidence of sexual dysfunction (73 percent, 71 percent, and 67 percent, respectively); mirtazapine and nefazodone had the lowest (24 percent and 8 percent, respectively). This study did not include data on bupropion, escitalopram, and trazodone.

A cross-sectional survey of patients on second-generation antidepressants presented similar results. ^184^ Paroxetine had the highest rate of sexual dysfunction; nefazodone and bupropion had the lowest.

Sexual dysfunction was also a commonly reported adverse event for SSRIs and SNRIs in efficacy trials. Most of these studies did not report the use of targeted questions for sexual dysfunction. Therefore, patient-reported numbers might not reflect the true incidence. Patients receiving paroxetine and sertraline frequently reported significantly higher rates of sexual dysfunction ^37,^ ^51,^ ^53,^ ^76,^ ^90,^ ^92^ than did patients in the active control groups. In one trial, significantly more patients on sertraline than on bupropion SR withdrew because of sexual dysfunction (13.5 percent vs. 3.3 percent; P = 0.004). ^90^ A pooled analysis of four efficacy trials comparing paroxetine and duloxetine reported significantly higher rates of sexual dysfunction for patients on paroxetine. ^185^

Six RCTs assessed the comparative risk of sexual dysfunction between two or more second-generation antidepressants as primary outcome measures. ^79,^ ^88,^ ^89,^ ^102,^ ^186,^ ^187^

Citalopram vs. sertraline. A subgroup analysis of a Swedish RCT examined the incidence of sexual dysfunction from citalopram (20–60 mg/day) and from sertraline (50–150 mg/day) in 308 study completers with MDD. ^186^ Outcome assessment was conducted at baseline and at week 24. Citalopram and sertraline did not differ significantly in the magnitude and frequency of sexual dysfunction. Only one patient was lost to followup attributable to sexual dysfunction in this study.

Bupropion vs. SSRIs. A good meta-analysis including data on 1,332 patients with MDD compared sexual adverse events of bupropion and three SSRIs (fluoxetine, paroxetine, sertraline) as a class. ^191^ We do not describe studies included in this meta-analysis individually. ^80,^ ^88,^ ^89,^ ^102^ The rate of sexual satisfaction was significantly higher in patients receiving bupropion than in those receiving SSRIs (RR, 1.28; 95% CI, 1.16–1.41).

An 8-week RCT (not in the meta-analysis cited above) compared efficacy and sexual dysfunction of bupropion SR (150–400 mg/day), fluoxetine (20–60 mg/day), and placebo in 456 outpatients with MDD. ^79^ Findings are consistent with those from the meta-analysis. Throughout the study, patients on bupropion SR experienced significantly less sexual dysfunction than those on fluoxetine. Moreover, beginning at week 1 until endpoint, significantly fewer patients on bupropion than on fluoxetine were dissatisfied with their overall sexual function (P < 0.05). The NNT to gain one more patient with high satisfaction with sexual functioning is 6 (95% CI, 4–9).

Sertraline vs. trazodone. In one RCT, the emergence of sexual adverse events in patients who experienced sexual dysfunction with sertraline treatment was significantly greater for those receiving sertraline than for those receiving trazodone. ^187^

Seizures. Evidence from controlled trials and observational studies is insufficient to conclude for or against an increased risk of seizures in patients taking any of the reviewed drugs, including bupropion. Two open-label trials ^193,^ ^194^ examined the rate of seizures during bupropion treatment. Both trials reported that the rate of seizures was within the range of other marketed antidepressants, but we rate the strength of this uncontrolled, open-label evidence as low. A recent review of medical charts on 538 patients with deliberate self-poisoning with antidepressants reported that seizures were more common in patients with venlafaxine overdose than in patients with TCA or SSRI overdose. ^195^

Cardiovascular adverse events. A post hoc analysis examined pooled data from 3,744 patients participating in venlafaxine trials. ^196^ At 6 weeks, 11.5 percent of venlafaxine patients had a supine diastolic blood pressure (DBP) greater than 90 mm Hg (placebo, 5.7 percent; P < 0.001). During continuation-phase treatment (up to 12 months), significantly more venlafaxine subjects than placebo subjects with normal supine DBPs developed elevated readings (P = 0.05).

A post hoc analysis of six RCTs (published and unpublished) comparing duloxetine with fluoxetine and paroxetine did not find any statistically significant differences in supine systolic or diastolic blood pressure. ^197^ Patients receiving duloxetine had a greater mean change in heart rate than those on either fluoxetine (+2.8 beats/min vs. -1.0 beat/min) or paroxetine (+1.0 beats/min vs. -1.4 beats/min).

Efficacy trials infrequently assessed cardiovascular outcomes. Two RCTs, one comparing venlafaxine XR with sertraline ^78^ and one comparing venlafaxine with fluoxetine, ^66^ detected statistically significant increases in supine DBP ^78^ and supine pulse rate ^66^ for venlafaxine relative to fluoxetine.

Other adverse events. A database analysis in the United Kingdom on fatal toxicity of second-generation antidepressants found venlafaxine to have the highest fatal toxicity rate (13.2 per 1,000,000 prescriptions) among second-generation antidepressants. ^198^ A case-control study did not find an association between SSRIs and breast cancer. ^199^ A retrospective review of the charts of 2,428 nursing home residents did not detect differences in the risk of falls among fluoxetine, paroxetine, and sertraline. ^201^

Hyponatremia. A retrospective cohort study reported that hyponatremia in elderly inpatients (mean age 74 years) was significantly more common in patients treated with SSRIs or venlafaxine than in controls not on these drugs (OR, 3.5; 95% CI, 1.4–8.9). ^200^ Otherwise, evidence from controlled trials and observational studies is insufficient to conclude for or against an increased risk of hyponatremia in patients treated with SSRIs.

Our methods for this comparative effectiveness review did not permit inclusion of case reports and case series. The published literature includes numerous case reports of hyponatremia and inappropriate secretion of an antidiuretic hormone as rare side effects. ^203^ Even if this evidence is considered weak, such findings might be important in the absence of studies with the methodological strength to account for rare adverse events.

Hepatotoxicity. Evidence from controlled trials and observational studies is insufficient to conclude for or against an increased risk of liver toxicity during nefazodone treatment. Nevertheless, numerous case reports not included in this report contain low quality but potentially important evidence citing an increased risk of liver toxicity during nefazodone treatment. ^204^

Serotonin syndrome. Serotonin hyperstimulation syndrome is characterized by symptoms that include mental status changes, agitation, myoclonus, hyperreflexia, sweating, shivering, tremor, diarrhea, lack of coordination, and fever; it can lead to death. ^165^ Evidence from controlled trials and observational studies is insufficient to draw conclusions about differences in risk among second-generation antidepressants. The published literature has numerous case reports of serotonin syndrome. ^205^

A postmarketing survey identified cases of the serotonin syndrome in British general practice among patients who received nefazadone. ^165^ In a cohort of 11,834 patients, 19 cases met criteria for the syndrome (incidence = 0.4 cases per 1,000 patient-months of treatment with nefazodone). Similar rates of the syndrome were reported for fluoxetine, sertraline, paroxetine, and venlafaxine.

### Adherence: Key Points

Few efficacy studies reported rates of adherence. Lack of adherence, however, was often used as a reason to exclude patients from the study. Efficacy trials do not indicate any differences in adherence among second-generation antidepressants. However, the quality of reporting and assessment of adherence was limited. Findings from highly controlled efficacy studies may have limited generalizability to “real-world” practice especially because of the overall short duration of these trials. The evidence is insufficient to conclude on adherence in effectiveness studies. A review of a large, managed care database suggested that extended-release formulations might have greater adherence than immediate-release medications. ^206^ Strength of evidence is moderate for efficacy studies and low for effectiveness studies.

### Adherence: Detailed Analysis

The published literature in this area frequently uses the terms “compliance” and “adherence” interchangeably. Compliance has traditionally been used to describe a patient's ability to take medications as prescribed. Some authors argue, however, that adherence better represents the more complex relationship among patients, providers, and medications; it is meant to reflect the fact that following a medication regimen is not necessarily a simple choice. ^207^ Given the lack of a clear definition, we use the term adherence. Table 30 summarizes included studies on adherence.

Table 30 Head-to-head trials reporting adherence to second-generation antidepressants

Study | N | Rate of Adherence | Quality Rating
| Drugs and Dose
| Duration
Coleman et al., 1999 ^88^ | 364 | Tablet: | Fair
| Bupropion SR 150–400 mg/d | Bupropion SR 96%
| Sertraline 50–200 mg/d | Sertraline 97%
| Placebo | Placebo 96%
| 8 weeks | Capsule:
| | Bupropion SR 98%
| | Sertraline 98%
| | Placebo 98%
Coleman et al., 2001 ^79^ | 456 | 97% to 99% in all groups | Fair
| Bupropion SR 150–400 mg/d
| Fluoxetine 20–60 mg/d
| Placebo
| 8 weeks
Croft et al., 1999 ^89^ | 360 | Bupropion SR 98% | Fair
| Bupropion SR 150–400 mg/d | Sertraline 97%
| Sertraline 50–200 mg/d | Placebo 98%
| Placebo
| 8 weeks
Ekselius et al., 1997 ^30^ | 400 | Citalopram 95% | Good
| Citalopram 20–60 mg/d | Sertraline 90%
| Sertraline 50–100 mg/d
| 24 weeks
Kavoussi et al., 1997 ^90^ | 248 | Bupropion SR 98% | Fair
| Bupropion SR 100–300 mg/d | Sertraline 99%
| Sertraline 50–200 mg/d
| 16 weeks
Segraves et al., 2000 ^102^ | 248 | Bupropion 98% | Fair
| Bupropion SR 100–300 mg/day | Sertraline 99%
| Sertraline 50–200 mg/day
| 16 weeks
Weihs et al., 2000 ^84^ | 100 | Bupropion SR 95% | Good
| Bupropion SR 100–300 mg/d | Paroxetine 98%
| Paroxetine 10–40 mg/d
| 6 weeks
Weisler et al., 1994 ^97^ | 124 | Bupropion 95% | Fair
| Bupropion 225–450 mg/day | Trazodone 90%
| Trazodone 150–400 mg/day
| 6 weeks

CR, controlled release; IR, immediate release; SR, sustained release.

The majority of RCTs that reported adherence stated a rate between 90 percent and 100 percent. Nineteen published studies, examining 18 RCTs, reported levels of adherence. ^25,^ ^30,^ ^35,^ ^59,^ ^79,^ ^85,^ ^88^ – ^90,^ ^128,^ ^136,^ ^193,^ ^194,^ ^208^ – ^213^ Most, however, contained only minimal information, and many did not stratify by treatment. Furthermore, they provided little or no information on the methods of assessment. For example, one fair study reported that both treatment arms exhibited 100 percent adherence, but the investigators did not describe their method of determining adherence. ^60^ Only 10 of 18 RCTs reported adherence rates for different treatment arms; ^30,^ ^36,^ ^79,^ ^81,^ ^82,^ ^87,^ ^88,^ ^100,^ ^117,^ ^212^ of these, 8 were head-to-head comparisons (Table 30). ^30,^ ^79,^ ^84,^ ^88^ – ^90,^ ^97,^ ^102^ None of these studies noted a significant difference in adherence.

None of the three effectiveness studies reported on adherence. To what extent results from highly controlled efficacy trials can be extrapolated to effectiveness settings remains unclear.

A retrospective database analysis used the Integrated Healthcare Information Services National Managed Care Benchmark Database to examine adherence levels in 116,090 patients being treated with SSRIs (immediate-release citalopram, escitalopram, fluoxetine, or sertraline) compared with controlled-release paroxetine. ^206^ Their primary finding was that patients on a controlled-release formula were significantly more compliant than patients on immediate-release formulations. After controlling for baseline covariates (age, sex, insurance type, titration rates, mental health specialty care, diagnoses, and comorbidity), patients initiating an immediate-release SSRI were 13.6 percent less likely to be adherent than patients on controlled-release paroxetine (P < 0.0001).

## Key Question 5: Efficacy, effectiveness, and harms for selected populations

KQ 5. How do the efficacy, effectiveness, or harms of treatment with antidepressants for a depressive syndrome differ for the following subpopulations:

- elderly or very elderly patients;
- other demographic groups (defined by age, ethnic or racial groups, and sex);
- patients with medical comorbidities (e.g., ischemic heart disease, cancer);
- patients with psychiatric and behavioral comorbidities (e.g., substance abuse disorders); and
- patients taking other medications.

### Overview

We did not find any studies directly comparing efficacy, effectiveness, and harms of second-generation antidepressants between subgroups and the general population for the treatment of depression syndromes (depressive disorders), which include MDD, dysthymia, and subsyndromal depression including minor depression. Numerous studies, however, conducted subgroup analyses or used subgroups as the study population.

Overall, we included 44 studies in addressing this key question: 36 RCTs, 3 pooled analyses, 2 open-label medication trials (1 randomized), 2 observational studies, and 1 systematic review. We focused on groups defined by age, sex, race or ethnicity, and comorbidities (which included HIV/AIDS, alcohol and substance abuse, Alzheimer's disease or dementia, cardiovascular disease, dialysis, and stroke). These results provide indirect evidence for KQ 5. All studies were rated as fair quality unless otherwise noted.

We present key points and detailed analyses below for the population groups noted above. Details about included studies are presented in Table 31 (listed alphabetically by author within each subgroup). Strength of evidence is moderate for comparative efficacy and effectiveness for age and low for sex, race or ethnicity, and comorbidities; it is low for harms for age.

Table 31 Studies of efficacy, effectiveness, and harms for patient subgroups

Study | Interventions | N | Results | Quality Rating
Age
Roose et al., 2004 ^219^ | Citalopram vs. placebo | 174 | No significant difference in response/remission except in high severity group | Fair
Rocca et al., 2005 ^114^ | Citalopram vs. sertraline | 138 | No significant difference | NA
Allard et al., 2004 ^55^ | Citalopram vs. venlafaxine XR | 151 | No significant difference | Fair
Burt et al., 2005 ^218^ | Duloxetine vs. placebo | 114 | Duloxetine was more efficacious (response/remission); no difference in effect in women 40–55 vs. older or younger women | Fair
Kasper et al., 2005 ^31^ | Escitalopram vs. fluoxetine vs. placebo | 517 | No significant difference in response rates; remission rates lower for fluoxetine than escitalopram | Fair
Cassano et al., 2002 ^34^ | Fluoxetine vs. paroxetine | 242 | No significant difference | Fair
Schone and Ludwig, 1993 ^39^ | Fluoxetine vs. paroxetine | 106 | Greater response rate for paroxetine | Fair
Geretsegger et al., 1994 ^214^
Kroenke et al., 2001 ^49^ | Fluoxetine vs. paroxetine vs. sertraline | 573 | No significant difference | Fair
Devanand et al., 2005 ^100^ | Fluoxetine vs. placebo | 90 | No difference in response rates and quality of life | Good
Goldstein et al., 1997 ^167^ | Fluoxetine vs. placebo | 671 | Higher weight loss with fluoxetine in older patients | Fair
Tollefson et al., 1993 ^222^ | Fluoxetine vs. placebo | 671 | Significantly greater response with fluoxetine; current physical illness not associated with response | Fair
Tollefson, et al., 1995 ^223^
Small et al., 1996 ^224^
Newhouse et al., 2000 ^44^ | Fluoxetine vs. sertraline | 236 | Overall similar efficacy, although sertraline patients experienced greater cognitive improvement and greater response among people over 70 years of age | Fair
Finkel et al., 1999 ^45^
Rossini et al., 2005 ^52^ | Fluvoxamine vs. sertraline | 93 | No significant difference in response rates | Fair
Halikas et al., 1995 ^94^ | Mirtazapine vs. trazodone vs. placebo | 150 | No significant difference | Fair
Weihs et al., 2000 ^84^ | Paroxetine vs. bupropion SR | 100 | No differences | Good
Schatzberg et al., 2002 ^73^ | Paroxetine vs. mirtazapine | 255 | Greater early efficacy for mirtazapine; similar number of CGI responders at end of continuation phase | Fair
Rapaport et al., 2003 ^213^ | Paroxetine (CR and IR) vs. placebo | 319 | Significantly more responders and remitters for paroxetine (CR and IR formulations) than for placebo | Fair
Barrett et al., 2001 ^113^ | Paroxetine vs. placebo vs. behavioral therapy | 656 | In patients older than 60 years, significantly greater improvement in symptom scores for paroxetine than for placebo; in patients younger than 60 years, no difference | Fair
Williams et al., 2000 ^112^
Schneider et al., 2003 ^220^ | Sertraline vs. placebo | 752 | Significantly more responders in sertraline group both with and without comorbid medical illness | Fair
Sheikh et al., 2004 ^221^
Wilson et al., 2003 ^137^ | Sertraline vs. placebo | 113 | No difference in prevention of depression; sertraline associated with longer time to recurrence | Fair
Oslin et al., 2003 ^215^ | Sertraline vs. venlafaxine | 52 | No significant difference in efficacy; tolerability was lower for venlafaxine | Poor
Kirby et al., 2002 ^200^ | SSRIs use vs. venlafaxine | 199 | Higher rate of hyponatremia in patients on SSRIs and venlafaxine | Fair
Entsuah et al., 2001 ^217^ | Venlafaxine (IR and XR) vs. SSRIs vs. placebo | 2,045 | Venlafaxine response not affected by age or sex; SSRI response poorer in older women; similar efficacy of venlafaxine and SSRIs except in older women, but HRT appears to eliminate the difference | Fair
Thase et al., 2005 ^216^
Sex
Kennedy et al., 2000 ^188^ | Paroxetine vs. sertraline vs. venlafaxine vs. moclobemide | 107 | Sex difference in impairment in drive/desire; rates of dysfunction in men similar in all treatments; in women, greater levels of dysfunction with sertraline and paroxetine; favorable drug response associated with less dysfunction | Fair
Thase et al., 2005 ^216^ and Enstuah et al., 2001 ^217^ | SSRIs vs. venlafaxine XR vs. placebo | 2,045 | Venlafaxine response not affected by age or sex; SSRI response poorer in older women; similar efficacy of venlafaxine and SSRIs, except in older women, but HRT appears to eliminate the difference | Fair
Ethnicity
Wagner et al., 1998 ^225^ | Fluoxetine vs. placebo | 118 | Ethnicity not associated with side effects; whites had a higher response rate, Latinos a higher drop-out rate | Poor
Comorbidities
HIV/AIDS
Rabkin et al., 1999 ^228^ | Fluoxetine vs. placebo | 120 | No difference in depressed HIV/AIDS patients | Fair
Wagner et al., 1998 ^225^ | Fluoxetine vs. placebo | 118 | Ethnicity not associated with side effects; whites had a higher response rate, Latinos a higher drop-out rate | Poor
Rabkin et al., 2004 ^227^ | Fluoxetine vs. testosterone vs. placebo | 123 | No difference in depressed HIV/AIDS patients | Fair
Ferrando et al., 1997 ^226^ | Sertraline vs. paroxetine vs. fluoxetine | 33 | Completers (all treatment groups) experienced improvements in affective and somatic symptoms (many of which were attributed to HIV rather than depression) | Poor
Alcohol
Hernandez-Avila et al., 2004 ^208^ | Nefazadone vs. placebo | 41 | No significant differences | Fair
Gual et al., 2003 ^229^ | Sertraline vs. placebo | 83 | No significant differences | Fair
Moak et al., 2003 ^210^ | Sertraline vs. placebo | 82 | Greater depression improvement in females treated with sertraline; less drinking associated with greater depression improvement | Fair
Alzheimer's disease/dementia
Nyth et al., 1992 ^211^ | Citalopram vs. placebo | 149 | Significantly greater improvement with citalopram | Poor
Lyketsos et al., 2003 ^230^ | Sertraline vs. placebo | 44 | Sertraline associated with greater response | Fair
Magai et al., 2000 ^231^ | Sertraline vs. placebo | 31 | No significant difference | Fair
Breast cancer
Roscoe et al., 2005 ^232^ | Paroxetine vs. placebo | 94 | Paroxetine associated with greater depression response | Poor
Cardiovascular disease
Strik et al., 2000 ^235^ | Fluoxetine vs. placebo | 54 | Significantly greater response with fluoxetine | Good
Krishnan et al., 2001 ^209^ | Sertraline | 220 | Vascular comorbidity not associated with more adverse events or premature discontinuation | Fair
Glassman et al., 2002 ^234^ | Sertraline vs. placebo | 369 | Significantly greater response with sertraline | Fair
Bush et al., 2005 ^233^ | SSRIs | NR | SSRIs improve depression in post-MI patients | Fair
Dialysis
Blumenfield et al., 1997 ^236^ | Fluoxetine vs. placebo | 14 | No significant difference | Fair
Stroke
Andersen et al., 1994 ^237^ | Citalopram vs. placebo | 285 | Significantly more improvement with citalopram | Fair
Murray et al., 2005 ^238^ | Sertraline vs. placebo | 123 | No difference in response; greater improvements in quality of life with sertraline | Fair
Substance abuse
Petrakis et al., 1998 ^212^ | Fluoxetine vs. placebo | 44 | No difference in depressed opioid addicts | Fair
Schmitz et al., 2001 ^239^ | Fluoxetine vs. placebo | 68 | No difference in depressed cocaine abusers | Poor

CGI, Clinical Global Impressions; CR, controlled release; HRT, hormone replacement therapy; IR, immediate release; MI, myocardial infarction; NA, not applicable; SR, slow release; XR, extended release.

### Age: Key Points

No studies directly compared the efficacy of second-generation antidepressants between either the elderly (60 to 79 years of age) or the very elderly (80 years of age or older) and the general population. Twelve head-to-head efficacy trials ^31,^ ^34,^ ^39,^ ^44,^ ^45,^ ^49,^ ^52,^ ^55,^ ^73,^ ^84,^ ^94,^ ^114,^ ^214,^ ^215^ and two meta-analyses (pooled analyses of original data) ^216,^ ^217^ provide mixed evidence on differences in efficacy in the elderly or very elderly treated with second-generation antidepressants. Comparisons were available for less than one-fourth of the potential comparisons between the 12 second-generation antidepressants addressed in this report. Only seven head-to-head trials or meta-analyses compared the efficacy of any non-SSRI second-generation antidepressant with any other second-generation antidepressant. ^55,^ ^73,^ ^84,^ ^94,^ ^215^ – ^217^

Subgroup analyses of two effectiveness studies provide mixed evidence on differences in effectiveness of second-generation antidepressants between either the elderly or very elderly and the general population for the treatment of MDD, ^49^ dysthymia, and minor depression. ^112,^ ^113^ We did not find any studies directly comparing the harms of second-generation antidepressants between either the elderly or very elderly and the general population. Some findings from randomized controlled trials and observational evidence indicate that very elderly patients might have an increased risk for some rare but potentially serious adverse events such as hyponatremia and weight loss. ^167,^ ^200^

### Age: Detailed Analysis

Head-to-head evidence. We identified 12 head-to-head RCTs (14 articles) in elderly or very elderly patients. ^31,^ ^34,^ ^39,^ ^44,^ ^45,^ ^49,^ ^52,^ ^55,^ ^73,^ ^84,^ ^94,^ ^114,^ ^214,^ ^215^ We also identified one set of meta-analyses of original data from eight RCTs. ^216,^ ^217^ These trials evaluated numerous treatment comparisons: first, intra-SSRI comparisons (citalopram vs. sertraline, escitalopram vs. fluoxetine vs. placebo, fluoxetine vs. paroxetine, fluoxetine vs. sertraline, fluvoxamine vs. sertraline, and paroxetine vs. sertraline); second, SSRI vs. SNRI comparisons (citalopram vs. venlafaxine XR, paroxetine vs. mirtazapine, sertraline vs. venlafaxine IR, SSRIs vs. venlafaxine IR or XR vs. placebo); third, SSRIs vs. other second-generation antidepressants (paroxetine vs. bupropion SR); and fourth, SNRIs vs. other second-generation antidepressants (mirtazapine vs. trazodone vs. placebo).

SSRIs vs. SSRIs. Citalopram vs. sertraline. One randomized trial evaluated citalopram and sertraline in the treatment of 138 nondemented elderly patients with minor depressive disorder and subsyndromal depressive symptomatology. ^114^ Although this trial does not meet eligibility criteria because of the study design (because of flawed randomization, it is essentially a nonrandomized trial) and therefore is not assigned a quality rating, we included it here because it is the only evidence pertaining to a comparison of these two SSRIs; the trial also had high loss to followup (27.5 percent). Both treatments improved depressive symptoms (as measured by the HAM-D); HAM-D remission rates were similar for citalopram and sertraline at the end of the study (53 percent and 42 percent, P = 0.25). Similar improvements were seen in Global Assessment of Function (GAF) and cognitive scores.

Escitalopram vs. fluoxetine vs. placebo. One 8-week study compared escitalopram, fluoxetine, and placebo in 517 participants older than 65 years of age (mean age in each treatment group, 75 years). ^31^ Outcome measures included the MADRS and the CGI-S. Patients on escitalopram experienced greater improvement than those on fluoxetine in MADRS score at week 8 (using an LOCF analysis) (P < 0.01); however, the patients treated with escitalopram and with placebo did not differ significantly. Escitalopram, placebo, and fluoxetine MADRS response rates were similar (46 percent, 47 percent, 37 percent, respectively, P = not significant).

In addition, MADRS remission rates were similar for escitalopram and placebo (40 percent and 42 percent), but for fluoxetine vs. placebo the difference was significant (30 percent vs. 42 percent, P = 0.05). Escitalopram- and fluoxetine-treated patients experienced significantly more nausea than placebo-treated patients (P < 0.01).

Fluoxetine vs. paroxetine. We identified three randomized trials (four articles) in populations older then 60 years of age. ^34,^ ^39,^ ^49,^ ^214^ One 6-week trial (two publications) compared fluoxetine (20–60 mg/day) and paroxetine (20–40 mg/day) in 106 depressed patients ages 61 to 85 years (mean age 74 years). ^39,^ ^214^ In this trial, patients treated with paroxetine achieved statistically significantly higher HAM-D response rates than patients in the fluoxetine group (P = 0.03). ^39,^ ^214^ No significant differences were seen in overall adverse events.

By contrast, an effectiveness trial conducted in patients older than 18 years of age with major depression, dysthymia, or minor depression did not detect any differences in the effectiveness of fluoxetine and paroxetine. ^49^ Both treatment groups showed significant improvements in depression and other health-related quality of life domains (social function, work function, physical function) with no significant differences between study groups. It also produced no interactions between treatment groups and age (≥ 60 years of age vs. younger).

An Italian study lasting 1 year enrolled 242 patients to compare the effects of fluoxetine (20–60 mg/day) and paroxetine (20–40 mg/day) on depressive symptoms, mood, and cognitive function in nondemented persons 65 years or older. ^34^ Treatment groups did not differ significantly at study endpoint in CGI scores. Although there are no statistically significant differences in outcome measures, this finding does not conclusively demonstrate noninferiority. ^109^ Severe adverse events were significantly more common in the fluoxetine group than the paroxetine group (22 vs. 9 events; P < 0.002).

Fluoxetine vs. sertraline. One 12-week study (two articles) comparing sertraline (50–100 mg/day) and fluoxetine (20–40 mg/day) in 236 participants ages 60 years and older provides evidence of the comparable efficacy of these drugs. ^44,^ ^45^ Outcome measures included MADRS, HAM-D, quality of life (Quality of Life Enjoyment and Satisfaction Questionnaire), and cognitive assessments (Shopping List Task [SLT], MMSE, and Digital Symbol Substitution Test [DSST]). Patients treated with these drugs did not differ significantly on primary outcome measures (MADRS, HAM-D). HAM-D response rates (sertraline, 73 percent; fluoxetine, 71 percent) and HAM-D remission rates (sertraline, 45 percent; fluoxetine, 46 percent) were similar. Adverse event rates were similar in the two treatment groups. Quality of life and other patient-rated measures were also similar for both treatment groups at endpoint. Sertraline-treated patients showed greater cognitive improvement than patients on fluoxetine on the DSST at endpoint (P = 0.037). A subgroup analysis of 75 patients 70 years of age or older demonstrated a greater response rate for sertraline than for fluoxetine (58.5 percent vs. 42.4 percent, respectively, P = 0.027). ^45^

A 9-month effectiveness study yielded similar results. ^49^ The investigators found no differences in effectiveness between fluoxetine and sertraline in patients older than 18 years of age with major depression, dysthymia, or minor depression. Both treatment groups showed significant improvements in depression and other health-related quality of life domains (social function, work function, physical function) with no significant differences between study groups. No interactions between treatment groups and age (≥ 60 years of age vs. younger) were seen.

Fluvoxamine vs. sertraline. A 7-week trial compared fluvoxamine and sertraline for the treatment of major depression in 93 patients 59 years of age and older (mean age for both treatment groups, 68 years). ^52^ HAM-D response rates favored fluvoxamine over sertraline but did not reach statistical significance (71.8 percent vs. 55.6 percent, P = 0.12). Although the difference was not statistically significant, this finding does not conclusively demonstrate noninferiority. ^109^ A two-way repeated measures analysis of variance revealed a significant time-by-group interaction in HAM-D scores favoring fluvoxamine (P = 0.007).

Paroxetine vs. sertraline. A fair effectiveness trial conducted in patients older than 18 years of age with major depression, dysthymia, or minor depression did not detect any differences in the effectiveness of paroxetine and sertraline. ^49^ The investigators found no differences in effectiveness between paroxetine and sertraline in patients 18 years of age and older with major depression, dysthymia, or minor depression. Both treatment groups showed significant improvements in depression and other health-related quality of life domains (social function, work function, physical function) with no significant differences between study groups. No interactions between treatment groups and age (≥ 60 years of age vs. younger) were seen.

SSRIs vs. SNRIs. Citalopram vs. venlafaxine XR. A European 6-month study compared citalopram with venlafaxine XR for the treatment of depression in 151 elderly outpatients (mean age, 73 years). ^55^ The investigators found no statistically significant differences at study endpoint in any outcome measures (MADRS, CGI-S, CGI-I). MADRS remission rates were 23 percent for citalopram and 19 percent for venlafaxine (P = not reported). Both treatment groups reached a 93 percent response rate at week 22 (response defined as a reduction of at least 50 percent in MADRS score). Although outcome measures did not differ significantly, this finding does not conclusively demonstrate noninferiority. ^109^ More spontaneously reported adverse events were reported by venlafaxine-treated patients than citalopram-treated patients (62 percent vs. 43 percent, respectively); tremor was more common in the citalopram group than the venlafaxine group, and nausea or vomiting was more common in the venlafaxine group than the citalopram group.

Paroxetine vs. mirtazapine. One study compared paroxetine (20–40mg/day) and mirtazapine (15–45 mg/day) for the treatment of major depression in 255 elderly patients 65 years of age and older; the trial included an acute phase (8 weeks) and a continuation phase (16 weeks). ^73^ Mirtazapine was associated with significantly more patients who responded (50 percent reduction in HAM-D scores) at day 14 and patients in remission at day 42 (27.8 percent and 31.0 percent, respectively) than paroxetine (13.3 percent and 19.2 percent, respectively; P = 0.005 and P = 0.044, respectively). The median time to achieving response was significantly shorter for mirtazapine than for paroxetine (26 days vs. 40 days, respectively). At study endpoint, the number of CGI responders was similar in the mirtazapine and paroxetine treatment groups (64 percent and 56.7 percent, respectively, P = 0.267). Significantly more mirtazapine-treated patients reported dry mouth and weight gain (P < 0.05). Paroxetine-treated patients reported a significantly higher rate of nausea, tremor, and flatulence (P < 0.05).

Sertraline vs. venlafaxine IR. One 10-week randomized trial compared sertraline (up to 100 mg/day) and venlafaxine IR (up to 150 mg/day) among 52 nursing home residents (61 to 99 years of age). ^215^ We graded the quality of this study as poor for efficacy because of high loss to followup (44 percent), but we note it here because it is the only study comparing these two agents and because the high loss to followup may be expected in this population (elderly nursing home residents) and may not be a reflection of the quality of the study. The investigators reported a significantly higher rate of loss to followup among venlafaxine- than sertraline-treated patients (63 percent vs. 24 percent). Venlafaxine-treated patients had a significantly higher rate of withdrawal because of severe adverse events (P = 0.022) and withdrawal because of severe adverse events or side effects (P = 0.005) than did the sertraline-treated patients.

SSRIs vs. venlafaxine (IR or XR) vs. placebo. In one study, investigators pooled data from eight randomized trials of venlafaxine IR (75–375 mg/day) or venlafaxine XR (75–225 mg/day), one of several SSRIs (fluoxetine, 20–80 mg/day; fluvoxamine, 100–200 mg/day; paroxetine, 20–40 mg/day), or placebo in the treatment of depression. ^216,^ ^217^ This study was not based on a systematic literature search, so results must be viewed cautiously. The trials varied in length (6 weeks [three studies], 8 weeks [four studies], or 12 weeks [one study]) and included either outpatients (seven studies) or inpatients (one study). Four of the outpatient trials had a placebo arm. For venlafaxine-treated patients, neither age (< 50 or ≥ 50 years of age) nor sex affected remission rates. ^216^ Among patients treated with SSRIs, however, a significant interaction was observed between treatment and sex (P = 0.004): older women had a poorer SSRI response (response rate: 28 percent) than younger women (response rate: 36 percent) and both older and younger men (response rates: 35 percent and 36 percent, respectively). Remission rates for older women treated with venlafaxine (48 percent) were higher than remission rates for older women treated with SSRIs (28 percent, P = 0.0004). Hormone replacement therapy appeared to eliminate these differences. Additional analyses of age subgroups (≤ 40, 41–54, 55–64, and ≥ 65 years of age) and sex subgroups revealed that no significant age-by-treatment, sex-by-treatment, or age-by-sex-by-treatment interactions occurred; men and women of different ages within each treatment group had similar rates of remission, response, and absence of depressed mood. ^217^ Among patients over 40 years of age, the rates of adverse events were similar between the treatment groups, although venlafaxine-treated patients 55 to 64 years of age reported significantly more nausea than placebo (P ≤ 0.003), and placebo patients 41 to 54 years of age reported significantly more headache than venlafaxine (P ≤ 0.01).

A fair retrospective cohort study reported that hyponatremia in elderly inpatients (mean age 74 years) was significantly more common in patients treated with SSRIs or venlafaxine than in controls not on these drugs (OR, 3.5; 95% CI, 1.4–8.9). ^200^ Otherwise, evidence from controlled trials and observational studies is insufficient to conclude for or against an increased risk of hyponatremia in patients treated with SSRIs.

SSRIs vs. other second-generation antidepressants. Paroxetine vs. bupropion SR. One good-quality RCT examined the efficacy of paroxetine and bupropion SR over 6 weeks in 100 outpatients ages 60 years or older (range 60–88 years). ^84^ The majority of patients were white (paroxetine, 90 percent; bupropion SR, 98 percent), female (paroxetine, 60 percent; bupropion SR, 54 percent), and did not use antidepressants for the current episode before enrollment (paroxetine, 88 percent; bupropion SR, 83 percent). Statistical analysis used an LOCF approach. The overall loss to followup was 16 percent, with no significant difference between treatment groups. Overall adverse events were similar in the two treatment groups. Efficacy according to any outcome measure did not differ significantly between treatment groups. Response rates (≥ 50 percent reduction in HAM-D scores) were similar in both groups (paroxetine, 77 percent; bupropion SR, 71 percent).

SNRIs vs. other second-generation antidepressants. Mirtazapine vs. trazodone vs. placebo. One study compared mirtazapine with trazodone in patients with MDD older than 55 years of age. ^94^ Efficacy outcome measures in this trial favored mirtazapine, but differences did not reach statistical significance. Although outcome measures did not differ significantly, this finding does not conclusively demonstrate noninferiority. ^109^ More mirtazapine-treated patients discontinued treatment than did those on both trazodone and placebo. Both treatments were associated with more somnolence and dry mouth than placebo (P ≤ 0.05); trazodone treatment was associated with significantly more dizziness and blurred vision compared to placebo (P ≤ 0.05).

Placebo-controlled evidence. Two studies (four articles) provide evidence of the general efficacy of paroxetine (CR and IR formulations) and fluoxetine in the treatment of elderly patients with depression. ^213,^ ^222^ – ^224^ A good-quality trial evaluated the efficacy of fluoxetine for treating patients 60 years of age and older with dysthymia over 12 weeks. ^100^ ITT results indicated that fluoxetine had limited efficacy. Response rates on the HAM-D favored fluoxetine over placebo, but the two groups did not differ significantly (27.3 percent vs. 19.6 percent; P < 0.4). One study of fluoxetine vs. placebo (n = 671 patients older than 60 years of age) recorded a significant weight loss for fluoxetine compared with placebo. ^167^

A study of citalopram vs. placebo yielded no significant difference between the two treatment groups in response or remission rates except in the high severity group (P = 0.04). ^219^ One sertraline trial (two publications) demonstrated that sertraline was superior to placebo in elderly patients with late-life depression with and without comorbid medical illness (HAM-D and CGI-I response rates). ^220,^ ^221^ Another trial reported that sertraline was not superior to placebo in the prevention of recurrence; however, patients on sertraline experienced a longer time to recurrence than did patients on placebo (92 weeks and 48 weeks, respectively). ^137^

One large, primary-care-based effectiveness study (two publications) randomized 656 patients with dysthymia or minor depression to 11 weeks of paroxetine, placebo, or behavioral therapy. ^112,^ ^113^ Participants were stratified into patients 60 years and older (n = 415) and patients younger than 60 years (n = 241) for ITT analysis.

In the 60 or older subgroup, paroxetine-treated patients showed a greater change in HSCL-D-20 scores than placebo-treated patients (P = 0.004). ^112^ Effects were similar for patients with dysthymia and minor depression. For older dysthymia patients with high or intermediate baseline functioning scores, paroxetine significantly improved mental health functioning compared with placebo. Overall, however, improvements of mental health functioning were not statistically significantly different between dysthymia patients receiving paroxetine and those receiving placebo.

Among the younger patients, treatment groups did not differ significantly on the HSCL-D scale. ^113^ For dysthymia only, the remission rate of patients with at least 4 weeks of treatment was significantly higher in the paroxetine group than in the placebo group (80 percent vs. 44 percent; P = 0.008). Paroxetine was not more efficacious than placebo in patients with minor depression.

One 9-week pooled analysis trial evaluated the efficacy of duloxetine in 114 depressed women ages 40 to 55 and women younger than 40 or older than 55. ^218^ In women 40 to 55, both response rates (58.2 percent vs. 32.2 percent, P = 0.003) and remission rates (34.6 percent vs. 18.6 percent, P = 0.027) were significantly higher in the women receiving duloxetine than in women receiving placebo. The magnitude of treatment effect was similar in women 40 to 55 years of age and older women (more than 55 years of age) and younger women (less than 40 years of age).

### Sex: Key Points

Two head-to-head comparisons (one observational trial ^188^ and one pooled analysis ^216,^ ^217^ ) were available for the potential comparisons between the 12 second-generation antidepressants addressed in this report. The effects of second-generation antidepressants do not appear to differ by sex. ^188,^ ^216,^ ^217^ Some differences may exist in the frequency of some adverse events (sexual side effects, ^188^ headache, ^216,^ ^217^ and nausea). ^216,^ ^217^ In both cases, the strength of the evidence is low. ^188^

No placebo-controlled trials are available on the efficacy, effectiveness, and harms of second-generation antidepressants in men and women.

### Sex: Detailed Analysis

Head-to-head evidence. One head-to-head observational study and one pooled analysis compared men and women. ^188,^ ^216,^ ^217^ The pooled analyses do not provide evidence of any differences in efficacy, although some difference was observed in adverse events. Men experienced higher rates of headaches with venlafaxine than with placebo, and women experienced higher rates of nausea with venlafaxine than with placebo. ^216,^ ^217^ Observational evidence also suggests that men and women may experience differences in sexual side effects. ^188^ The strength of the evidence is low.

SSRIs vs. SNRIs. One 14-week trial of paroxetine (mean dose 30.7 mg/day), sertraline (99.0 mg/day), venlafaxine (151.6 mg/day), and moclobemide (485 mg/day) evaluated disturbances in sexual drive/desire and arousal/orgasm in depressed patients who completed 8 weeks of the study. ^188^ Men reported greater impairment in drive/desire than women (P < 0.05). Men and women did not differ significantly on the arousal/orgasm scale (P = 0.21). Rates of dysfunction in all treatment groups were similar for men; among women, sertraline and paroxetine appeared to be associated with greater dysfunction. All drugs appeared to be equally effective in reducing depressive symptoms (main effect for time, P < 0.001); a favorable drug response was associated with less sexual dysfunction.

SSRIs vs. venlafaxine (IR or XR) vs. placebo. As described above (head-to-head evidence for age), data were pooled from eight randomized trials of venlafaxine IR (75–375 mg/day) or venlafaxine XR (75–225 mg/day), one of several SSRIs (fluoxetine, 20–80 mg/day; fluvoxamine, 100–200 mg/day; paroxetine, 20–40 mg/day), or placebo in the treatment of depression. ^216,^ ^217^ Remission rates for venlafaxine-treated patients were not affected by sex. ^216^ Among patients treated with SSRIs, however, a significant interaction was observed between treatment and sex (P = 0.04): older women had a poorer SSRI response (28 percent) than younger women (36 percent) and than both older and younger men (35 percent and 36 percent, respectively). Additional analyses of the age (≤ 40, 41–54, 55–64, and ≥ 65) and sex subgroups revealed no significant sex-by-treatment or age-by-sex interactions; men and women of different ages within each treatment group had similar rates of remission, response, and absence of depressed mood. ^217^

Placebo-controlled evidence. We did not identify any placebo-controlled trials on the efficacy or harms of second-generation antidepressants in men and women.

### Race or Ethnicity: Key Points

One placebo-controlled efficacy study compared different racial or ethnic groups. ^225^ Fluoxetine and placebo did not differ significantly in outcomes, but this study may not have been powered to detect a significant difference; it was rated poor quality because it lacked an ITT analysis (completer analysis only). No studies directly compared the effectiveness and harms of second-generation antidepressants between different races or ethnicities.

### Race or Ethnicity: Detailed Analysis

Head-to-head evidence. No head-to-head trials on the efficacy, effectiveness, or harms of second-generation antidepressants compared different racial or ethnic groups.

Placebo-controlled evidence. One trial evaluated the efficacy of fluoxetine vs. placebo in the treatment of patients with comorbid HIV/AIDS. ^225^ We included it even though we rated it as poor for efficacy (no ITT analysis) because it is the only trial identified in the literature search that examined race or ethnicity.

A total of 118 patients were randomized to 8 weeks of treatment with either fluoxetine or placebo. Of all participants, 67 percent were white, 19 percent black, and 14 percent Latino; only 1.7 percent (n = 2) were female. Loss to followup was significantly greater among Latinos (53 percent) than blacks (14 percent) and whites (28 percent) (P < 0.05). Ethnicity was not associated with the total number of treatment side effects or dosage. Response rates among subjects who completed the study were higher in the fluoxetine group (white, 84 percent; black, 50 percent; Latino, 67 percent) than the placebo group (white, 43 percent; black, 36 percent; Latino, 80 percent). The differences were not significant; however, this may be because of the small sample size, particularly in the Latino group.

### Comorbidities: Key Points

We found no studies directly comparing the efficacy, effectiveness, and harms of second-generation antidepressants between depressed patients with comorbidities and the general population.

One poor-quality head-to-head study examined the efficacy of treatment with second-generation antidepressants for patients with MDD and comorbid HIV/AIDS. ^226^

Eighteen placebo-controlled trials of varying quality ^208^ – ^212,^ ^225,^ ^227^ – ^232,^ ^234^ – ^239^ and one systematic review ^233^ evaluated second-generation antidepressants in patients with various comorbid conditions. Some of these suggested that second-generation antidepressants may not be efficacious for depressed patients with comorbidities. ^208,^ ^210,^ ^212,^ ^225,^ ^227^ – ^229,^ ^231,^ ^236^ – ^239^ However, many of the studies may not have been powered to detect a difference between active treatment and placebo.

### Comorbidities: Detailed Analysis

HIV/AIDS. One poor-quality head-to-head study compared the efficacy and tolerability of fluoxetine, paroxetine, or sertraline in depressed individuals with HIV. ^226^ This 6-week open-label trial evaluated 33 depressed HIV-positive men and women. This trial was rated as poor because it included a completer-only analysis (no ITT analysis); it has been included here because it is the only head-to-head trial in patients with depression and various comorbidities. The overall clinical response rate for completers (n = 24) was 83 percent (fluoxetine, 90 percent; paroxetine, 86 percent; sertraline, 71 percent). Overall, and in each treatment group, significant reductions were seen in both affective and somatic symptoms (as measured by the HAM-D, BDI, HAM-D affective subscale, BDI cognitive subscale, HAM-D vegetative subscale, and BDI somatic subscale scores among completers), including somatic symptoms that were attributed to HIV rather than depression.

Two placebo-controlled studies evaluated the efficacy of fluoxetine vs. placebo in the treatment of patients with depression and comorbid HIV/AIDS. ^227,^ ^228^ The first study, a 12-week randomized trial, compared fluoxetine and placebo in the treatment of depression in patients with HIV/AIDS. ^228^ The second trial, a 12-week, randomized trial compared fluoxetine, testosterone, and placebo in the treatment of depression in patients with HIV/AIDS. ^227^ In both studies, fluoxetine and placebo response rates (57 percent vs. 41 percent ^228^ and 54 percent vs. 44 percent ^227^ ) did not differ significantly. However, these studies may not have been powered to detect a statistically significant difference.

A third, 8-week, placebo-controlled trial evaluated the efficacy of fluoxetine vs. placebo in the treatment of patients with comorbid HIV/AIDS (described for race and ethnicity). ^225^ We rated it as poor because it had no ITT analysis; however, we included it here because of the very limited evidence on this topic. Response rates among subjects who completed the study were higher in the fluoxetine group (white, 84 percent; black, 50 percent; Latino, 67 percent) than in the placebo group (white, 43 percent; black, 36 percent; Latino, 80 percent). The differences were not significant; however, this may be because of the small sample size, particularly in the Latino group.

Alcohol abuse. One randomized trial compared nefazadone and placebo in the treatment of depressed patients with comorbid alcohol dependence over a period of 10 weeks. ^208^ Nefazadone was superior to placebo, as measured by improvement in depression on the HAM-D from intake to study endpoint (mean change in HAM-D score for nefazadone vs. placebo: -12.25 vs. -12.55, P = 0.51), the difference did not achieve statistical significance, perhaps because the study was underpowered to do so.

Two randomized trials compared sertraline and placebo in the treatment of patients with depression and alcoholism. ^210,^ ^229^ Results suggested that, in some subgroups, sertraline was superior to placebo (i.e., in women), but overall the two treatment groups did not differ significantly. A 24-week study compared sertraline (50–150 mg/day) and placebo in recently detoxified alcohol-dependent patients with current depressive symptoms. ^229^ Response (≥ 50 percent decrease in MADRS) was slightly higher in sertraline-treated patients (44 percent) than in placebo-treated patients (39 percent). Both groups experienced significant improvements in HAM-D and MADRS scores during the study, although the two groups did not differ significantly. Adverse event rates were similar for the two treatment groups. A 12-week trial showed similar results. ^210^ In women, treatment with sertraline was associated with less depression at the end of treatment than those receiving placebo. Less drinking during the study was associated with improved depression outcomes.

Alzheimer's disease or dementia. Two randomized trials compared sertraline and placebo for patients with depression and comorbid Alzheimer's disease. ^230,^ ^231^ An 8-week trial of late-stage Alzheimer's disease failed to demonstrate a statistically significant difference between sertraline and placebo; 47 percent and 36 percent, respectively, achieved at least a 50 percent improvement in the Cornell Score for Depression in Dementia (CSDD) and 35 percent and 50 percent, respectively, achieved at least a 50 percent improvement in the Gestalt Depression Scale. However, this study may not have been powered to detect statistically significant differences. ^231^ A fair 12-week trial demonstrated that sertraline was statistically significantly superior to placebo, as measured by both the CSDD (P = 0.002) and the Hamilton Depression Rating Scale (HDRS) (P = 0.01). ^230^ More patients treated with sertraline responded to treatment (full responders, 38 percent; partial responders, 46 percent) than did patients treated with placebo (full responders, 20 percent; partial responders, 15 percent) (P = 0.007).

One poor-quality randomized trial compared citalopram and placebo for patients 65 years of age and older with depression and comorbid mild to moderate dementia. ^211^ We rated this trial poor because it appeared to be a completer-analysis only and had high loss to followup. In the efficacy analysis, which includes only those patients who completed the trial, the mean total HAM-D score at endpoint (P < 0.05) and improvement in HAM-D total score at endpoint (P < 0.01) were statistically significantly better for patients treated with citalopram than those receiving placebo; similar results were seen with the CGI-S. Significantly more citalopram-treated patients than placebo-treated patients improved (score of 1 or 2 on the CGI-I) (60 percent vs. 24 percent, P < 0.001).

Breast cancer. One randomized trial compared paroxetine and placebo for patients with breast cancer who were receiving at least four cycles of chemotherapy to evaluate whether the use of an antidepressant can alleviate symptoms of depression and reduce fatigue. ^232^ We rated it as poor because it appeared to be a completer-analysis only and the length of the study was not adequately described. Paroxetine was more effective in reducing depression during chemotherapy, as measured by the Center for Epidemiological Studies of Depression (CES-D) (P = 0.006); mean (standard deviation [SD]) scores at cycle 4 for paroxetine and placebo were 8.8 (1.11) and 12.6 (1.24), respectively. However, paroxetine and placebo did not differ significantly on all four fatigue scales.

Cardiovascular disease. AHRQ sponsored a systematic review of postmyocardial infarction (post-MI) depression that we graded fair overall. The authors concluded that SSRIs improve depression in post-MI patients. ^233^

We also identified three studies evaluating second-generation antidepressants in the treatment of depression in patients with MI or angina; ^209,^ ^234,^ ^235^ two had been included in the AHRQ report. ^234,^ ^235^ The first, a 24-week randomized trial, evaluated sertraline vs. placebo for treating depression in patients with acute MI or unstable angina. ^234^ The second, a good-quality 25-week randomized trial, evaluated fluoxetine vs. placebo in the treatment of depression after a first MI. ^235^ In both trials, active treatment was associated with a significantly greater response rate than placebo (sertraline, 67 percent; placebo, 53 percent; P = 0.01; ^234^ fluoxetine, 48 percent; placebo, 26 percent; P = 0.05 ^235^ ).

The third study was a pooled analysis of two randomized trials of sertraline (sertraline vs. fluoxetine and sertraline vs. nortriptyline); the article evaluated sertraline only in patients older than 60 with vascular disease (fluoxetine and nortriptyline results are not reported). ^209^ Newhouse et al. reported the results of the sertraline vs. fluoxetine comparison in all patients (not limited to those with cardiovascular disease); this article is described in detail for KQ 5, subsection Age. ^44^ Results for sertraline vs. nortriptyline were reported by Bondareff et al.; ^240^ this article was excluded because the comparison (sertraline vs. nortyriptyline) is outside of the scope of interest of this report.

The former analysis categorized patients into one of three groups: patients with a current diagnosis of hypertension but no other past or present cardiovascular disease, patients reporting a current or past history of cardiovascular illness but excluding hypertension, and patients with no hypertension and no other comorbid vascular illness. Sertraline was safe, well tolerated, and effective as an antidepressant in elderly patients suffering from hypertension and other forms of vascular comorbidity. Rates of response (measured by the HAM-D and the CGI-I) were similar in sertraline-treated patients in all three vascular illness categories.

Dialysis. We identified one randomized trial of fluoxetine vs. placebo in depressed patients on dialysis (N = 14). ^236^ Patients treated with fluoxetine had slightly greater improvement than patients treated with placebo, as measured by the BDI (-9.57 vs. -8.8, P = 0.91), the Brief Symptom Inventory (Depression Scale) (-4.43 vs. -3.2, P = 0.88), the HAM-D (-9.0 vs. -7.5, P = 0.72), and the MADRS (-11.14 vs. -6.67, P = 0.45). Although the differences were not statistically significant at study endpoint, this may be attributable to the small sample size. No patients discontinued because of side effects; no side effects were judged to be severe.

Stroke. Two studies evaluated the efficacy of citalopram and sertraline in the treatment of patients with poststroke depression. ^237,^ ^238^ One 6-week randomized trial evaluated the efficacy of citalopram vs. placebo in poststroke depression. ^237^ A 26-week trial evaluated the efficacy of sertraline vs. placebo in the treatment of minor depression and less severe depression in stroke patients. ^238^ Citalopram was associated with significantly greater improvements in depression than placebo on the HAM-D; mean (SD) improvements for citalopram vs. placebo were 8.0 (6.0) vs. 7.2 (5.8), respectively. ^237^ Sertraline and placebo did not differ significantly in response rates (week 6: 56 percent vs. 46 percent, respectively; week 26: 76 percent vs. 78 percent, respectively) or week 6 or week 26 remission rates (week 6: 59 percent vs. 51 percent, respectively; week 26: 81 percent vs. 87 percent, respectively). ^238^ However, at week 26, sertraline was associated with greater improvements in quality of life than placebo (effect size not reported, P < 0.05).

Substance abuse. Two studies evaluated the efficacy of fluoxetine in the treatment of patients with depression and comorbid substance abuse (persons with methadone-maintained opioid addiction or cocaine dependence); overall, fluoxetine and placebo did not differ significantly in reducing depressive symptoms. ^212,^ ^239^

One randomized 12-week trial evaluated fluoxetine vs. placebo in the treatment of depression in methadone-maintained opioid addicts. ^212^ Among the entire sample (N = 44), BDI (mean decrease for fluoxetine vs. placebo -8.0 vs. -4.7, respectively) and HDRS scores (mean decrease for fluoxetine vs. placebo: -6.0 vs. -7.7, respectively) decreased in both groups, but the treatment groups did not differ significantly. Among those subjects with major depression (n = 31), there were no significant differences in the rate of change of depressive symptoms by treatment group (fluoxetine vs. placebo) over time (BDI: -7.8 vs. -3.4; respectively; HDRS: -5.1 vs. -6.9, respectively). The second study, a poor-quality, 12-week randomized trial, evaluated fluoxetine vs. placebo for treating major depression in cocaine-dependent patients. ^239^ This trial was rated poor for efficacy (high loss to followup [52.9 percent]) but is included here because of the dearth of evidence on this topic. Fluoxetine and placebo did not differ significantly on the BDI (effect size not reported).