# Methods

## Topic Development

The topic of this report and preliminary key questions arose through a public process involving the public, the Scientific Resource Center (www.effectivehealthcare.ahrq.gov/aboutUs/contact.cfm) for the Effective Health Care program of the Agency for Healthcare Research and Quality (AHRQ) (www.effectivehealthcare.ahrq.gov), and various stakeholder groups (www.effectivehealthcare.ahrq.gov/aboutUs/stakeholder.cfm). Investigators from the RTI International-University of North Carolina Evidence-based Practice Center (RTI-UNC EPC) then refined the questions in consultation with AHRQ, the Scientific Resource Center, and a Technical Expert Panel (TEP).

## Literature Search

To identify articles relevant to each key question (Appendix B), we searched MEDLINE®, Embase, The Cochrane Library, PsychLit, and the International Pharmaceutical Abstracts. We used either Medical Subject Headings (MeSH or MH) as search terms when available or key words when appropriate. We combined terms for selected indications (major depressive disorder [MDD], dysthymia, minor depression, subsyndromal depressive disorder), drug interactions, and adverse events with a list of 12 specific second-generation antidepressants (bupropion, citalopram, duloxetine, escitalopram, fluoxetine, fluvoxamine, mirtazapine, nefazodone, paroxetine, sertraline, trazodone, and venlafaxine). We limited the electronic searches to “human” and “English language.” Sources were searched from 1980 to 2006 (February) to capture literature relevant to the scope of our topic.

We used the National Library of Medicine (NLM) publication type tags to identify reviews, randomized controlled trials (RCTs), and meta-analyses. We also manually searched reference lists of pertinent review articles and letters to the editor. We imported all citations into an electronic database (EndNote 9.0). Additionally, we handsearched the Center for Drug Evaluation and Research (CDER) database to identify unpublished research submitted to the US Food and Drug Administration (FDA).

The Scientific Resource Center contacted pharmaceutical manufacturers and invited them to submit dossiers, including citations. We received dossiers from three pharmaceutical companies (Eli Lilly, GlaxoSmithKline, and Wyeth).

Our searches found 1,967 citations, unduplicated across databases. Additionally, we detected 129 articles from manually reviewing the reference lists of pertinent review articles. Three other studies came from pharmaceutical dossiers. The total number of citations in our database was 2,099.

## Study Selection

We developed eligibility criteria with respect to study design or duration, patient population, interventions, outcomes, and comparisons to antidepressant medications outside our scope of interest, as described in Table 4 (in the introduction). Two persons independently reviewed abstracts. If both reviewers agreed that the trial did not meet eligibility criteria, we excluded it. We obtained the full text of all remaining articles and used the same eligibility criteria to determine which, if any, to exclude at this stage.

For this review, results from well-conducted, valid head-to-head trials provide the strongest evidence to compare drugs with respect to efficacy, effectiveness, and harms. We defined head-to-head trials as those comparing one second-generation antidepressant with another. RCTs of at least 6 weeks' duration and an adult study population with a sample size of at least 40 participants were eligible for inclusion.

We did not examine placebo-controlled trials in detail if head-to-head trials were available. If no head-to-head evidence was published, we reviewed placebo-controlled trials to provide an overview of efficacy. For harms (i.e., evidence pertaining to safety, tolerability, and adverse events), we examined data from both experimental and observational studies. We included observational studies with large sample sizes (≥100 patients), lasting at least 3 months, that reported an outcome of interest.

Initially, we reviewed studies with health outcomes as primary outcome measures. Outcomes for efficacy or effectiveness, for example, were quality of life, relapse, functional capacity, and hospitalization. If no study measuring health outcomes was available for a particular indication or population subgroup, we included intermediate outcomes (e.g., changes in depression scores). We reviewed response and remission when based on changes in depression scores as proxies for health outcomes (e.g., 50 percent improvement of depression scores for response). For harms (throughout this report we use “harms” as a summary term for adverse events and unwanted effects, as suggested by the CONSORT [Consolidated Standards of Reporting Trials] statement), we looked for both overall and specific outcomes ranging in severity (e.g., suicide, sexual side effects, hyponatremia, weight change, seizures, gastrointestinal symptoms, discontinuation syndrome), withdrawals attributable to adverse events, and drug interactions.

We included meta-analyses in our evidence report if we found them to be relevant for a key question and of good or fair methodological quality (based on the QUORUM statement ^15^ ). We did not review individual studies if they were included in a high-quality meta-analysis. We excluded meta-analyses that were not based on a comprehensive systematic literature search or did not maintain the units of the studies in their statistical analyses. We checked our database to guarantee that our literature search had detected trials included in any meta-analyses that we discarded, and we then obtained any missing articles.

## Data Extraction

We designed and used a structured data abstraction form to ensure consistency of appraisal for each study. Trained reviewers abstracted data from each study and assigned an initial quality rating. A senior reviewer read each abstracted article, evaluated the completeness of the data abstraction, and confirmed the quality rating.

We abstracted the following data from included trials: study design, eligibility criteria, intervention (drugs, dose, duration), additional medications allowed, methods of outcome assessment, population characteristics (such as age, sex, race or ethnicity, or comorbid anxiety), sample size, loss to followup, withdrawals because of adverse events, results, and adverse events reported. We recorded intention-to-treat results (ITT) if available. All data abstraction employed SRS 3.0, TrialStat™ Corporation.

## Quality Assessment

To assess the quality (internal validity) of trials, we used predefined criteria based on those developed by the US Preventive Services Task Force (ratings: good, fair, poor) ^16^ and the National Health Service Centre for Reviews and Dissemination. ^17^ Elements of quality assessment included, among others, randomization and allocation concealment, similarity of compared groups at baseline, use of ITT analysis (i.e., all patients are analyzed as randomized with missing values imputed), and overall and differential loss to followup.

In general terms, a “good” study has the least bias and results are considered to be valid. A “fair” study is susceptible to some bias, but probably not sufficient to invalidate its results. The fair quality category is likely to be broad, so studies with this rating will vary in their strengths and weaknesses. A “poor” rating indicates significant bias (stemming from, e.g., serious errors in design, analysis reporting large amounts of missing information, or discrepancies in reporting) that may invalidate the study's results.

To assess the quality of observational studies, we used criteria outlined by Deeks et al. ^18^ Items assessed included selection of cases or cohorts and controls, adjustment for confounders, methods of outcomes assessment, length of followup, and statistical analysis.

Two independent reviewers assigned quality ratings. They resolved any disagreements by discussion and consensus or by consulting a third, independent party.

Studies that met all criteria were rated good quality. The majority of studies received a quality rating of fair. This category includes studies that presumably fulfilled all quality criteria but did not report their methods to an extent that answered all our questions. Time constraints precluded our contacting study authors for clarification of methodological questions. Thus, the fair quality category includes studies with quite different strengths and weaknesses. Studies that had a fatal flaw in one or more categories were rated poor quality and, generally, excluded from our analyses. If no other evidence on an outcome of interest was available, we comment on findings from poor studies.

In addition to internal and external validity, we assessed the comparability of dosages. Because we could not find any clear definitions about equivalence of dosages among second-generation antidepressants in the published literature, we developed a roster of low, medium, and high dosages for each drug, which is outlined in Table 5. This classification, based on the interquartile dosing range, does not indicate dosing equivalence. We used this roster to detect gross inequalities in dosing that could affect comparative efficacy and effectiveness.

Table 5 Dosing classification based on lower and upper dosing range quartiles

Drug | Range | Low | Medium | High
Bupropion | 300–450 mg/d | < 337.5 | 337.5–412.5 | > 412.5
Citalopram | 20–60 mg/d | < 30 | 30–50 | > 50
Duloxetine | 60–100 mg/d | < 70 | 70–90 | > 90
Escitalopram | 10–30 mg/d | < 15 | 15–25 | > 25
Fluoxetine | 20–60 mg/d | < 30 | 30–50 | > 50
Fluvoxamine | 50–150 mg/d | < 75 | 75–125 | > 125
Mirtazapine | 15–45 mg/d | < 22.5 | 22.5–37.5 | > 37.5
Nefazodone | 300–600 mg/d | < 375 | 375–525 | > 525
Paroxetine | 20–60 mg/d | < 30 | 30–50 | > 50
Sertraline | 50–150 mg/d | < 75 | 75–125 | > 125
Trazodone | 300–600 mg/d | < 375 | 375–525 | > 525
Venlafaxine | 125–250 mg/d | < 156.25 | 156.25–218.75 | > 218.75

## Applicability Assessment

Throughout this report, we highlight effectiveness studies conducted in primary care or office-based settings that use less stringent eligibility criteria, assess health outcomes, and have longer followup periods than most efficacy studies. The results of effectiveness studies are more applicable to the spectrum of patients that will use a drug, have a test, or undergo a procedure than results from highly selected populations in efficacy studies. We used criteria proposed by Gartlehner et al. to distinguish effectiveness from efficacy trials. ^19^ These criteria assess seven categories: primary care population, eligibility criteria, outcome measures, study duration and intervention modalities, adverse events assessment, sample size, and ITT analysis.

## Rating Strength of a Body of Evidence

We rated the strength of the available evidence in a three-part hierarchy based on an approach devised by the GRADE working group. ^20^ Developed to grade the quality of evidence and the strength of recommendations, this approach incorporates four key elements: study design, study quality, consistency, and directness. As shown in Table 6, we used three grades: high, moderate, and low (combining the GRADE category of very low with low). ^21^ Gradings reflect the strength of the body of evidence to answer key questions on the comparative efficacy, effectiveness, and harms of second-generation antidepressants. Gradings do not refer to the general efficacy or effectiveness.

Table 6 Definitions of the grades of the overall quality of evidence

High | Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Further research is likely to have an important impact on our confidence in the estimate of the effect and may change the estimate.
Low | Further research is very likely to have an important impact on our confidence in the estimate of the effect and is likely to change the estimate.

Source: Adapted from the GRADE working group. ^20^

This approach does not incorporate other factors that might be relevant to assess reliably the comparative efficacy, effectiveness, and harms, such as funding sources and comparable dosing. We have assessed these additional factors and highlighted inequalities that could potentially bias our assessments (e.g., all studies funded by the same manufacturer).

## Data Synthesis

Throughout this report we synthesized the literature qualitatively. If data were sufficient, we augmented findings with quantitative analyses. We conducted meta-analyses of data for head-to-head comparisons for trials that were fairly homogenous in study populations and outcome assessments. For efficacy, we used two outcome measures:

1 The relative risk (RR) of being a responder (more than 50 percent improvement from baseline) on the Hamilton Rating Scale for Depression (HAM-D) or the Montgomery-Asberg Depression Rating Scale (MADRS) at study endpoint.
2 The weighted mean difference of changes on a specific depression rating scale (HAM-D or MADRS). We chose this outcome measure to have an estimate of the actual difference in effect sizes between treatments.

For each meta-analysis, we conducted a test of heterogeneity (I^2^ statistic) and applied both a random and a fixed effects model. We report the results from random effects models because, in all meta-analyses, the results from random and fixed effects models were very similar. If the RR was statistically significant, we then conducted a meta-analysis of the risk differences to calculate the number needed to treat (NNT) on the pooled risk difference.

We assessed publication bias using funnel plots and Kendell's tests. However, given the small number of component studies in our meta-analyses, these tests have low sensitivity to detect publication bias.

If fewer than three head-to-head trials were available for any drug comparison, we computed indirect comparisons. Evidence suggests that indirect comparisons agree with head-to-head trials if component studies are similar and treatment effects are expected to be consistent in patients in different trials. ^22^

For indirect comparisons we employed two statistical approaches:

1 We conducted meta-regressions of good or fair placebo-controlled trials using individual drugs as covariates. We also attempted to assess the influence of disease severity, concomitant anxiety, and dosing on our findings. Data, however, were insufficient to use these factors as covariates in the meta-regression models.
2 When the number of placebo-controlled trials was insufficient to conduct meta-regressions, we used network meta-analyses. ^23^ Network meta-analyses allow the use of studies with multiple common comparators. Therefore, we could include both placebo-controlled and active-controlled studies, increasing the precision of results. All statistical analyses used StatsDirect Ltd. version 2.4.5, and STATA 9.1.