# Introduction

## Background

Axis I psychiatric disorders such as depressive disorder, anxiety disorder, adjustment disorder, and premenstrual dysphoric disorders can be serious disabling illnesses. Combined, they affect approximately one in five Americans. ^1^ Major depressive disorder (MDD) is the most prevalent, affecting more than 16 percent (lifetime) of US adults. ^2^ In 2000, the US economic burden of depressive disorders was estimated to be $83.1 billion. ^3^ More than 30 percent of these costs were attributable to direct medical expenses.

Pharmacotherapy dominates the medical management of Axis I mood and anxiety disorders. Before the late 1980s, pharmacologic treatment was limited to tricyclic antidepressants (TCAs) and monoamine oxidase inhibitors (MAOIs) (with the exception of premenstrual dysphoric disorder, which historically was untreated). TCAs and MAOIs sometimes are referred to as traditional or first-generation antidepressants. They are often accompanied by multiple side effects that many patients find intolerable. For example, TCAs tend to cause anticholinergic effects including dry mouth and eyes, urinary hesitancy, and sometimes retention and constipation. In addition, TCAs have a high rate of lethality when overdose occurs; MAOIs can produce hypertensive crisis if taken along with certain foods or dietary supplements containing excessive amounts of tyramine. Thus, first-generation antidepressants are no longer agents of choice in many circumstances.

Newer treatments include selective serotonin reuptake inhibitors (SSRIs), serotonin and norepinephrine reuptake inhibitors (SNRIs), and other second-generation drugs. The first of the second-generation drugs was introduced to the US market in 1982, when trazodone was approved for treatment of patients with MDD. In 1987, the US Food and Drug Administration (FDA) approved the first SSRI, fluoxetine. Since then, five other SSRIs have been introduced: sertraline (1991), paroxetine (1992), citalopram (1999), fluvoxamine (2000), and escitalopram (2002).

Two other second-generation antidepressant drugs, trazodone and nefazodone, also function as serotonin reuptake inhibitors, but they possess additional serotonin antagonist properties. Trazodone, which was first synthesized in 1966, appears to produce its primary effect by selectively inhibiting serotonin reuptake, but it also causes adrenoreceptor subsensitivity and induces significant changes in 5-hydroxytryptamine (5-HT) presynaptic receptor adrenoreceptors. Although approved for MDD, trazodone commonly is used as a sedative to complement newer stimulating antidepressants. In 1994, the FDA approved nefazodone, which is essentially an SSRI with additional 5-HT2 and 5-HT3 antagonist properties.

The SNRIs were first introduced to the market in 1993 with the approval of venlafaxine. Mirtazapine, a drug that acts centrally on adrenergic autoreceptors, was added to the therapeutic arsenal in 1996. ^4^ Duloxetine, a selective serotonin and norepinephrine reuptake inhibitor (SSNRI), was approved for the treatment of MDD and diabetic peripheral neuropathic pain in 2004.

The mechanism of action of most second-generation antidepressants is poorly understood. In general, these drugs work through their effect on prominent neurotransmitters in the central nervous system. Bupropion is a relatively weak inhibitor of the neuronal uptake of norepinephrine, serotonin, and dopamine; its primary mechanism of action is believed to be dopaminergic and noradrenergic. The SSRIs (citalopram, escitalopram, fluoxetine, fluvoxamine, paroxetine, and sertraline) act by selectively inhibiting the reuptake of serotonin 5-HT at the presynaptic neuronal membrane. Reuptake inhibition has the effect of increasing the levels of serotonin made available to improve the transmission of neural signals at the synapse. The SNRIs (venlafaxine) are potent inhibitors of serotonin and norepinephrine reuptake and weak inhibitors of dopamine reuptake. Mirtazapine, sometimes characterized as an SNRI, is believed to enhance central noradrenergic and serotonergic activity as a 5-HT2 and 5-HT3 receptor antagonist. Trazodone inhibits neuronal uptake of serotonin. At low doses, it appears to act as a serotonin antagonist and at higher doses as an agonist. ^5,^ ^6^ Nefazodone is believed to inhibit neuronal uptake of serotonin and norepinephrine. Preclinical studies of duloxetine suggest that it is a potent inhibitor of neuronal serotonin and norepinephrine reuptake and a less potent inhibitor of dopamine reuptake.

Except for fluvoxamine, which is approved only for the treatment of obsessive-compulsive disorder (OCD), all second-generation antidepressants are approved for the treatment of MDD. Table 1 summarizes the newer products that are available in the United States by mechanism of action; it shows names, all dosage forms, therapeutic class, and FDA-approved (labeled) uses. The second-generation antidepressants have established a prominent role in the US pharmaceutical market. In 2003, the antidepressant class, including SSRIs and SNRIs, ranked third in US prescription sales among all drug therapy classes. ^7^ The serotonergic class dominates this market, accounting for 57.6 percent of market share in 2002. ^7^ Prescription drug spending for these products is not anticipated to decline until 2009, when the patents for leading brands will expire.

Table 1 Second-generation antidepressants approved for use in the United States

Generic Name | US Trade Name* | Dosage Forms | Therapeutic Classification | Labeled Uses†
Bupropion‡ | Wellbutrin®; | 75, 100 mg tabs; | Other | MDD
| Wellbutrin SR®; | 50, 100, 150, 200 mg SR tabs
| Wellbutrin XL®; | 150, 300 mg XL tabs
| Zyban®
Citalopram‡ | Celexa® | 10, 20, 40 mg tabs; | SSRI | MDD
| | 1, 2 mg/ml solution
Duloxetine | Cymbalta® | 20, 30, 60 mg caps | Other | MDD;
| | | | Neuropathic pain
Escitalopram | Lexapro®§ | 10, 20 mg tabs | SSRI | MDD;
| | 1 mg/ml solution | | GAD
Fluoxetine‡ | Prozac®; | 10, 20, 40 mg caps; | SSRI | MDD; OCD;
| Prozac Weekly®; | 10 mg tabs; | | PMDD;
| Sarafem® | 4 mg/ml solution; | | Panic disorder
| | 90 mg pellets (weekly)
Fluvoxamine‡ | Luvox®‖ | 25, 50, 100 mg tabs | SSRI | OCD
Mirtazapine‡ | Remeron® | 15, 30, 45 mg tabs; | Other | MDD
| | 15, 30, 45 mg orally disintegrating tabs
Nefazodone‡ | Serzone®‖ | 50, 100, 150, 200, 250 mg tabs | Other | MDD
Paroxetine‡ | Paxil®; | 10, 20, 30, 40 mg tabs; | SSRI | MDD;
| Paxil CR® | 2 mg/ml solution; | | OCD;
| | 12.5, 25, 37.5 mg CR tabs | | Panic disorder;
| | | | Social anxiety disorder;
| | | | GAD;
| | | | PTSD;
| | | | PMDD¶
Sertraline‡ | Zoloft® | 25, 50, 100 mg tabs; | SSRI | MDD;
| | 20 mg/ml solution | | OCD;
| | | | Panic disorder;
| | | | PTSD;
| | | | PMDD;
| | | | Social anxiety disorder
Trazodone‡ | Desyrel® | 50, 100, 150, 300 mg tabs | Other | MDD
Venlafaxine | Effexor®; | 25, 37.5, 50, 75, 100 mg tabs; | SNRI | MDD;
| Effexor XR® | 37.5, 75, 150 mg XR caps | | GAD;**
| | | | Social anxiety disorder**

* CR, SR, XL, and XR are registered trademarks referring to controlled, sustained, or extended-release dosage forms.

† GAD, generalized anxiety disorder; MDD, major depressive disorder; OCD, obsessive-compulsive disorder; PMDD, premenstrual dysphoric disorder; PTSD, post-traumatic stress disorder.

‡ Generic available for some dosage forms.

§ Lexapro was denied approval for social anxiety disorder March 30, 2005.

‖ Brand-name product no longer available in the US.

¶ Only Paxil CR® (not Paxil®) is approved for the treatment of PMDD.

** Only Effexor XR® (not Effexor®) is approved for the treatment of GAD and social anxiety disorder.

Compared with the first-generation antidepressants, the SSRIs and other second-generation antidepressant have comparable efficacy and comparable or better side effect profiles. ^8,^ ^9^ However, comparative differences in efficacy, tolerability, and safety are not well defined among the second-generation drugs. The tremendous volume and large variability in the quality of evidence to support use of these products makes it difficult for clinicians, patients, and others to make evidence-based decisions.

## Purpose of this Report

The purpose of this review is to help policymakers and clinicians make informed choices about the use of SSRIs and newer antidepressants. Given the prominent role of drug therapy in psychiatric disease and the prevalent use of these drugs, our goal is to summarize comparative data on the efficacy, effectiveness, and harms of newer antidepressants: bupropion, citalopram, duloxetine, escitalopram, fluoxetine, fluvoxamine, mirtazapine, paroxetine, sertraline, trazodone, nefazodone, and venlafaxine. We examine the role of these agents in treating patients with depressive syndrome, including MDD, dysthymic disorder, and subsyndromal depressive disorders. We focus this review on these disorders in adult populations.

This report extends prior analyses by addressing two areas that are relevant for clinicians and policymakers but that previous reports have not covered. First, we consider treatment in the continuation and maintenance phases of depression, not simply the acute phase of treatment (see Figure 1). Previous estimates suggest that continuing treatment beyond the acute phase can reduce the odds of relapse by 70 percent. ^10^ However, most reports have been limited to outcomes in the acute phase of management, i.e., the initial part of treatment during which the treatment goal is eradication of the depressive symptoms to achieve remission.

Figure 1. Phases of treatment for major depression

We consider all three phases of depression management:

- acute phase, usually 6 to 12 weeks in length;
- continuation phase, during which the treatment goal is continued absence of depressive symptoms for an additional 4 to 9 months such that the patient's episode can be considered completely resolved; and
- maintenance phase, the frequently multi-year period during which the treatment goal is preventing the recurrence of a new, distinct episode.

This categorization allows us to make the clinically relevant distinction between relapse and recurrence. We define relapse as the return of depressive symptoms during the acute or continuation phases, so it is considered part of the same depressive episode. We define recurrence as the return of depressive symptoms during the maintenance phase, so it is considered a new, distinct episode.

This distinction is critical to determining the long-term treatment plan. If an individual has a single episode of MDD that has resolved, treatment recommendations may or may not include continued medication treatment. If, however, an individual has a diagnosis of recurrent MDD, the recommendation for continued treatment may be years. ^12,^ ^13^ In addition, this categorization can frame decisions about depression management into best treatments for immediate resolution of depressive symptoms (acute phase) and those best for ongoing management once symptoms have resolved (continuation and maintenance phases). Of note, the latter two phases involve a time period of much greater duration than the first one.

Second, we review the data addressing whether the presence of accompanying symptoms, such as anxiety and insomnia, might affect outcomes. For example, MDD is frequently associated with concurrent anxiety. If certain antidepressants can more successfully treat such a depression than other agents, or if they can mitigate the specific concurrent anxiety symptoms, these agents might be preferred choices. Such data could guide clinicians on how better to target antidepressant selection and steer policymakers toward the best available agents.

Table 1 (above) and Table 2 provide detailed information on second-generation agents approved for use in the United States. Table 2 shows trade names, usual (recommended) daily doses, and frequency.

Table 2 Usual dosing range and frequency of administration for adults

Generic Name | US Trade Name* | Usual Daily Dosing Range | Frequency
Bupropion | Wellbutrin® | 100–450 mg | Three times daily
| Wellbutrin SR® | 150–400 mg | Twice daily
| Wellbutrin XL® | 150–450 mg | Once daily
Citalopram | Celexa® | 20–60 mg | Once daily
Duloxetine | Cymbalta® | 40–60 mg | Once or twice daily
Escitalopram | Lexapro® | 10–20 mg | Once daily
Fluoxetine | Prozac® | 10–80 mg | Once or twice daily
| Prozac Weekly® | 90 mg (weekly) | Once weekly
| Sarafem® | 20 mg | Once daily†
Fluvoxamine | Luvox®§ | 50–300 mg | Once or twice daily
Mirtazapine | Remeron® | 15–45 mg | Once daily
Nefazodone‡ | Serzone®§ | 200–600 mg | Twice daily
Paroxetine | Paxil® | 10–60 mg | Once daily
| Paxil CR® | 12.5–75 mg | Once daily
Sertraline | Zoloft® | 25–200 mg | Once daily
Trazodone | Desyrel® | 150–400 mg | Three times daily
Venlafaxine | Effexor® | 75–375 mg | Two to three times daily
| Effexor XR® | 75–225 mg | Once daily

* CR, SR, XL, and XR are registered trademarks referring to controlled-, sustained-, or extended-release dosage forms.

† Sarafem is marketed for the treatment of premenstrual dysphoric disorder (PMDD); dosing may be continuous or intermittent.

‡ Branded product withdrawn from the US market effective June 14, 2004.

§ Brand-name product no longer available in the US.

## Scope and Key Questions

This review compares the efficacy, effectiveness, and harms of second-generation antidepressant medications. To that end, we address the following key questions:

1a For adults with major depressive disorder (MDD), dysthymia, or subsyndromal depressive disorders, do commonly used medications for depression differ in efficacy or effectiveness in treating depressive symptoms?
1b If a patient has responded to one agent in the past, is that agent better than current alternatives at treating depressive symptoms?
2a For adults with a depressive syndrome, do antidepressants differ in their efficacy or effectiveness for maintaining response or remission (i.e., preventing relapse or recurrence)?
2b For adults receiving antidepressant treatment for a depressive syndrome that either has not responded (acute phase) or has relapsed (continuation phase) or recurred (maintenance phase), do alternative antidepressants differ in their efficacy or effectiveness for treatment-resistant or recurrent depression?
3 Do medications or combinations of medications (including tricyclics in combination) used to treat depression differ in their efficacy or effectiveness for treating accompanying symptoms, such as anxiety, insomnia, and neurovegetative symptoms? This question focuses on accompanying neurovegetative (physical) symptoms of depression (such as disturbances in sleep, appetite, or motor activity; or symptoms of fatigue or pain). These symptom clusters are in contrast to psychological or cognitive symptoms, such as worthlessness, hopelessness, excessive guilt, and suicidal ideation. For patients presenting with these accompanying symptom clusters, two treatment outcomes are relevant: the effect on the depressive disorder overall, and the effect on the particular accompanying symptoms. Consequently, we further divide this question into two subquestions:
  3a Do medications differ in their efficacy and effectiveness in treating the depressive episode?
  3b Do medications differ in their efficacy and effectiveness in treating the accompanying symptoms?
4 For adults with a depressive syndrome, do commonly used antidepressants differ in safety, adverse events, or adherence? Adverse effects of interest include but are not limited to nausea, diarrhea, headache, tremor, daytime sedation, decreased libido, failure to achieve orgasm, nervousness, insomnia, and more serious events including suicide.
5 How do the efficacy, effectiveness, or harms of treatment with antidepressants for a depressive syndrome differ for the following subpopulations?
  - elderly or very elderly patients;
  - other demographic groups (defined by age, ethnic or racial groups, and sex);
  - patients with medical comorbidities (e.g., ischemic heart disease, cancer);
  - patients with psychiatric and behavioral comorbidities (e.g., substance abuse disorders); and
  - patients taking other medications.

Throughout this report, we highlight effectiveness studies conducted in primary care or office-based settings that use less stringent eligibility criteria, assess health outcomes, and have longer followup periods than most efficacy studies. ^14^ We deemed studies that met at least six of seven predefined criteria as effectiveness studies (Table 3). Their results are more applicable to the average patient than results from highly selected populations in efficacy studies.

Table 3 Criteria for effectiveness studies

Criteria | Relevance to Treatment of Depressive Disorders
Study population | Primary care population
Less stringent eligibility criteria | Determine case by case
Health outcomes | Response, remission, quality of life, functional capacity, hospitalization
Clinically relevant treatment modalities | ≥ 8 weeks study duration; flexible dose design; physician-based diagnosis
Assessment of adverse events | Always
Adequate sample size to assess a minimally important difference from a patient perspective | N ≥ 150
Intention-to-treat analysis | Always

For each key question, we evaluated specific outcome measures (where appropriate), as reported in Table 4. For efficacy and effectiveness, we focused on head-to-head trials comparing one second-generation antidepressant with another. When sufficient head-to-head evidence was unavailable, we evaluated placebo-controlled evidence. Finally, we included observational studies to assess relapse or recurrence prevention, second-line treatment, and safety and tolerability.

Table 4 Outcome measures and study eligibility criteria

Key Question Outcomes of Interest and Specific Measures | Study Eligibility Criteria
Key Questions 1, 3, and 5: Efficacy and effectiveness | Study design; - Head-to-head, double-blind, RCTs; - High-quality meta-analyses; - When sufficient evidence is not available for direct head-to-head comparisons: double-blind, placebo-controlled RCTs
Response | Minimum study duration; - 6 weeks
Remission | Study population; - Adult inpatients and outpatients with major depressive disorder, dysthymia, or subsyndromal depression
Speed of response/remission | Sample size; - For quantitative analysis: no limit; - For qualitative analysis: n ≥ 40
Relapse
Quality of life
Functional capacity
Hospitalization
Key Question 2a: Maintenance of remission | Study design; - Head-to-head, double-blind, RCTs; - High-quality meta-analyses; - High-quality, controlled observational studies
| Minimum study duration; - For all studies: 3 months
| Study population; - Adult inpatients and outpatients with a history of depressive illnesses currently in remission
| Sample size; - For RCTs: no limit; - For observational studies: n ≥ 100
Key Question 2b:Response and remission for recurrent depression | Study design; - Head-to-head, double-blind, RCTs; - High-quality meta-analyses; - High-quality, controlled observational studies
| Minimum study duration; - For RCTs: 6 weeks; - For observational studies: 3 months
| Study population; - Adult inpatients and outpatients with recurrent depression
| Sample size; - For RCTs:; 1 For quantitative analysis: no limit; 2 For qualitative analysis: n ≥ 40; - For observational studies: n ≥ 100
Key Question 4: Safety and tolerability: | Study design; - Head-to-head, double-blind, RCTs; - High-quality meta-analyses; - Observational studies (cohort studies, case-control studies, large database reviews)
- Overall adverse events; - Withdrawals because of adverse events; - Serious adverse events; - Specific adverse events or withdrawals because of specific adverse events, including:; 3 hyponatremia; 4 seizures; 5 suicide; 6 hepatoxicity; 7 weight gain; 8 gastrointestinal symptoms; 9 sexual side effects; 10 others | Minimum study duration; - For RCTs: 6 weeks; - For observational studies: 3 months
| Study population; - Adult inpatients and outpatients with major depressive disorder, dysthymia, or subsyndromal depression
| Sample size; - For RCTs:; 11 For quantitative analysis: no limit; 12 For qualitative analysis: n ≥ 40; - For observational studies: n ≥ 100

RCT, randomized controlled trial.

Appendix A lists our peer reviewers. Appendices B–I pertain to aspects of our results.