# Publications Appearing Only as Abstracts

1 Ansseau M, Gabriels A, Loyens J, Bartholome F, Evrard J, Linhart R, et al. A double-blind comparison of paroxetine and fluvoxamine in major depression. Eur Neuropsychopharmacol. 1993;3(3):323-324.
2 Montgomery SA. Comparative efficacy and tolerability of escitalopram oxalate versus venlafaxine XR. Data on file at Forest Laboratories. 2004.
3 Skinner EP, Cantrell R, Chaffin J, et al. Adherence with once-daily bupropion XL versus twice-daily bupropoion SR. J Am Pharm Assoc. 2005;45:265.