# Meta-analyses of Discontinuation Rates

## Discontinuation Rates

### Background

Presented in this appendix are relative risk meta-analyses that compare selective serotonin reuptake inhibitors (SSRIs) with individual drugs with respect to discontinuation. The specific comparisons with SSRIs are shown below: bupropion, duloxetine, mirtazapine; nefazodone; trazodone, and venlafaxine The first six figures are for overall discontinuation. The two sets of figures following those are for discontinuation specifically for adverse events and then for discontinuation for lack of efficacy. All are random effects models.

### Relative Risk of Overall Discontinuation

Figure H-1. Bupripion vs. SSRIs

Figure H-2. Duloxetine vs. SSRIs

Figure H-3. Mirtazapine vs. SSRIs

Figure H-4. Nefazodone vs. SSRIs

Figure H-5. Trazadone vs. SSRIs

Figure H-6. Venlafaxine vs. SSRIs

### Relative Risk of Discontinuation because of Adverse Events

Figure H-7. Bupropion vs. SSRIs: Adverse Events

Figure H-8. Duloxetine vs. SSRIs: Adverse Events Only

Figure H-9. Mirtzapine vs SSRIs: Adverse Events Only

Figure H-10. Nefazodone vs SSRIs: Adverse Events Only

Figure H-11. Trazodone vs SSRIs: Adverse Events Only

Figure H-12. Venlafaxine vs SSRIs: Adverse Events Only

### Relative Risk of Discontinuation because of Lack of Efficacy

Figure H-13. Bupropion vs. SSRIs: Lack of Efficacy

Figure H-14. Mirtzazpine vs. SSRIs: Lack of Efficacy

Figure H-15. Nefazodone vs SSRIs: Lack of Efficacy

Figure H-16. Venlaxafine vs SSRIs: Lack of Efficacy