# Placebo Studies Excluded from Meta-Regression

Study | Design | Sample Size | Intervention | Reason for Exclusion
Brown et al., 2005 ^1^ | RCT | 90 | Citalopram vs. placebo | High attrition
Byerley et al., 1988 ^2^ | RCT | 97 | Fluoxetine vs. placebo | No ITT analysis
Claghorn et al., 1995 ^3^ | RCT | 90 | Mirtazapine vs. placebo | No ITT analysis
Claghorn et al., 1996 ^4^ | RCT | 150 | Fluvoxamine vs. placebo | No ITT analysis
Claghorn, 1992 ^5^ | RCT | 72 | Paroxetine vs. placebo | No ITT analysis
Cohn et al., 1990 ^6^ | RCT | 120 | Paroxetine vs. placebo | No ITT analysis
Cohn et al., 1992 ^7^ | RCT | 120 | Paroxetine vs. placebo | No ITT analysis; high rate of post-randomization exclusions
Corrigan et al., 2000 ^8^ | RCT | 70 | Fluoxetine vs. placebo | No ITT analysis
Croft et al., 2002 ^9^ | RCT | 432 | Bupropion vs. placebo | High LTF
Dunbar et al., 1991 ^10^ | RCT | 480 | Paroxetine vs. placebo | High Attrition
Dunbar et al., 1993 ^11^ | RCT | 273 | Paroxetine vs. placebo | High Attrition
Elliot et al., 1998 ^12^ | RCT | 75 | Paroxetine vs. placebo | High LTF; no ITT analysis
Evans et al., 1997 ^13^ | RCT | 82 | Fluoxetine vs. placebo | High Attrition
Fabre et al., 1996 ^14^ | RCT | 100 | Fluvoxamine vs. placebo | High Attrition
Fabre et al., 1995 ^15^ | RCT | 369 | Sertraline vs. placebo | No ITT analysis
Fabre et al.,1992 ^16^ | RCT | 74 | Paroxetine vs. placebo | High Attrition
Fabre et al., 1987 ^17^ | RCT | 84 | Fluoxetine vs. placebo | No ITT analysis
Fava et al., 2005 ^18^ | RCT | 90 | Fluoxetine vs. placebo | High Attrition
Fava et al., 1997 ^19^ | RCT | 20 | Venlafaxine vs. placebo | No ITT analysis
Feighner et al., 1989 ^20^ | RCT | 45 | Nefazodone vs. placebo | Not enough data
Feighner et al., 1992 ^21^ | RCT | 430 | Paroxetine vs. placebo | High Attrition
Feighner et al., 1992 ^22^ | RCT | 76 | Paroxetine vs. placebo | High Attrition
Feighner et al., 1993 ^23^ | RCT | 480 | Paroxetine vs. placebo | High Attrition
Feighner et al., 1998 ^24^ | RCT | 117 | Nefazodone vs. placebo | High Attrition
Gilaberte et al., 2001 ^25^ | RCT | 140 | Fluoxetine vs. placebo | High attrition
Lapierre et al., 1987 ^26^ | RCT | 63 | Fluvoxamine vs. placebo | No ITT analysis
March et al., 1990 ^27^ | RCT | 54 | Fluvoxamine vs. placebo | No ITT analysis
McGrath et al., 2000 ^28^ | RCT | 154 | Fluoxetine vs. placebo | High rate of post-randomization exclusions
Montgomery et al., 1992 ^29^ | RCT | 199 | Citalopram vs. placebo | High rate of post-randomization exclusions
Muijen et al., 1988 ^30^ | RCT | 81 | Fluoxetine vs. placebo | No ITT analysis
Petracca et al., 2001 ^31^ | RCT | 41 | Fluoxetine vs. placebo | No ITT analysis
Ravindram et al., 1995 ^32^ | RCT | 103 | Sertraline vs. placebo | High attrition; no ITT analysis
Reimherr et al., 1998 ^33^ | RCT | 362 | Bupropion vs. placebo | High Attrition
Rickels et al., 1994 ^34^ | RCT | 191 | Nefazodone vs. placebo | High Attrition
Rickels et al., 1982 ^35^ | RCT | 202 | Trazadone vs. placebo | No ITT analysis
Rickels et al., 1992 ^36^ | RCT | 111 | Paroxetine vs. placebo | No ITT analysis
Roth et al., 1990 ^37^ | RCT | 90 | Fluvoxamine vs. placebo | No ITT analysis
Roy-Byrne et al., 2000 ^38^ | RCT | 64 | Nefazodone vs. placebo | High Attrition
Rudolph et al., 1998 ^39^ | RCT | 358 | Venlafaxine vs. placebo | High Attrition
Schweizer et al., 1991 ^40^ | RCT | 60 | Venlafaxine vs. placebo | High Attrition
Smith et al., 1990 ^41^ | RCT | 150 | Mirtazapine vs. placebo | No ITT analysis
Smith et al., 1992 ^42^ | RCT | 77 | Paroxetine vs. placebo | No ITT analysis
Sramek et al., 1995 ^43^ | RCT | 144 | Fluoxetine vs. placebo | Not enough data
Vartiainen et al., 1994 ^44^ | RCT | 114 | Mirtazapine vs. placebo | High Attrition
Wernicke et al., 1987 ^45^ | RCT | 345 | Fluoxetine vs. placebo | High Attrition
Wernicke et al., 1988 ^46^ | RCT | 363 | Fluoxetine vs. placebo | Not enough data

ITT, intent to treat; RCT, randomized controlled trial; LTF, lost to follow-up

## References for Appendix G

1 Brown ES, Vigil L, Khan DA, Liggin JD, Carmody TJ, Rush AJ. A randomized trial of citalopram versus placebo in outpatients with asthma and major depressive disorder: a proof of concept study. Biol Psychiatry. 2005;58(11):865-70. [pmid: 15993860].
2 Byerley WF, Reimherr FW, Wood DR, Grosser BI. Fluoxetine, a selective serotonin uptake inhibitor, for the treatment of outpatients with major depression. J Clin Psychopharmacol. 1988;8(2):112-5. [pmid: 3286684].
3 Claghorn JL, Lesem MD. A double-blind placebo-controlled study of Org 3770 in depressed outpatients. J Affect Disord. 1995;34(3):165-71. [pmid: 7560544].
4 Claghorn JL, Earl CQ, Walczak DD, Stoner KA, Wong LF, Kanter D, et al. Fluvoxamine maleate in the treatment of depression: a single-center, double-blind, placebo-controlled comparison with imipramine in outpatients. J Clin Psychopharmacol. 1996;16(2):113-20. [pmid: 8690826].
5 Claghorn JL. The safety and efficacy of paroxetine compared with placebo in a double-blind trial of depressed outpatients. J Clin Psychiatry. 1992;53(Suppl):33-5. [pmid: 1531821].
6 Cohn JB, Crowder JE, Wilcox CS, Ryan PJ. A placebo- and imipramine-controlled study of paroxetine. Psychopharmacol Bull. 1990;26(2):185-9. [pmid: 2146697].
7 Cohn JB, Wilcox CS. Paroxetine in major depression: a double-blind trial with imipramine and placebo. J Clin Psychiatry. 1992;53(Suppl):52-6. [pmid: 1531826].
8 Corrigan MH, Denahan AQ, Wright CE, Ragual RJ, Evans DL. Comparison of pramipexole, fluoxetine, and placebo in patients with major depression. Depress Anxiety. 2000;11(2):58-65. [pmid: 10812530].
9 Croft H, Houser TL, Jamerson BD, Leadbetter R, Bolden-Watson C, Donahue R, et al. Effect on body weight of bupropion sustained-release in patients with major depression treated for 52 weeks. Clin Ther. 2002;24(4):662-72. [pmid: 12017410].
10 Dunbar GC, Cohn JB, Fabre LF, Feighner JP, Fieve RR, Mendels J, et al. A comparison of paroxetine, imipramine and placebo in depressed out-patients. Br J Psychiatry. 1991;159:394-8. [pmid: 1835664].
11 Dunbar GC, Claghorn JL, Kiev A, Rickels K, Smith WT. A comparison of paroxetine and placebo in depressed outpatients. Acta Psychiatr Scand. 1993;87(5):302-5. [pmid: 8517168].
12 Elliott AJ, Uldall KK, Bergam K, Russo J, Claypoole K, Roy-Byrne PP. Randomized, placebo-controlled trial of paroxetine versus imipramine in depressed HIV-positive outpatients. Am J Psychiatry. 1998;155(3):367-72. [pmid: 9501747].
13 Evans M, Hammond M, Wilson K, Lye M, Copeland J. Placebo-controlled treatment trial of depression in elderly physically ill patients. Int J Geriatr Psychiatry. 1997;12(8):817-24. [pmid: 9283926].
14 Fabre L, Birkhimer LJ, Zaborny BA, Wong LF, Kapik BM. Fluvoxamine versus imipramine and placebo: a double-blind comparison in depressed patients. Int Clin Psychopharmacol. 1996;11(2):119-27. [pmid: 8803649].
15 Fabre LF, Abuzzahab FS, Amin M, Claghorn JL, Mendels J, Petrie WM, et al. Sertraline safety and efficacy in major depression: a double-blind fixed-dose comparison with placebo. Biol Psychiatry. 1995;38(9):592-602. [pmid: 8573661].
16 Fabre LF. A 6-week, double-blind trial of paroxetine, imipramine, and placebo in depressed outpatients. J Clin Psychiatry. 1992;53(Suppl):40-3. [pmid: 1531823].
17 Fabre LF, Putman HP 3rd. A fixed-dose clinical trial of fluoxetine in outpatients with major depression. J Clin Psychiatry. 1987;48(10):406-8. [pmid: 3312176].
18 Fava M, Alpert J, Nierenberg AA, Mischoulon D, Otto MW, Zajecka J, et al. A Double-blind, randomized trial of St John's wort, fluoxetine, and placebo in major depressive disorder. J Clin Psychopharmacol. 2005;25(5):441-7. [pmid: 16160619].
19 Fava M, Mulroy R, Alpert J, Nierenberg AA, Rosenbaum JF. Emergence of adverse events following discontinuation of treatment with extended-release venlafaxine. Am J Psychiatry. 1997;154(12):1760-2. [pmid: 9396960].
20 Feighner JP, Pambakian R, Fowler RC, Boyer WF, D'Amico MF. A comparison of nefazodone, imipramine, and placebo in patients with moderate to severe depression. Psychopharmacol Bull. 1989;25(2):219-21. [pmid: 2690165].
21 Feighner JP. A double-blind comparison of paroxetine, imipramine and placebo in depressed outpatients. Int Clin Psychopharmacol. 1992;6(Suppl 4):31-5. [pmid: 1431008].
22 Feighner JP, Boyer WF. Paroxetine in the treatment of depression: a comparison with imipramine and placebo. J Clin Psychiatry. 1992;53(Suppl):44-7. [pmid: 1531824].
23 Feighner JP, Cohn JB, Fabre LF Jr, Fieve RR, Mendels J, Shrivastava RK, et al. A study comparing paroxetine placebo and imipramine in depressed patients. J Affect Disord. 1993;28(2):71-9. [pmid: 8354771].
24 Feighner J, Targum SD, Bennett ME, Roberts DL, Kensler TT, D'Amico MF, et al. A double-blind, placebo-controlled trial of nefazodone in the treatment of patients hospitalized for major depression. J Clin Psychiatry. 1998;59(5):246-53. [pmid: 9632036].
25 Gilaberte I, Montejo AL, de la Gandara J, Perez-Sola V, Bernardo M, Massana J, et al. Fluoxetine in the prevention of depressive recurrences: a double-blind study. J Clin Psychopharmacol. 2001;21(4):417-24. [pmid: 11476126].
26 Lapierre YD, Browne M, Horn E, Oyewumi LK, Sarantidis D, Roberts N, et al. Treatment of major affective disorder with fluvoxamine. J Clin Psychiatry. 1987;48(2):65-8. [pmid: 3100510].
27 March JS, Kobak KA, Jefferson JW, Mazza J, Greist JH. A double-blind, placebo-controlled trial of fluvoxamine versus imipramine in outpatients with major depression. J Clin Psychiatry. 1990;51(5):200-2. [pmid: 2110560].
28 McGrath PJ, Stewart JW, Janal MN, Petkova E, Quitkin FM, Klein DF. A placebo-controlled study of fluoxetine versus imipramine in the acute treatment of atypical depression. Am J Psychiatry. 2000;157(3):344-50. [pmid: 10698808].
29 Montgomery SA, Rasmussen JG, Lyby K, Connor P, Tanghoj P. Dose response relationship of citalopram 20 mg, citalopram 40 mg and placebo in the treatment of moderate and severe depression. Int Clin Psychopharmacol. 1992;6(Suppl 5):65-70. [pmid: 1431024].
30 Muijen M, Roy D, Silverstone T, Mehmet A, Christie M. A comparative clinical trial of fluoxetine, mianserin and placebo in depressed outpatients. Acta Psychiatr Scand. 1988;78(3):384-90. [pmid: 3057817].
31 Petracca GM, Chemerinski E, Starkstein SE. A double-blind, placebo-controlled study of fluoxetine in depressed patients with Alzheimer's disease. Int Psychogeriatr. 2001;13(2):233-40. [pmid: 11495397].
32 Ravindran AV, Teehan MD, Bakish D, Yatham LN, O'Reilly R, Fernando ML, et al. The impact of sertraline, desipramine, and placebo on psychomotor functioning in depression. Hum Psychopharmacol. 1995;10(4):273-281.
33 Reimherr FW, Cunningham LA, Batey SR, Johnston JA, Ascher JA. A multicenter evaluation of the efficacy and safety of 150 and 300 mg/d sustained-release bupropion tablets versus placebo in depressed outpatients. Clin Ther. 1998;20(3):505-16. [pmid: 9663366].
34 Rickels K, Schweizer E, Clary C, Fox I, Weise C. Nefazodone and imipramine in major depression: a placebo-controlled trial. Br J Psychiatry. 1994;164(6):802-5. [pmid: 7952987].
35 Rickels K, Case WG. Trazodone in depressed outpatients. Am J Psychiatry. 1982;139(6):803-6. [pmid: 7044154].
36 Rickels K, Amsterdam J, Clary C, Fox I, Schweizer E, Weise C. The efficacy and safety of paroxetine compared with placebo in outpatients with major depression. J Clin Psychiatry. 1992;53(Suppl):30-2. [pmid: 1531820].
37 Roth D, Mattes J, Sheehan KH, Sheehan DV. A double-blind comparison of fluvoxamine, desipramine and placebo in outpatients with depression. Prog Neuropsychopharmacol Biol Psychiatry. 1990;14(6):929-39. [pmid: 2126144].
38 Roy-Byrne PP, Pages KP, Russo JE, Jaffe C, Blume AW, Kingsley E, et al. Nefazodone treatment of major depression in alcohol-dependent patients: a double-blind, placebo-controlled trial. J Clin Psychopharmacol. 2000;20(2):129-36. [pmid: 10770449].
39 Rudolph RL, Fabre LF, Feighner JP, Rickels K, Entsuah R, Derivan AT. A randomized, placebo-controlled, dose-response trial of venlafaxine hydrochloride in the treatment of major depression. J Clin Psychiatry. 1998;59(3):116-22. [pmid: 9541154].
40 Schweizer E, Weise C, Clary C, Fox I, Rickels K. Placebo-controlled trial of venlafaxine for the treatment of major depression. J Clin Psychopharmacol. 1991;11(4):233-6. [pmid: 1918421].
41 Smith WT, Glaudin V, Panagides J, Gilvary E. Mirtazapine vs. amitriptyline vs. placebo in the treatment of major depressive disorder. Psychopharmacol Bull. 1990;26(2):191-6. [pmid: 2236455].
42 Smith WT, Glaudin V. A placebo-controlled trial of paroxetine in the treatment of major depression. J Clin Psychiatry. 1992;53(Suppl):36-9. [pmid: 1531822].
43 Sramek JJ, Kashkin K, Jasinsky O, Kardatzke D, Kennedy S, Cutler NR. Placebo-controlled study of ABT-200 versus fluoxetine in the treatment of major depressive disorder. Depression. 1995;3(4):199-203.
44 Vartiainen H, Leinonen E. Double-blind study of mirtazapine and placebo in hospitalized patients with major depression. Eur Neuropsychopharmacol. 1994;4(2):145-50. [pmid: 7919944].
45 Wernicke JF, Dunlop SR, Dornseif BE, Zerbe RL. Fixed-dose fluoxetine therapy for depression. Psychopharmacol Bull. 1987;23(1):164-8. [pmid: 3496625].
46 Wernicke JF, Dunlop SR, Dornseif BE, Bosomworth JC, Humbert M. Low-dose fluoxetine therapy for depression. Psychopharmacol Bull. 1988;24(1):183-8. [pmid: 3290940].