# Placebo Studies Included in Meta-Regression

Study | Design | Sample Size | Intervention | Quality Rating
Addington et al., 2002 ^1^ | RCT | 48 | Sertraline vs. placebo | Fair
Brannan et al., 2005 ^2^ | RCT | 282 | Duloxetine vs. placebo | Fair
Burke et al., 2001 ^3^ | RCT | 70 | Fluoxetine vs. placebo | Fair
Claghorn et al., 1992 ^4^ | RCT | 71 | Paroxetine vs. placebo | Fair
Claghorn et al., 1992 ^5^ | RCT | 341 | Paroxetine vs. placebo | Fair
Cohn et al., 1996 ^6^ | RC | 81 | Nefazodone vs. placebo | Fair
Cunningham et al., 1997 ^7^ | RCT | 268 | Venlafaxine vs. placebo | Fair
Detke et al., 2002 ^8^ | RCT | 267 | Duloxetine vs. placebo | Fair
Detke et al., 2002 ^9^ | RCT | 236 | Duloxetine vs. placebo | Fair
Feighner et al., 1999 ^10^ | RCT | 650 | Citalopram vs. placebo | Fair
Fontaine et al., 1994 ^11^ | RCT | 135 | Nefazodone vs. placebo | Fair
Hypericum Depression Trial Study Group, 2002 ^12^ | RCT | 227 | Sertraline vs. placebo | Good
Khan et al., 1991 ^13^ | RCT | 93 | Venlafaxine vs. placebo | Fair
Kocsis et al., 1997 ^14^ , ^15^ | RCT | 416 | Sertraline vs. placebo | Fair
Lineberry et al., 1990 ^16^ | RCT | 224 | Bupropion vs. placebo | Fair
Lydiard et al., 1989 ^17^ | RCT | 36 | Fluvoxamine vs. placebo | Fair
Lydiard et al., 1997 ^18^ | RCT | 234 | Sertraline vs. placebo | Fair
Mendels et al., 1993 ^19^ | RCT | 312 | Venlafaxine vs. placebo | Fair
Mendels et al., 1995 ^20^ | RCT | 240 | Nefazodone vs. placebo | Fair
Olie et al., 1997 ^21^ | RCT | 258 | Sertraline vs. placebo | Fair
Reimherr et al., 1990 ^22^ | RCT | 290 | Sertraline vs. placebo | Fair
Reimherr et al., 1988 ^23^ | RCT | 77 | Sertraline vs. placebo | Fair
Rickels et al., 1989 ^24^ | RCT | 102 | Paroxetine vs. placebo | Fair
Shrivastava et al., 1992 ^25^ | RCT | 69 | Paroxetine vs. placebo | Fair
Strik et al., 2000 ^26^ | RCT | 54 | Fluoxetine vs. placebo | Fair
Thase et al., 1997 ^27^ | RCT | 197 | Venlafaxine vs. placebo | Fair
Tollefson et al., 1993 ^28^ | RCT | 534 | Fluoxetine vs. placebo | Fair
Tollefson et al., 1995 ^29^ , ^30^ | RCT | 671 | Fluoxetine vs. placebo | Fair
Trivedi et al., 2004 ^31^ | RCT | 459 | Paroxetine vs. placebo | Fair
Wade et al., 2002 ^32^ | RCT | 380 | Escitalopram vs. placebo | Fair
Walczak et al., 1996 ^33^ | RCT | 577 | Fluvoxamine vs. placebo | Fair

## References for Appendix F

1 Addington D, Addington J, Patten S, Remington G, Moamai J, Labelle A, et al. Double-blind, placebo-controlled comparison of the efficacy of sertraline as treatment for a major depressive episode in patients with remitted schizophrenia. J Clin Psychopharmacol. Feb. 2002;22(1):20-5. [pmid: 11799338].
2 Brannan SK, Mallinckrodt CH, Brown EB, Wohlreich MM, Watkin JG, Schatzberg AF. Duloxetine 60 mg once-daily in the treatment of painful physical symptoms in patients with major depressive disorder. J Psychiatr Res. Jan. 2005;39(1):43-53. [pmid: 15504423].
3 Burke WJ, McArthur-Miller DA. Exploring treatment alternatives: weekly dosing of fluoxetine for the continuation phase of major depressive disorder. J Clin Psychiatry. 2001;62(Suppl 22):38-42. [pmid: 11599647].
4 Claghorn J. A double-blind comparison of paroxetine and placebo in the treatment of depressed outpatients. Int Clin Psychopharmacol. Jun. 1992;6(Suppl 4):25-30. [pmid: 1431007].
5 Claghorn JL, Kiev A, Rickels K, Smith WT, Dunbar GC. Paroxetine versus placebo: a double-blind comparison in depressed patients. J Clin Psychiatry. Dec. 1992;53(12):434-8. [pmid: 1487471].
6 Cohn CK, Robinson DS, Roberts DL, Schwiderski UE, O'Brien K, Ieni JR. Responders to antidepressant drug treatment: a study comparing nefazodone, imipramine, and placebo in patients with major depression. J Clin Psychiatry. 1996;57(Suppl 2):15-8.
7 Cunningham LA. Once-daily venlafaxine extended release (XR) and venlafaxine immediate release (IR) in outpatients with major depression. Venlafaxine XR 208 Study Group. Ann Clin Psychiatry. Sep. 1997;9(3):157-64. [pmid: 9339881].
8 Detke MJ, Lu Y, Goldstein DJ, McNamara RK, Demitrack MA. Duloxetine 60 mg once daily dosing versus placebo in the acute treatment of major depression. J Psychiatr Res. Nov–Dec. 2002;36(6):383-90. [pmid: 12393307].
9 Detke MJ, Lu Y, Goldstein DJ, Hayes JR, Demitrack MA. Duloxetine, 60 mg once daily, for major depressive disorder: a randomized double-blind placebo-controlled trial. J Clin Psychiatry. Apr. 2002;63(4):308-15. [pmid: 12000204].
10 Feighner JP, Overo K. Multicenter, placebo-controlled, fixed-dose study of citalopram in moderate-to-severe depression. J Clin Psychiatry. Dec. 1999;60(12):824-30. [pmid: 10665628].
11 Fontaine R, Ontiveros A, Elie R, Kensler TT, Roberts DL, Kaplita S, et al. A double-blind comparison of nefazodone, imipramine, and placebo in major depression. J Clin Psychiatry. Jun. 1994;55(6):234-41. [pmid: 8071277].
12 Hypericum Depression Trial Study Group. Effect of Hypericum perforatum (St John's wort) in major depressive disorder: a randomized controlled trial. Jama. Apr 10. 2002;287(14):1807-14. [pmid: 11939866].
13 Khan A, Fabre LF, Rudolph R. Venlafaxine in depressed outpatients. Psychopharmacol Bull. 1991;27(2):141-4. [pmid: 1924660].
14 Kocsis JH, Zisook S, Davidson J, Shelton R, Yonkers K, Hellerstein DJ, et al. Double-blind comparison of sertraline, imipramine, and placebo in the treatment of dysthymia: psychosocial outcomes. Am J Psychiatry. Mar. 1997;154(3):390-5. [pmid: 9054788].
15 Thase ME, Fava M, Halbreich U, Kocsis JH, Koran L, Davidson J, et al. A placebo-controlled, randomized clinical trial comparing sertraline and imipramine for the treatment of dysthymia. Arch Gen Psychiatry. Sep. 1996;53(9):777-84. [pmid: 8792754].
16 Lineberry CG, Johnston JA, Raymond RN, Samara B, Feighner JP, Harto NE, et al. A fixed-dose (300 mg) efficacy study of bupropion and placebo in depressed outpatients. J Clin Psychiatry. May. 1990;51(5):194-9. [pmid: 2110559].
17 Lydiard RB, Laird LK, Morton WA Jr, Steele TE, Kellner C, Laraia MT, et al. Fluvoxamine, imipramine, and placebo in the treatment of depressed outpatients: effects on depression. Psychopharmacol Bull. 1989;25(1):68-70. [pmid: 2505304].
18 Lydiard RB, Stahl SM, Hertzman M, Harrison WM. A double-blind, placebo-controlled study comparing the effects of sertraline versus amitriptyline in the treatment of major depression. J Clin Psychiatry. Nov. 1997;58(11):484-91. [pmid: 9413414].
19 Mendels J, Johnston R, Mattes J, Riesenberg R. Efficacy and safety of b.i.d. doses of venlafaxine in a dose-response study. Psychopharmacol Bull. 1993;29(2):169-74. [pmid: 8290661].
20 Mendels J, Reimherr F, Marcus RN, Roberts DL, Francis RJ, Anton SF. A double-blind, placebo-controlled trial of two dose ranges of nefazodone in the treatment of depressed outpatients. J Clin Psychiatry. 1995;56(Suppl 6):30-6. [pmid: 7649971].
21 Olie JP, Gunn KP, Katz E. A double-blind placebo-controlled multicentre study of sertraline in the acute and continuation treatment of major depression. European Psychiatry. 1997;12(1):34-41. [pmid: 19698503].
22 Reimherr FW, Chouinard G, Cohn CK, Cole JO, Itil TM, LaPierre YD, et al. Antidepressant efficacy of sertraline: a double-blind, placebo- and amitriptyline-controlled, multicenter comparison study in outpatients with major depression. J Clin Psychiatry. Dec. 1990;51(Suppl B):18-27.
23 Reimherr FW, Byerley WF, Ward MF, Lebegue BJ, Wender PH. Sertraline, a selective inhibitor of serotonin uptake, for the treatment of outpatients with major depressive disorder. Psychopharmacol Bull. 1988;24(1):200-5. [pmid: 3290941].
24 Rickels K, Amsterdam J, Clary C, Fox I, Schweizer E, Weise C. A placebo-controlled, double-blind, clinical trial of paroxetine in depressed outpatients. Acta Psychiatr Scand Suppl. 1989;350:117-23. [pmid: 2530761].
25 Shrivastava RK, Shrivastava SH, Overweg N, Blumhardt CL. A double-blind comparison of paroxetine, imipramine, and placebo in major depression. J Clin Psychiatry. Feb. 1992;53(Suppl):48-51. [pmid: 1531825].
26 Strik JJ, Honig A, Lousberg R, Lousberg AH, Cheriex EC, Tuynman-Qua HG, et al. Efficacy and safety of fluoxetine in the treatment of patients with major depression after first myocardial infarction: findings from a double-blind, placebo-controlled trial. Psychosom Med. Nov–Dec. 2000;62(6):783-9. [pmid: 11138997].
27 Thase ME. Efficacy and tolerability of once-daily venlafaxine extended release (XR) in outpatients with major depression. The Venlafaxine XR 209 Study Group. J Clin Psychiatry. Sep. 1997;58(9):393-8. [pmid: 9378690].
28 Tollefson GD, Holman SL. Analysis of the Hamilton Depression Rating Scale factors from a double-blind, placebo-controlled trial of fluoxetine in geriatric major depression. Int Clin Psychopharmacol. Winter. 1993;8(4):253-9. [pmid: 8277144].
29 Tollefson GD, Bosomworth JC, Heiligenstein JH, Potvin JH, Holman S. A double-blind, placebo-controlled clinical trial of fluoxetine in geriatric patients with major depression. The Fluoxetine Collaborative Study Group. Int Psychogeriatr. Spring. 1995;7(1):89-104. [pmid: 7579025].
30 Heiligenstein JH, Ware JE Jr, Beusterien KM, Roback PJ, Andrejasich C, Tollefson GD. Acute effects of fluoxetine versus placebo on functional health and well-being in late-life depression. Int Psychogeriatr. 1995;7(Suppl):125-37. [pmid: 8580388].
31 Trivedi MH, Pigotti TA, Perera P, Dillingham KE, Carfagno ML, Pitts CD. Effectiveness of low doses of paroxetine controlled release in the treatment of major depressive disorder. J Clin Psychiatry. Oct. 2004;65(10):1356-64. [pmid: 15491239].
32 Wade A, Michael Lemming O, Bang Hedegaard K. Escitalopram 10 mg/day is effective and well tolerated in a placebo-controlled study in depression in primary care. Int Clin Psychopharmacol. May. 2002;17(3):95-102. [pmid: 11981349].
33 Walczak DD, Apter JT, Halikas JA, Borison RL, Carman JS, Post GL, et al. The oral dose-effect relationship for fluvoxamine: a fixed-dose comparison against placebo in depressed outpatients. Ann Clin Psychiatry. Sep. 1996;8(3):139-51. [pmid: 8899132].