# Characteristics of Studies with Poor Internal Validity

Study | Design | Sample Size | Intervention | Reason for Exclusion
Aguglia et al., 1993 ^1^ | RCT | 108 | Fluoxetine vs. sertraline | High LTF
Amini et al., 2005 ^2^ | RCT | 36 | Mirtazapine vs. fluoxetine | No ITT analysis
Clerc et al., 1994 ^3^ | RCT | 68 | Fluoxetine vs. venlafaxine | High differential attrition
Falk et al., 1989 ^4^ | RCT | 27 | Trazadone vs. fluoxetine | High LTF
Ferrando et al., 1997 ^5^ | RCT | 33 | Sertraline vs. paroxetine vs. fluoxetine | No ITT analysis
Flament et al., 2001 ^6^ | RCT | 286 | Sertraline vs. fluoxetine | No ITT analysis
Goldstein et al., 2004 ^7^ | RCT | 353 | Duloxetine vs. paroxetine | High LTF
Grigoriadis et al., 2003 ^8^ | Observational | 201 | Citalopram vs. fluoxetine | No ITT analysis (completer analysis only)
Gülseren et al., 2005 ^9^ | RCT | 25 | Fluoxetine vs. paroxetine | No ITT analysis; high rate of post-randomization exclusions
Mesters et al., 1993 ^10^ | RCT | 308 | Fluoxetine | No ITT analysis
Oslin et al., 2003 ^11^ | RCT | 52 | Sertraline vs. venlafaxine IR | High attrition
Roscoe et al., 2005 ^12^ | RCT | 94 | Paroxetine vs. placebo | No ITT analysis
Rosenbaum et al., 1998 ^13^ | Observational | 242 | Sertraline, fluoxetine, paroxetine | No ITT analysis
Schmitz et al., 2001 ^14^ | RCT | 68 | Fluoxetine vs. placebo | High LTF
Stahl et al., 2000 ^15^ | RCT | 323 | Citalopram vs. sertraline | High attrition
Thase et al., 2001 ^16^ | Pooled analysis | 2,045 | Venlafaxine vs. SSRIs | No systematic literature search
Tollefson et al., 1994 ^17^ and Beasley et al., 1991 ^18^ | Meta-analysis | 3,065 | Fluoxetine vs. placebo | No systematic literature search
Wade et al., 2003 ^19^ | RCT | 197 | Mirtzapine vs paroxetine | High LTF; high post-randomization exclusions
Wagner et al., 1998 ^20^ | RCT | 118 | Fluoxetine vs. placebo | No ITT analysis
Winokur et al., 2003 ^21^ | RCT | 21 | Fluoxetine vs. mirtazapine | No ITT analysis, small sample size
Zanardi et al., 1996 ^22^ | RCT | 46 | Paroxetine vs. sertraline | High LTF (41%)

ITT, intent to treat analysis; LTF, loss to followup; RCT, randomized controlled trial.

## References for Appendix E

1 Aguglia E, Casacchia M, Cassano GB, Faravelli C, Ferrari G, Giordano P, et al. Double-blind study of the efficacy and safety of sertraline versus fluoxetine in major depression. Int Clin Psychopharmacol. Fall. 1993;8(3):197-202. [pmid: 8263318].
2 Amini H, Aghayan S, Jalili SA, Akhondzadeh S, Yahyazadeh O, Pakravan-Nejad M. Comparison of mirtazapine and fluoxetine in the treatment of major depressive disorder: a double-blind, randomized trial. J Clin Pharm Ther. Apr. 2005;30(2):133-8. [pmid: 15811165].
3 Clerc GE, Ruimy P, Verdeau-Palles J. A double-blind comparison of venlafaxine and fluoxetine in patients hospitalized for major depression and melancholia. The Venlafaxine French Inpatient Study Group. Int Clin Psychopharmacol. Sep. 1994;9(3):139-43. [pmid: 7814822].
4 Falk WE, Rosenbaum JF, Otto MW, Zusky PM, Weilburg JB, Nixon RA. Fluoxetine versus trazodone in depressed geriatric patients. J Geriatr Psychiatry Neurol. Oct–Dec. 1989;2(4):208-14. [pmid: 2699556].
5 Ferrando SJ, Goldman JD, Charness WE. Selective serotonin reuptake inhibitor treatment of depression in symptomatic HIV infection and AIDS. Improvements in affective and somatic symptoms. Gen Hosp Psychiatry. Mar. 1997;19(2):89-97. [pmid: 9097063].
6 Flament MF, Lane R. Acute antidepressant response to fluoxetine and sertraline in psychiatric outpatients with psychomotor agitation. International Journal of Psychiatry in Clinical Practice. 2001;5(2):103-9.
7 Goldstein DJ, Lu Y, Detke MJ, Wiltse C, Mallinckrodt C, Demitrack MA. Duloxetine in the treatment of depression: a double-blind placebo-controlled comparison with paroxetine. J Clin Psychopharmacol. Aug. 2004;24(4):389-99. [pmid: 15232330].
8 Grigoriadis S, Kennedy SH, Bagby RM. A comparison of antidepressant response in younger and older women. J Clin Psychopharmacol. Aug. 2003;23(4):405-7. [pmid: 12920418].
9 Gulseren L, Gulseren S, Hekimsoy Z, Mete L. Comparison of fluoxetine and paroxetine in type II diabetes mellitus patients. Arch Med Res. Mar–Apr. 2005;36(2):159-65. [pmid: 15847950].
10 Mesters P, Cosyns P, Dejaiffe G, Fanielle J, Gilles C, Godderis J, et al. Assessment of quality of life in the treatment of major depressive disorder with fluoxetine, 20 mg, in ambulatory patients aged over 60 years. Int Clin Psychopharmacol. Winter. 1993;8(4):337-40. [pmid: 8277160].
11 Oslin DW, Ten Have TR, Streim JE, Datto CJ, Weintraub D, DiFilippo S, et al. Probing the safety of medications in the frail elderly: evidence from a randomized clinical trial of sertraline and venlafaxine in depressed nursing home residents. J Clin Psychiatry. Aug. 2003;64(8):875-82. [pmid: 12927001].
12 Roscoe JA, Morrow GR, Hickok JT, Mustian KM, Griggs JJ, Matteson SE, et al. Effect of paroxetine hydrochloride (Paxil) on fatigue and depression in breast cancer patients receiving chemotherapy. Breast Cancer Res Treat. Feb. 2005;89(3):243-9. [pmid: 15754122].
13 Rosenbaum JF, Fava M, Hoog SL, Ascroft RC, Krebs WB. Selective serotonin reuptake inhibitor discontinuation syndrome: a randomized clinical trial. Biol Psychiatry. Jul 15. 1998;44(2):77-87. [pmid: 9646889].
14 Schmitz JM, Averill P, Stotts AL, Moeller FG, Rhoades HM, Grabowski J. Fluoxetine treatment of cocaine-dependent patients with major depressive disorder. Drug Alcohol Depend. Aug 1. 2001;63(3):207-14. [pmid: 11418225].
15 Stahl SM. Placebo-controlled comparison of the selective serotonin reuptake inhibitors citalopram and sertraline. Biol Psychiatry. Nov 1. 2000;48(9):894-901. [pmid: 11074227].
16 Thase ME, Entsuah AR, Rudolph RL. Remission rates during treatment with venlafaxine or selective serotonin reuptake inhibitors. Br J Psychiatry. Mar. 2001;178:234-41. [pmid: 11230034].
17 Tollefson GD, Rampey AH Jr, Beasley CM Jr, Enas GG, Potvin JH. Absence of a relationship between adverse events and suicidality during pharmacotherapy for depression. J Clin Psychopharmacol. Jun. 1994;14(3):163-9. [pmid: 8027412].
18 Beasley CM Jr, Dornseif BE, Bosomworth JC, Sayler ME, Rampey AH Jr, Heiligenstein JH, et al. Fluoxetine and suicide: a meta-analysis of controlled trials of treatment for depression. Br Med J. Sep 21. 1991;303(6804):685-92. [pmid: 1833012]. [pmcid: 1670974].
19 Wade A, Crawford GM, Angus M, Wilson R, Hamilton L. A randomized, double-blind, 24-week study comparing the efficacy and tolerability of mirtazapine and paroxetine in depressed patients in primary care. Int Clin Psychopharmacol. May. 2003;18(3):133-41. [pmid: 12702891].
20 Wagner GJ, Maguen S, Rabkin JG. Ethnic differences in response to fluoxetine in a controlled trial with depressed HIV-positive patients. Psychiatr Serv. Feb. 1998;49(2):239-40. [pmid: 9575014].
21 Winokur A, DeMartinis NA 3rd, McNally DP, Gary EM, Cormier JL, Gary KA. Comparative effects of mirtazapine and fluoxetine on sleep physiology measures in patients with major depression and insomnia. J Clin Psychiatry. Oct. 2003;64(10):1224-9. [pmid: 14658972].
22 Zanardi R, Franchini L, Gasperini M, Perez J, Smeraldi E. Double-blind controlled trial of sertraline versus paroxetine in the treatment of delusional depression. Am J Psychiatry. Dec. 1996;153(12):1631-3. [pmid: 8942464].