# Evidence Tables

Evidence Table 1. KQ1: Efficacy or effectiveness of antidepressants for treating depressive symptoms

Study Characteristics | Research Objective | Inclusion/Exclusion | Baseline Characteristics | Health Outcome Results | Adverse Events (%) | Analysis and Quality Rating
| Duration
| Study Design
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Response | Constipation: | Overall attrition rate:
Aberg-Wistedt et al., 2000 | SER vs. PAR clinical outcomes after 6 mos of continuous therapy | - Adults 18 or older; - MDD diagnosis according to DSM-III or -IV | Overall: 43 | 8 wks- | D1: 5.7 | 35.4%
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | SER: 63% | D2: 16.4 | ITT analysis:
Sweden | 24 wks | - Pregnant; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Suicidal tendencies | Overall: 67.4 | PAR: 63% | Diarrhea: | Yes
Multicenter | Study design: | | Race (% white): | LOCF at 24 wks: | D1: 35.2 | Quality rating:
Funding: | RCT | | NR | SER: 72% | D2: 15.2 | Fair
Pfizer, Inc | Overall study N: | | Baseline (HAM-A): | PAR: 69% | Libido decrease (men):
| 353 | | NR | Response-Observed Cases at 24 wks: | D1: 12.7
| Intervention: | | Mean HAM-D score at baseline: | SER: 89% | D2: 3.8
| D1: Sertraline 50–150 mg/d | | NR | PAR: 89% | Libido decrease (women):
| D2: Paroxetine 20–40 mg/d | | | Remission | D1: 1.8
| | | | No sig diff at endpoint or at any other study point measures | D2: 8.8
| | | | 8 wks: | P ≤ 0.05
| | | | SER: 51.6%
| | | | PAR: 57.3%
| | | | 24 wks:
| | | | SER: 80.2%
| | | | PAR: 73.7%
| | | | No sig diff in CGI severity change score or improvement score
| | | | Relapse during wks 9 to 24:
| | | | PAR 8.6%
| | | | SER 1.9%
| | | | (P-value NR)
| | | | No sig diffs on BQOL
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No statistically sig diffs between treatments in any outcome measures (MADRS, CGI-S, CGI-I) | Overall adverse events: | Overall attrition rate:
Allard et al., 2004 | Compare efficacy and tolerability of VEN ER 75–150 mg/d with of CIT 10–20 mg/d in elderly patients with major depression according to DSM-IV criteria | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV | D1: 73.6 | Response rates were 93% in both groups at wk 22 | D1: 62 | 22.2%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 72.5 | MADRS remission rate was 19% for VEN and 23% for CIT (P = NR) | D2: 43 | ITT analysis
Sweden and Denmark | 22 wks | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Uncontrolled hypertension; - Sig cardiovascular or cerebrovascular disorders | Sex (% female): | Side effects were common during both treatments but differed in tremor being more common during CIT and nausea/vomiting during VEN treatment | Constipation: | Yes
Multicenter (12 sites) | Study design: | | D1: 73.6 | | D1: 6.6 | Quality rating:
Funding: | RCT | | D2: 72.7 | | D2: 2.7 | Fair
Wyeth | Overall study N: | | Race (% white): | | Dizziness:
| 150 | | NR | | D1: 34
| Intervention: | | Baseline HAM-A: | | D2: 30
| D1: Venlafaxine 37.5–150 mg/d | | NR | | Headache:
| D2: Citalopram 10–30 mg/d | | Baseline HAM-D: | | D1: 26
| | | NR | | D2: 31
| | | | | Nausea:
| | | | | D1: 30
| | | | | D2: 16
| | | | | Sweating (increase):
| | | | | D1: 2.6
| | | | | D2: 2.7
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig diffs between study groups in any outcome measures at endpoint. HAM-D responders: VEN: 87%, FLUO: 74% (P = NR); HAM-D Remitters: VEN: 51%, FLUO: 41% (P = NR) | Overall adverse events: | Overall attrition rate:
Alves et al., 1999 | Efficacy and tolerability of VEN and FLUO in MDD | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV | D1: 45.4 | VEN showed faster onset with sig diffs in various outcome measures during wks 1 to 4: mean decreases of HAM-D and MADRS scores were sig greater with VEN (P < 0.05) during wks 1–4 | D1: 56.4 | 21.8%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 42.3 | Suicide ideation scores at wk 6 were sig lower for VEN on MADRS and HAM-D scales | D2: 51.1 | ITT analysis:
Portugal | 12 wks | - Pregnant; - Lactating; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Suicidal tendencies | Sex (% female): | Remission (HAM-D < 8) at wk 3 was found in 30% of VEN treated patients and 11% of FLUO treated patients (P = 0.03) | Constipation: | Yes
Multicenter (3 sites) | Study design: | | D1: 92.5 | | D1: 7.7 | Quality rating:
Funding: | RCT | | D2: 91.5 | | D2: 2.1 | Fair
Wyeth-Ayerst International | Overall study N: | | Race (% white): | | Dizziness:
| 87 | | NR | | D1: 10.3
| Intervention: | | Baseline (HAM-A): | | D2: 2.1
| D1: Venlafaxine 75–150 mg/d | | NR | | Insomnia:
| D2: Fluoxetine 20–40 mg/d | | Mean HAM-D score at baseline: | | D1: 5.1
| | | NR | | D2: 10.6
| | | | | Nausea:
| | | | | D1: 33.3
| | | | | D2: 27.7
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Both groups showed sig improvements from baseline HAM-D, HAM-A and MADRS scores | Overall adverse events: | Overall attrition rate:
Baldwin et al., 1996 | To compare efficacy, safety, and tolerance of NEF and PAR in treatment of depressed outpatients | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18; - Rated at least moderately ill on CGI-S | D1: 38.3 | Proportion of CGI responders similar between treatment groups (NEF: 58% vs. PAR: 60%, P = NR) | D1: 84 | 27.2%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 37.9 | No sig diffs between treatment groups | D2: 78 | ITT analysis:
UK, Ireland, Multicenter (20 psychiatric outpatient clinics) | 8 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - ECT within last 6 mos; - Suicidal tendencies; - Failed to respond to at least 2 adequate courses of anti-depressant treatment; - History of allergy or hypersensitivity to TRA, etoperidone, m-CPP, or PAR | Sex (% female): | | Dizziness: | Yes
Funding: | Study design: | | D1: 60 | | D1: 17 | Quality rating:
Bristol Myers Squibb | RCT | | D2: 50 | | D2: 9 | Fair
| Overall study N: | | Race (% white): | | Headache:
| 206 | | NR | | D1: 35
| Intervention: | | Baseline (HAM-A): | | D2: 25
| D1: Nefazodone 200–600 mg/d | | D1: 19 | | Nausea:
| D2: Paroxetine 20–40 mg/d | | D2: 18.3 | | D1: 27
| | | Mean HAM-D score at baseline: | | D2: 30
| | | D1: 24.6 | | Somnolence (fatigue):
| | | D2: 24.8 | | D1: 16
| | | | | D2: 24
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig diffs between groups on HAM-D, MADRS, or CGI scales at 24 wks or endpoint | Overall adverse events: | Overall attrition rate:
Ballus et al., 2000 | To compare efficacy and tolerability of VEN and PAR in patients MDD and dsythmia | - Adults 18 to 70; - Minimum HAM-D score of 17 | D1: 44 | At wk 12, percent of patients with HAM-D score < 8 was sig greater in VEN group than PAR group (57% vs. 33%; P = 0.011) | D1: 68 | 32%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 45.1 | More patients exhibited a drug response (> 50% decrease in HAM-D) on VEN than PAR at wk 6 (P = 0.03) | D2: 79 | ITT analysis:
Spain | 24 wks | - Pregnant; - Lactating; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Suicidal tendencies | Sex (% female): | Response rates at wk 24: VEN: 59% vs. PAR: 49% | Constipation: | Yes
Multicenter | Study design: | | D1: 88 | | D1: 12.5 | Quality rating:
Funding: | RCT | | D2: 88 | | D2: 16.3 | Fair
NR | Overall study N: | | Race (% white): | | Diarrhea:
| 84 | | NR | | D1: 0
| Intervention: | | Baseline (HAM-A): | | D2: 9.3
| D1: Venlafaxine 75–150 mg/d | | NR | | Headache:
| D2: Paroxetine 20–40 mg/d | | Mean HAM-D score at baseline: | | D1: 17.5
| | | D1: 23.4 (4.1) | | D2: 39.5
| | | D2: 24.3 (4.7) | | Insomnia:
| | | | | D1: 7.5
| | | | | D2: 9.3
| | | | | Nausea:
| | | | | D1: 27.5
| | | | | D2: 9.3
| | | | | Sweating (increase):
| | | | | D1: 2.5
| | | | | D2: 7.0
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | ITT analysis: mean decrease in HSCL-D-20; PAR: 0.88 (0.08), placebo: 0.85 (0.09); behavior therapy: 0.79 (0.09), no sig diffs between arms | NR | Overall attrition rate:
Barrett et al., 2001 | To compare PAR vs. placebo vs. behavioral treatment for dysthymia and minor depression in primary care patients | - Adults 18 to 59; - Minimum HAM-D score of 10; - Dysthymia | D1: 45.2 | Remission by HAM-D-17 score < 6: PAR: 80%, placebo: 44.4%; behavior therapy: 56.8% (P = 0.008 for diff among all 3 arms) | | 20.7%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 42.6 | Minor depression: PAR 60.7%, placebo 65.6%; behavior therapy 65.5% (P = 0.906 for diff among all 3 arms) | | ITT analysis:
United States | 11 wks | - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Suicidal tendencies; - Current depression treatment | Sex (% female): | | | Yes
Multicenter, primary care clinics | Study design: | | D1: 57.5 | | | Quality rating:
Funding: | RCT | | D2: 66.7 | | | Fair
Hartford and MacArthur Foundation | Overall study N: | | Race (% white):
| 241 | | D1: 90
| Intervention: | | D2: 89
| D1: Paroxetine 10–40 mg/d, individually titrated | | Baseline (HAM-A):
| D2: placebo | | NR
| | | Mean HAM-D score at baseline:
| | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Response rates, n (%) (response = ≥ 50% decrease in HAM-D at endpoint) | Diarrhea: | Overall attrition rate:
Beasley et al., 1991 | To evaluate comparative safety and efficacy of FLUO and TRA in major depression and to evaluate incidence and temporal patterns of activation and sedation | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20; - DSM depression but 4 wks in duration | D1: 40.0 | FLUO = 40.5 (62.3%) | D1: 7.7 | 34.1%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 40.0 | TRA = 42.0 (68.9%) | D2: 3.3 | ITT analysis:
Country NR (appears to be United States) | Up to 6 wks (after a single-blind placebo run-in approximately 1 wk in duration) | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse | Sex (% female): | Remission rates (remission = HAM-D ≤ 7 at endpoint) | Dizziness: | Yes
Multicenter | Study design: | | D1: 64.6 | FLUO = 33.1(50.9%) | D1: 6.2 | Quality rating:
Funding: | RCT | | D2: 68.8 | TRA = 25.7(42.2%) | D2: 21.3 | Fair
Eli Lilly | Overall study N: | | Race (% white): | PGIS mean change at endpoint | Headache:
| 126 | | NROverall | FLUO 2.4 (1.2) vs. TRA 2.3 (1.2) (P = NR) | D1: 21.5
| Intervention: | | Baseline (HAM-A): | | D2: 27.9
| D1: Fluoxetine: 20–60 mg/d | | NR | | Insomnia:
| D2: Trazodone: 100–400 mg/d | | Mean HAM-D score at baseline: | | D1: 9.2
| | | D1: 23.4 (2.7) | | D2: 3.3
| | | D2: 24.3 (3.6) | | Nausea:
| | | | | D1: 27.7
| | | | | D2: 24.6
| | | | | Somnolence (fatigue):
| | | | | D1: 20.0
| | | | | D2: 45.9
| | | | | Sweating (increase):
| | | | | D1: 4.6
| | | | | D2: 0
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Onset of action faster in MIR group | Overall adverse events: | Overall attrition rate:
Behnke et al., 2003 | To compare onset of antidepressant efficacy of MIR and SER | - Adults 18 to 70; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18 | D1: 42 | At all assessments during first 2 wks mean change of HAM-D from baseline sig greater in MIR group than in SER group (P < 0.05) | D1: 64 | 20.8%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 41 | After wk 2 diff remained greater with MIR but lacked statistical significance | D2: 68 | ITT analysis:
Multinational | 8 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies; - Epilepsy; - History of seizure disorder or anti-convulsant treatment; - Current eating disorders diagnosis; - Previous postpartum depression or anxiety disorder diagnosis | Sex (% female): | HAM-D response rate showed similar findings | Diarrhea: | Yes
Multicenter | Study design: | | D1: 55.7 | HAM-D remission rate higher with MIR than SER at all assessments; diff reached statistical significance at day 14 | D1: 4 | Quality rating:
Funding: | RCT | | D2: 61.5 | Reduction in sleep disturbance was sig greater in MIR group at all assessments (P ≤0.01) | D2: 9.5 | Fair
NV Organon | Overall study N: | | Race (% white): | CGI scores not sig diff | Dizziness:
| 346 | | NR | | D1: 6.8
| Intervention: | | Baseline (HAM-A): | | D2: 10.1
| D1: Mirtazapine: 30–45 mg/d | | NR | | Headache:
| D2: Sertraline: 50–150 mg/d | | Mean HAM-D score at baseline: | | D1: 14.2
| | | NR | | D2: 18.3
| | | | | Insomnia:
| | | | | D1: 5.1
| | | | | D2: 8.9
| | | | | Nausea:
| | | | | D1: 7.4
| | | | | D2: 22.5
| | | | | Somnolence (fatigue):
| | | | | D1: 19.9
| | | | | D2: 7.7
| | | | | Sweating (increase):
| | | | | D1: 1.1
| | | | | D2: 5.3
| | | | | Libido decrease:
| | | | | D1: 1.1
| | | | | D2: 5.9
| | | | | P = 0.02
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Benkert-MIR and PAR equally effective in reducing mean | Overall adverse events: | Overall attrition rate:
Benkert et al., 2000 | Safety and efficacy of MIR and PAR in treatment of major depression | - Adults 18 to 70; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18 | D1: 47.2 | HAM-D-17 score (58.3% vs. 53.7%) | D1: 68.1 | 23%
Szegedi et al., 2003 | Duration of study: | Exclusion criteria: | D2: 47.3 | Szegedi-Improvement occurred in majority of analyzed patients within 2 wks, MIR: 72.7% PAR: 64.9% | D2: 63.4 | ITT analysis:
Country and setting: | 6 wks | - Pregnant; - Additional mental illnesses or organic mental disorder; - Suicidal tendencies | Sex (% female): | Early improvement was highly sensitive predictor of later stable response or stable remission for both drugs | Changes in weight (increase): | Yes
Germany | Study design: | | D1: 63 | At endpoint, 40.9% of MIR group and 34.1% of PAR group were considered HAM-D remitters (score ≤ 7) | D1: 14.8 | Quality rating:
Multicenter (50) | RCT | | D2: 65 | | D2: 3.7 | Fair
Funding: | Overall study N: | | Race (% white): | | Constipation:
Organon, GmBH, Munich, Germany | 275 | | NR | | D1: 7.4
| Intervention: | | Baseline (HAM-A): | | D2: 6.7
| D1: Mirtazapine: 15–45 mg/d (32.7) | | NR | | Dizziness:
| D2: Paroxetine: 20–40 mg/d (22.9) | | Mean HAM-D score at baseline: | | D1: 8.9
| | | D1: 22.4 (3.3) | | D2: 8.2
| | | D2: 22.4 (3.2) | | Headache:
| | | | | D1: 9.6
| | | | | D2: 10.4
| | | | | Nausea:
| | | | | D1: 4.4
| | | | | D2: 11.2
| | | | | Somnolence (fatigue):
| | | | | D1: 11.1 fatigue-8.9
| | | | | D2: 7.5 fatigue-8.2
| | | | | Sweating (increase):
| | | | | D1: 2.2
| | | | | D2: 7.5
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig diffs between treatment groups in any outcome measures at any point in time (changes in HAM-D, HAM-A, CGI, Raskin, Covi scales) | Overall adverse events: | Overall attrition rate:
Bennie et al., 1995 | To compare SER and FLUO in outpatients with depression | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18 | D1: 49.9 | Response rate (≥ 50% improvement on HAM-D): SER: 59%, FLUO: 51% | D1: 56 | 13.3%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 49.9 | | D2: 60 | ITT analysis:
UK | 6 wks | - Pregnant; - Lactating; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Suicidal tendencies | Sex (% female): | | Diarrhea: | Yes
Multicenter (20 centers) | Study design: | | D1: 57.7 | | D1: 4.9 | Quality rating:
Funding: | RCT | | D2: 64.6 | | D2: 3.5 | Fair
Pfizer, Inc | Overall study N: | | Race (% white): | | Dizziness:
| 286 | | NR | | D1: 1.4
| Intervention: | | Baseline (HAM-A): | | D2: 5.6
| D1: Sertraline: 50–100 mg/d | | NR | | Headache:
| D2: Fluoxetine: 20–40 mg/d | | Mean HAM-D score at baseline: | | D1: 14.1
| | | D1: 23.2 | | D2: 14.6
| | | D2: 23.4 | | Nausea:
| | | | | D1: 21.1
| | | | | D2: 25.0
| | | | | Somnolence (fatigue):
| | | | | D1: 4.2
| | | | | D2: 4.2
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Response (≥ 50% dec in MADRS): | Overall adverse events: | Overall attrition rate:
Bielski et al., 2004 | To compare ESC and VEN XR in depressed outpatients at highest recommended doses in United States | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV; - HAM-D24>20; - Normal physical exam, labs, and ECG (or any abnormality insignficant); - Using contraceptive | D1: 37.3 | ESC: 58.8% | D1: 68 | 30%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 37.5 | VEN: 48% | D2: 85 | ITT analysis:
United States | 8 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies; - Previous treatment with VEN or ESC; - Failure to respond to adequate trials of 2+ antidepressants | Sex (% female): | Response (≥ 50% decrease in HAM-D): | Headache: | Yes
Outpatient centers | Study design: | | D1: 69.4 | ESC: 61% | D1: 15.3 | Quality rating:
Funding: | RCT | | D2: 47.0 | VEN: 48% | D2: 14.0 | Fair
Forrest Laboratories, Inc | Overall study N: | | Race (% white): | Response (CGI-I ≤ 2): | Nausea:
| 198 | | D1: 77.6 | ESC: 65% | D1: 6.1
| Intervention: | | D2: 73.0 | VEN: 57% | D2: 24.0
| D1: Escitalopram: 20mg | | Baseline (HAM-A): | Remission (MADRS < 12): | Sexual dysfunction:
| D2: Venlafaxine: XR 225mg | | NR | ESC: 50.5 | D1: 6.7
| | | Mean HAM-D score at baseline: | VEN: 41.8 | D2: 22.6
| | | D1: 28.6 (4.1) | Remission (MADRS ≤ 10): | Somnolence (fatigue):
| | | D2: 27.4 (4.5) | ESC: 41.2 | D1: 9.2
| | | | VEN: 36.7 | D2: 17.0
| | | | Remission (HAM-D17 ≤ 7): | Sweating (increase):
| | | | ESC: 36.1 | D1: 5.1
| | | | VEN: 31.6 | D2: 11.0
| | | | LOCF results, mean change from baseline (SD):
| | | | ESC:
| | | | CES-D -15.1 (11.9)
| | | | Q-LES-Q 12.8 (11.4)
| | | | VEN:
| | | | CES-D -12.8 (12.7)
| | | | Q-LES-Q 9.9 (11.1)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig diffs in changes in MADRS, FSQ, CGI-I, and CGI-S scores between treatment groups | Overall adverse events: | Overall attrition rate:
Boyer et al., 1998 | To compare efficacy, tolerability, QOL outcomes, and costs of SER and FLUO in treatment of depression | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV | D1: 43.7 | No sig diffs in response rates (improvement of MADRS ≥ 50%) between treatment groups | D1: 51.3 | NR
Country and setting: | Duration of study: | Exclusion criteria: | D2: 43.0 | Day 120: | D2: 57.8 | ITT analysis:
France | 180 days | - Pregnant; - Lactating; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies; - History of serious allergy or AE reaction related to medicines | Sex (% female): | FLUO: 54.3% | | Yes
Multicenter, primary care settings (57 general practitioners) | Study design: | | D1: 79.1 | SER: 49% | | Quality rating:
Funding: | RCT | | D2: 77.6 | Day 180: | | Fair
NR | Overall study N: | | Race (% white): | FLUO: 42.6%
| 242 | | NR | SER: 47.4%
| Intervention: | | Baseline (HAM-A): | Sig improvements observed in both treatment groups in all dimensions of FSQ
| D1: Fluoxetine: 50–150 mg/d | | NR
| D2: Sertraline: 20–60 mg/d | | Mean HAM-D score at baseline:
| | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Responders (50 % improvement in MADRS from baseline): 50% vs. 51.2% vs. 45.6% for ESC 10 mg/d, ESC 20 mg/d and CIT 40 mg/d, placebo treatment (27.7%, P < 0.01) | Overall adverse events: | Overall attrition rate:
Burke et al., 2002 | To evaluate efficacy and tolerability of ESC in treatment of MDD | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of at least 2 on item 1 (depressed mood); - Depressive episode ≥ 4 wks; - MADRS ≥ 22 | D1: 40.1 | For QOL, diff in mean change from baseline for ESC vs. placebo treatment was 2.4 for 10 mg/d group (P = 0.04) and 4.8 for 20 mg/d group (P < 0.01) | D1: 70.5 | 24%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 40.7 | ESC 10 mg/d was equally effective as CIT 40 mg/d on majority of outcome measures (MADRS, HAM-D, CGI-I, CGI-S) | D2: 79 | ITT analysis:
United States | 8 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Illicit drug and alcohol abuse; - Suicidal tendencies; - Any DSM-IV Axis I disorder other than MDD; - Score at least 5 on item 10 of MADRS | D3: 39.6 | All treatment groups were sig more efficacious than placebo group | D3: 85.6 | Yes
Multicenter (35 centers) | Study design: | | D4: 40.0 | | D4: 86.4 | Quality rating:
Funding: | RCT | | Sex (% female): | | Diarrhea: | Fair
Forest Laboratories | Overall study N: | | D1: 60 | | D1: 7
| 491 | | D2: 70 | | D2: 10
| Intervention: | | D3: 68 | | D3: 14
| D1: placebo | | D4: 62 | | D4: 11
| D2: Escitalopram 10 mg/d | | Race (% white): | | Insomnia:
| D3: Escitalopram 20 mg/d | | NR | | D1: 3
| D4: Citalopram 40 mg/d | | Baseline (HAM-A): | | D2: 10
| | | NR | | D3: 14
| | | Mean HAM-D score at baseline: | | D4: 11
| | | D1: 25.8 (5.9) | | Nausea:
| | | D2: 24.3 (6.2) | | D1: 6
| | | D3: 25.8 (5.7) | | D2: 21
| | | D4: 25.9 (5.9) | | D3: 14
| | | | | D4: 22
| | | | | Sexual dysfunction:
| | | | | D1: 0
| | | | | D2: 9
| | | | | D3: 12
| | | | | D4: 4
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Both treatment groups showed sig improvements in cognitive performance on all test scales | Overall adverse events: | Overall attrition rate:
Cassano et al., 2002 | To assess efffects of PAR and FLUO on mood and cognitive function in depressed non-demented geriatric patients | - Adults 18 or older; - Minimum HAM-D score of 18; - ICD-10, mini mental state, Raskin, Covi Anxiety | D1: 75.6 | No sig diffs between treatment groups and cognitive performance except for Buschke test at wk 3 and 6 where PAR showed a sig greater improvement on a number of tests | D1: 27.6 | 39.3%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 74.9 | Both treatment groups sig improved HAM-D total scores but overall no diffs in HAM-D improvement between treatment groups | D2: 32.8 | ITT Analysis
Italy | 1 yr | - Additional mental illnesses or organic mental disorder not related to depression; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies | Sex (% female): | A Kaplan Meier analysis evaluating percentage of responders (HAM-D < 10) over time showed a sig diff in favor of PAR (P < 0.03) | Cardiovascular adverse events: | No another type of analysis was used (define): Observed case
Multicenter (38 centers) | Study design: | | D1: 61 | No sig diffs on CGI scores | D1: 6.5 | Quality rating:
Funding: | RCT | | D2: 50 | | D2: 7.5 | Fair
SmithKline, Beecham | Overall study N: | | Race (% white):
| 242 | | NR
| Intervention: | | Baseline (HAM-A):
| D1: Paroxetine: 20–40 mg/d | | NR
| D2: Fluoxetine: 20–60 mg/d | | Baseline HAM-D:
| | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No statistically sig diffs in response rates: (Observed cases at 12 wks) | Changes in weight (decrease): | Overall attrition rate:
Chouinard et al., 1999 | Antidepressant and anxiolytic efficacy of PAR and FLUO were compared | - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20 | D1: 40.6 | PAR: 85.7% | D1: 11.88 | 36%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 41.2 | FLUO: 88.4% | D2: 2.94 | ITT analysis:
Canada | 12 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - ECT within last 2 mos; - Suicidal tendencies | Sex (% female): | (LOCF endpoint) | Constipation: | Yes
Multicenter (8) | Study design: | | D1: 63.7 | PAR: 67.0% | D1: 17.65 | Quality rating:
Funding: | RCT | | D2: 59.4 | FLUO: 68.4% | D2: 3.96 | Fair
SmithKline, Beecham | Overall study N: | | Race (% white): | No statistically sig diffs in remission rates: (Observed cases at 12 wks) | Diarrhea:
| 203 | | D1: 96.5 | PAR: 77.8% | D1: 11.76
| Intervention: | | D2: 96.5 | FLUO: 81.2% | D2: 18.81
| D1: Paroxetine: 20–50 mg/d | | Baseline (HAM-A): | (LOCF endpoint) | Headache:
| D2: Fluoxetine: 20–80 mg/d | | NR | PAR: 58.0% | D1: 36.27
| | | Mean HAM-D score at baseline: | FLUO: 59.2% | D2: 36.63
| | | D1: 25.91 (0.46) | | Insomnia:
| | | D2: 25.45 (0.46) | | D1: 26.47
| | | | | D2: 22.77
| | | | | Nausea:
| | | | | D1: 37.25
| | | | | D2: 31.68
| | | | | Somnolence (fatigue):
| | | | | D1: 18.63
| | | | | D2: 16.83
| | | | | Sweating (increase):
| | | | | D1: 13.73
| | | | | D2: 5.94
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No diff in responders (> 50 decrease in HAM-D) FLUO: 57% vs BUP: 56% (P = NR), remitters (HAM-D < 8) FLUO: 40% vs. BUP: 47% (P = NR) | Diarrhea: | Overall attrition rate:
Coleman et al., 2001 | Comparison of BUP, FLUO and placebo on safety, efficacy, and sexual functioning in patients with recurrent major depression | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20; - Have sexual activity at least once every 2 wks; - Currently experiencing episode lasting 2 to 24 mos; - Currently in stable relationship | D1: 37.1 | More BUP SR remitters (47%) compared to placebo (32%) | D1: 12 | 34%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 36.6 | Orgasm dysfunction occurred sig more in FLUO patients compared with placebo or BUP SR patients (P < 0.001) | D2: 9 | ITT analysis:
United States | 8 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Illicit drug and alcohol abuse; - Suicidal tendencies | D3: 36.7 | At endpoint, more FLUO treated patients had sexual desire disorder than BUP SR treated patients (P < 0.05) | D3: 9 | Yes
Multicenter (15 centers) | Study design: | | Sex (% female): | More FLUO-treated patients dissatisfied with sexual function beginning at wk 1 (P < 0.05) | Headache: | Quality rating:
Funding: | RCT | | D1: 66 | | D1: 31 | Fair
Glaxo Wellcome | Overall study N: | | D2: 63 | | D2: 28
| 456 | | D3: 61 | | D3: 20
| Intervention: | | Race (% white): | | Insomnia:
| D1: Fluoxetine: 20–60 mg/d (26) | | D1: 82 | | D1: 15
| placebo | | D2: 83 | | D2: 21
| D2: Bupropion: 150–400 mg/d (319) | | D3: 82 | | D3: 10
| D3: placebo | | Baseline (HAM-A): | | Nausea:
| | | NR | | D1: 12
| | | Mean HAM-D score at baseline: | | D2: 21
| | | D1: 24.6 | | D3: 16
| | | D2: 24.5 | | Somnolence (fatigue):
| | | D3: 24.4 | | D1: 11
| | | | | D2: 3
| | | | | D3: 4
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig diff between BUP SR and SER groups. HAM-D responders: SER: 61% vs. BUP: 66% (P = NR) | Diarrhea: | Overall attrition rate:
Coleman et al., 1999 | To compare sexual functioning as well as safety and efficacy of BUP SR and SER | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18; - Stable relationship; - Have normal sexual functioning; - Sexual activity at least once every 2 wks | D1: 38.3 | CGI-I and CGI-S for BUP SR sig better than placebo but not better than SER | D1: 12 | 30%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 38.1 | SER not statistically better than placebo | D2: 18 | ITT analysis:
United States | 8 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Illicit drug and alcohol abuse; - Suicidal tendencies | D3: 38.5 | No diffs in HAM-A; sig fewer BUP SR patients had sexual desire disorder than SER patients (P < 0.05) | Headache: | Yes
Multicenter (9 centers) | Study design: | | Sex (% female): | Orgasm dysfunction occurred sig more in SER patients compared with placebo or BUP SR patients (P < 0.05) | D1: 34 | Quality rating:
Funding: | RCT | | D1: 54 | Diagnosed with at least one sexual dysfunction: SER: 39%, BUP SR: 13%, placebo: 17% | D2: 27 | Fair
Glaxo Wellcome Inc | Overall study N: | | D2: 56 | | Insomnia:
| 364 | | D3: 59 | | D1: 20
| Intervention: | | Race (% white): | | D2: 17
| D1: Sertraline: 50–200 mg/d | | D1: 92 | | Nausea:
| D2: Bupropion: 150–400 mg/d | | D2: 87 | | D1: 19
| D3: placebo | | D3: 88 | | D2: 23
| | | Baseline (HAM-A): | | Sexual dysfunction:
| | | NR | | D1: 39
| | | Mean HAM-D score at baseline: | | D2: 13
| | | D1: 34.5
| | | D2: 34.8
| | | D3: 34.0
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | MADRS responders: | Overall adverse events: | Overall attrition rate:
Colonna, et al., 2005 | Compare efficacy and safety of ESC to CIT in patients with moderate to severe MDD | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV; - MADRS ≥ 22 and <40 | D1: 46 | Wk 8: | D1: 62.9 | 17.7%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 46 | ESC: 63% vs. CIT 55% | D2: 72 | ITT analysis:
Mulitnational | 24 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications or ECT; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - History of severe drug allergy; - Had lack of response to more than 1 antidepressant treatment | Sex (% female): | Wk 24: | Changes in weight (increase): | Yes
Primary care centers | Study design: | | D1: 127 (73) | ESC 80%; CIT 78% | D1: 1.1 | Quality rating:
Funding: | RCT | | D2: 138 (76) | MADRS remitters: | D2: 6.6 | Fair
H Lundbeck A/S, Denmark | Overall study N: | | Race (% white): | Wk 8: | Headache:
| 357 | | NR | ESC 55% vs. CIT 45% | D1: 6.9
| Intervention: | | Baseline (HAM-A): | Wk 24: | D2: 8.8
| D1: Escitalopram: 10 mg/d | | NR | ESC 76%; CIT 71% | Nausea:
| D2: Citalopram: 20 mg/d | | Mean HAM-D score at baseline: | CGI-S mean change: | D1: 16
| | | NR | ESC -2.49 | D2: 9.9
| | | | CIT -2.24
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | HAM-D and MADRS scores decreased sig in both treatment groups (P < 0.05) | Overall adverse events: | Overall attrition rate:
Costa e Silvia, 1998 | Safety and efficacy of VEN versus FLUO in patients with depression in Latin America and Brazil | - Adults 18 to 60; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20 | D1: 40.5 | No sig diffs between treatment groups in primary efficacy measures (HAM-D, MADRS, CGI) | D1: 69.4 (whole study) | 12.3%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 39.8 | Global response (≥ 50% decrease in HAM-D or MADRS and CGI score of 1 or 2) was achieved by 86.8% in VEN group and 82% in FLUO group (P = 0.074) | D2: 65 (whole study) | ITT analysis:
South America | 8 wks | - Pregnant; - Lactating; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Investigational drug use within last 30 days; - Suicidal tendencies | Sex (% female): | Remission was observed in 60.2% of patients in each group | Dizziness: | Yes
Multicenter | Study design: | | D1: 80.1 | Patients who increased dose to VEN 150 mg and FLUO 40 mg after 3 wks sig more achieved CGI score of 1 in VEN group (P < 0.05) | D1: 8.3 | Quality rating:
Funding: | RCT | | D2: 77.4 | | D2: 3.2 | Fair
Wyeth-Ayerst International | Overall study N: | | Race (% white): | | Headache:
| 382 | | NR | | D1: 11.3
| Intervention: | | Baseline (HAM-A): | | D2: 7
| D1: Venlafaxine: 75–225 mg/d | | NR | | Insomnia:
| D2: Fluoxetine: 20–40 mg/d | | Mean HAM-D score at baseline: | | D1: 6.2
| | | NR | | D2: 8.1
| | | | | Nausea:
| | | | | D1: 28.9
| | | | | D2: 18.9
| | | | | Somnolence (fatigue):
| | | | | D1: 8.3
| | | | | D2: 1.6
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Mean HAM-D scores in both BUP and SER group were statistically better than placebo (P < 0.05) | Diarrhea: | Overall attrition rate:
Croft et al., 1999 | Comparison of efficacy and effects on sexual functioning of depressed patients using BUP, SER, or placebo | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18; - In stable relationship; - Have normal sexual functioning and sexual activity at least once every 2 wks; - Current depressive episode of 8 wks to 24 mos | D1: 36.0 | No sig diff in HAM-D scores between BUP and SER groups | D1: 26 | 32%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 35.9 | HAM-D responders: BUP: 66% vs. SER 68% | D2: 7 | ITT analysis:
United States | 8 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Illicit drug and alcohol abuse; - Suicidal tendencies | D3: 37.4 | CGI-S and CGI-I improvement compared to placebo but no diffs between drugs at any wk | D3: 11 | Yes
Multicenter (8 centers) | Study design: | | Sex (% female): | Orgasmic dysfunction occurred sig more in SER patients compared with placebo or BUP patients (P < 0.001) | Headache: | Quality rating:
Funding: | RCT | | D1: 50 | At day 56 no diff in overall satisfaction with sexual function between treatment groups | D1: 40 | Fair
Glaxo Wellcome | Overall study N: | | D2: 51 | | D2: 34
| 360 | | D3: 50 | | D3: 30
| Intervention: | | Race (% white): | | Insomnia:
| D1: Sertraline: 50–200 mg/d (mean = 121) | | D1: 87 | | D1: 18
| D2: Bupropion: 150–400 mg/d (mean = 293) | | D2: 86 | | D2: 13
| D3: placebo | | D3: 88 | | D3: 4
| | | Baseline (HAM-A): | | Nausea:
| | | NR | | D1: 31
| | | Mean HAM-D score at baseline: | | D2: 18
| | | NR | | D3: 10
| | | | | Somnolence (fatigue):
| | | | | D1: 17
| | | | | D2: 3
| | | | | D3: 6
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Results for HAM-D, MADRS, CGI available (results below) | Overall adverse events: | Overall attrition rate:
Cunningham et al., 1994 | To compare efficacy and safety of VEN, TRA, and placebo in outpatients with major depression | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20; - Must have major depression; - Symptoms for at least 1 mo prior to initial visit | NR | At wk 6, CGI response rates based on score of 1 or 2 were 72% for VEN group and 60% for TRA group (P ≤ 0.05) | D1: 18 | 33.78%
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | | D2: 23 | ITT analysis:
5 United States sites and 1 in Montreal, Canada | Short-term study: 6 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Investigational drug use within last 2 yrs; - ECT within last 14 days; - Suicidal tendencies; - No formal psychotherapy allowed during study period | NR | | D3: 4 | Yes
Multicenter | Long-term study: 1 yr | | Race (% white): | | Constipation: | Quality rating:
Funding: | Study design: | | NR | | D1: 22 | Fair
Wyeth-Ayerst Research | RCT | | Baseline (HAM-A): | | D2: 9
| Overall study N: | | NR | | D3: 4
| 225 | | Mean HAM-D score at baseline: | | Dizziness:
| Intervention: | | D1: 25.02 | | D1: 17
| D1: Venlafaxine: 156–160 mg/d | | D2: 24.66 | | D2: 36
| D2: Trazodone: 294–300 mg/d | | D3: 24.41 | | D3: 5
| D3: placebo | | | | Nausea:
| | | | | D1: 44
| | | | | D2: 19
| | | | | D3: 5
| | | | | Somnolence (fatigue):
| | | | | D1: 43
| | | | | D2: 61
| | | | | D3: 12
| | | | | Sweating (increase):
| | | | | D1: 12
| | | | | D2: 3
| | | | | D3: 1
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Both treatment groups resulted in sig improvements of symptoms | Headache: | Overall attrition rate:
Dalery and Honig 2003 | Comparison of efficacy and safety of FLUV and FLUO | - Adults 18 to 70; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of ≥ 17 | D1: 42.0 | No sig diffs between study groups in changes of HAM-D scores from baseline at any point in time. At end of study, 60% of both groups were considered responders | D1: 14 | 20.9%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 42.1 | After 2 wks of treatment, percentage of patients who responded was sig higher in FLUV group (29% vs. 16%; P ≥ 0.05), as was improvement of CGI-I scores (P ≥ 0.05). Sig diff not evident after wk 2 | D2: 13 | ITT analysis:
Europe | 6 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Suicidal tendencies | Sex (% female): | Improvement in sleep disturbance sub scores (HAM-D) was sig greater in FLUV group at wk 4 and at endpoint (P ≥ 0.05) | Nausea: | Yes
Multicenter | Study design: | | D1: 63.3 | | D1: 20 | Quality rating:
Funding: | RCT | | D2: 62.7 | | D2: 24 | Fair
Solvay Pharmaceuticals | Overall study N: | | Race (% white):
| 184 | | NR
| Intervention: | | Baseline (HAM-A):
| D1: Fluoxetine: 20 mg/d | | NR
| D2: Fluvoxamine: 100 mg/d | | Mean HAM-D score at baseline:
| | | D1: 22.3
| | | D2: 22.2
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | VEN group showed sig higher response rates in MADRS scores (75.0 vs. 49.3%, P = 0.001) and HAM-D scores (71.9% vs. 49.3%; P = 0.008) compared to FLUO group | Overall adverse events: | Overall attrition rate:
De Nayer et al., 2002 | To compare efficacy and safety of VEN and FLUO in patients with depression and anxiety | - Adults 18 to 70; - HAM-D score of 18–25; - Covi Anxiety scale >8 | D1: 41.6 | VEN treated patients also showed sig greater improvements in Covi Anxiety scores (P = 0.0004) and CGI scores (P = 0.016) | D1: 55.7 | 36.3%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 43.9 | At final visit 59.4% of VEN patients were in remission vs. 40.3 % of FLUO patients (P = 0.028) | D2: 67.1 | ITT analysis:
Belgium | 12 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Illicit drug and alcohol abuse; - Suicidal tendencies | Sex (% female): | Fewer VEN patients required dose increase (37.1% vs. 52.9%) | Headache: | Yes
Psychiatric practices (14) | Study design: | | D1: 71.2 | | D1: 8.6 | Quality rating:
Funding: | RCT | | D2: 65.8 | | D2: 11.4 | Fair
NR | Overall study N: | | Race (% white): | | Nausea:
| 146 | | NR | | D1: 28.6
| Intervention: | | Baseline (HAM-A): | | D2: 21.4
| D1: Venlafaxine: 75–150 mg/d | | NR
| D2: Fluoxetine: 20–40 mg/d | | Mean HAM-D score at baseline:
| | | D1: 23
| | | D2: 23.1
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Responders at wk 6 (i.e., reduction > 50% from baseline HAM-D21): | Overall adverse events: | Overall attrition rate:
De Wilde et al., 1993 | To compare efficacy and tolerability of PAR and FLUO | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score > 18 | D1: 44.6 | PAR: ~ 67% | D1: 43 | 21.2%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 44.1 | FLUO: ~ 62% | D2: 58 | ITT analysis:
Belgium | 6 wks | - Pregnant; - Lactating; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - ECT within last 3 mos; - Suicidal tendencies; - MAOIs or oral neuroleptics in last 14 days; - Depot neurolecptics in last 4 wks; - Lithium use | Sex (% female): | no sig diff | Changes in weight (increase): | NR
Multicenter | Study design: | | D1: 57 | HAM-A score reduction statistically sig diff for PAR vs. FLUO at wk 3; no sig diff at wks 4 or 6 | D1: 6 | Quality rating:
Funding: | RCT | | D2: 66 | At wk 4, 53% of PAR patients and 23% of FLUO patients showed CGI response of at least 2; diff is sig (P < 0.01) | D2: 4 | Fair
SmithKline, Beecham | Overall study N: | | Race (% white): | No sig diffs in CGI response noted at wks 1,3, or 6 | Nausea:
| 100 | | NR | | D1: 20
| Intervention: | | Baseline (HAM-A): | | D2: 20
| D1: Paroxetine: 20–40 mg/d | | NR | | Sweating (increase):
| D2: Fluoxetine: 20–60 mg/d | | Mean HAM-D score at baseline: | | D1: 2
| | | D1: 27 (4.8) | | D2: 14
| | | D2: 28.2 (5.3)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Response and remission rates did not differ sig among DUL 120 mg (71%; 52%), DUL 80 mg (65%; 46%) and PAR (74%; 44%) (P = NR) | Headache: | Overall attrition rate:
Detke et al., 2004 | To determine comparative efficacy and safety of DUL and PAR for treatment of MDD | - Adults 18 or older; - Met DSM-IV and MINI criteria for MDD; - CGI-S rating > 4; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 15 | D1: 43.1 | PGI scores were sig superior in patients receiving PAR than patients receiving 80 mg/d DUL (P < 0.05) | D1: 5.3 | 13.3%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 44.7 | | D2: 5.4 | ITT analysis:
United States | 8 wks | - Pregnant; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies | D3: 42.0 | | D3: 4.7 | Yes
Multicenter, university clinics | Study design: | | D4: 42.0 | | Nausea: | Quality rating:
Funding: | RCT | | Sex (% female): | | D1: 12.6 | Fair
Eli Lilly | Overall study N: | | D1: 70 | | D2: 5.4
| 367 | | D2: 70 | | D3: 11.6
| Intervention: | | D3: 58 | | Somnolence (fatigue):
| D1: Duloxetine 80 mg/d | | D4: 58 | | D1: 2.1
| D2: Duloxetine 120 mg/d | | Race (% white): | | D2: 7.5
| D3: Paroxetine: 20 mg/d | | D1: 95 | | D3: 5.8
| D4: placebo | | D2: 92 | | Sweating (increase):
| | | D3: 86 | | D1: 4.2
| | | D4: 86 | | D2: 8.6
| | | Baseline (HAM-A): | | D3: 5.8
| | | D1: 17.8
| | | D2: 18.0
| | | D3: 18.5
| | | D4: 17.9
| | | Mean HAM-D score at baseline:
| | | D1: 19.9 (3.6)
| | | D2: 20.2 (3.4)
| | | D3: 20.3 (4.1)
| | | D4: 19.9
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig diffs in response rates between treatment groups | NR | Overall attrition rate:
Devanand et al., 2005 | FLUO vs. placebo for treatment of dysthymia in patients over 60 | - Minimum HAM-D score of 8, max score 25; - Dysthymia; - Adults at least 60 yrs old; - CGI-s score ≥ 3 | D1: 69.0 | Responders: FLUO: 27.3% placebo: 19.6% (P = 0.4) | | 21%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 70.8 | No sig diffs in QOL measures on Q-LES-Q | | ITT analysis:
United States | 12 wks | - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Active suicidal ideation or plan; - MDD during current dysthymia episode; - Lack of response of current episode to prior trial of any SSRI; - Major neurologic disorder; - MMSE <24 | Sex (% female): | | | Yes
Outpatient clinic | Study design: | | D1: 32.6 | | | Quality rating:
Funding: | RCT | | D2: 40.9 | | | Good
NIMH | Overall study N: | | Race (% white):
| 90 | | D1: 86.4
| Intervention: | | D2: 89.1
| D1: Fluoxetine: 20–60 mg (individually titrated by protocol according to response) | | Baseline (HAM-A):
| D2: placebo | | NR
| | | Mean HAM-D score at baseline:
| | | D1: 15.3 (5.1)
| | | D2: 14.4 (3)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Response rate on HAM-D scale was sig higher in VEN group at wk 6: | Overall adverse events: | Overall attrition rate:
Dierick et al., 1996 | Comparison of efficacy and safety of VEN and FLUO in outpatients with major depression | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20 | D1: 43.7 | VEN: 72% | D1: 63 | 25%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 43.2 | FLUO: 60% | D2: 56 | ITT analysis:
France | 8 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Investigational drug use within last 14 days; - ECT within last 14 days; - Suicidal tendencies | Sex (% female): | (P = 0.023) | Headache: | Yes
NR | Study design: | | D1: 65 | In low dose comparison, no sig diffs between groups | D1: 10 | Quality rating:
Funding: | RCT | | D2: 64 | | D2: 12 | Fair
Wyeth-Ayerst International | Overall study N: | | Race (% white): | | Insomnia:
| 314 | | NR | | D1: 6
| Intervention: | | Baseline (HAM-A): | | D2: 4
| D1: Venlafaxine: 75–150 mg/d (mean daily dose for Venlafaxine: 109–122 mg/d from day 15 forward) | | NR | | Nausea:
| D2: Fluoxetine: 20 mg/d | | Mean HAM-D score at baseline: | | D1: 28
| | | D1: 27.0 (4.2) | | D2: 14
| | | D2: 26.6 (4.1) | | Somnolence (fatigue):
| | | | | D1: 5-Asthenia
| | | | | D2: 2-Asthenia
| | | | | Sweating (increase):
| | | | | D1: 6
| | | | | D2: 4
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Both treatment groups showed sig decreases in MADRS and CGI scores from baseline at all wks starting at wk 2 | Overall adverse events: | Overall attrition rate:
Ekselius et al., 1997 | To compare efficacy and safety of SER with CIT in patients with major depression | - Adults 18 to 70; - Diagnosed with MDD according to DSM-III or -IV; - MADRS at least 21 | D1: 47.0 | No sig diffs between treatment groups in any primary outcome variables at any time | D1: 90 D2: 85.5 | 22%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 47.2 | Response rates | Cardiovascular adverse events: | ITT analysis:
Sweden | 24 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies; - Previous treatment with SER or CIT w/o sig effect | Sex (% female): | Wk 12: SER: 69.5%; CIT: 68.0% | D1: 3 D2: 4 | Yes
Multicenter (general physicians) | Study design: | | D1: 71 | Wk 24: SER: 75.5%; CIT: 81.0% | Changes in weight (decrease): | Quality rating:
Funding: | RCT | | D2: 72.5 | Compliance: SER 90.3%, CIT 94.5% | D1: 4.5 D2: 9.5 | Good
Swedish Medical Research Council, Pfizer | Overall study N: | | Race (% white): | | Changes in weight (increase):
| 400 | | NR | | D1: 15 D2: 13
| Intervention: | | Baseline (HAM-A): | | Constipation:
| D1: Sertraline: 50–100 mg/d | | NR | | D1: 3 D2: 2
| D2: Citalopram: 20–60 mg/d | | Mean HAM-D score at baseline: | | Diarrhea:
| | | NR | | D1: 8.5 D2: 5.5
| | | | | Headache:
| | | | | D1: 9 D2: 6.5
| | | | | Insomnia:
| | | | | D1: 3.5 D2: 6
| | | | | Nausea:
| | | | | D1: 6 D2: 2.5
| | | | | Sexual dysfunction:
| | | | | D1: 4 D2: 6.5
| | | | | Somnolence (fatigue):
| | | | | D1: 5
| | | | | D2: 4.5
| | | | | Sweating (increase):
| | | | | D1: 13
| | | | | D2: 17
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No statistically sig diffs between FLUO, SER and PAR on all outcome measures of HAM-D | Diarrhea: | Overall attrition rate:
Fava et al., 2002 | To assess effects of SSRI treatment interruption after successful initial treatment (acute phase) of major depression. Acute treatment phase of study reported here | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 16; - MDD for at least 1 mo | D1: 42.1 | No statistically sig diffs between FLUO, SER and PAR in response rates (50% or greater reduction in total HAM-D score from baseine) or remission rates (HAM-D total score of 7 or less at endpoint); response rates: 64.8%, 72.9%, and 68.8% respectively; remission rates: 54.4%, 59.4%, and 57.0% respectively | D2: 26.0 | 27.1%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 44.0 | | Headache: | ITT analysis:
United States | 10 to 16 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies; - Presence of seizure disorder with seizure occurring in last yr; - History of allergy to study drugs; - Use of MAOIs within 2 wks of active therapy | D3: 42.5 | | D1: 25 | Yes
Multicenter (15 academic centers) | Study design: | | Sex (% female): | | D2: 28.1 | Quality rating:
Funding: | RCT | | D1: 63.0 | | D3: 21.9 | Fair
Eli Lilly Research | Overall study N: | | D2: 57.3 | | Insomnia:
| 284 | | D3: 58.3 | | D2: 26
| Intervention: | | Race (% white): | | D3: 20.8
| D1: Fluoxetine: 20–60 mg/d | | NR | | Nausea:
| D2: Sertraline: 50–200 mg/d | | Baseline (HAM-A): | | D2: 20.8
| D3: Paroxetine: 20–60 mg/d | | NR | | D3: 25.0
| | | Mean HAM-D score at baseline: | | Sexual dysfunction:
| | | D1: 23.1/18.4 | | D1: 11.8
| | | D2: 23.5/19.2 | | D2: 4.9
| | | D3: 22.6/18.9 | | D3: 20.0
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No statistically sig diffs between FLUO, SER and PAR in baseline-to-endpoint improvement in HAM-D total (overall P = 0.323) | Diarrhea: | Overall attrition rate:
Fava et al., 2000 | To compare tolerability and efficacy of FLUO, PAR and SER in treatment of anxious depression | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 16; - HAM-D-Anxiety/ Somatization Factor score of at least 7 | D1: 40.3 | No sig diffs in efficacy and tolerability of FLUO, SER, and PAR in treating anxious depression | D2: 25.6 | NR
Country and setting: | Duration of study: | Exclusion criteria: | D2: 44.1 | For all treatments, incidence of substantial emergence or any worsening was low with improvement at highest frequency for all HAM-D items | D3: 20.0 | ITT analysis:
United States | 10 to 16 wks (4 wks with additional wks determined by response on CGI) | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies; - Presence of seizure disorder with seizure in last yr; - History of allergy to study drugs; - Use of MAOIs within 2 wks of active therapy | D3: 41.4 | | Headache: | Yes
Multicenter (15 sites) | Study design: | | Sex (% female): | | D1: 22.9 | Quality rating:
Funding: | RCT | | D1: 65.7 | | D2: 25.6 | Fair
Eli Lilly Research | Overall study N: | | D2: 62.8 | | D3: 23.3
| 108 (drawn from larger sample of 284 MDD outpatients) | | D3: 66.7 | | Insomnia:
| Intervention: | | Race (% white): | | D1: 17.1
| D1: Fluoxetine: 20–60 mg/d | | NR | | D2: 23.3
| D2: Sertraline: 50–200 mg/d | | Baseline (HAM-A): | | D3: 23.3
| D3: Paroxetine: 20–60 mg/d | | NR | | Nausea:
| | | Mean HAM-D score at baseline: | | D3: 26.7
| | | D1: 23.6 (3.9) | | Somnolence (fatigue):
| | | D2: 23.9 (3.4) | | D1: 11.4
| | | D3: 25.0 (3.8) | | D2: 16.3
| | | | | D3: 10.0
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig diffs among 3 treatment groups in degree of depression and anxiety improvement | Cardiovascular adverse events: | Overall attrition rate:
Fava et al., 1998 | Efficacy and tolerability of PAR and FLUO | - Minimum HAM-D score of 18; - Raskin Depression score of > 8 (and larger in value than Covi anxiety scale) | D1: 41.3 | | D1: 5 | 28%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 41.3 | | D2: 11 | ITT analysis:
United States | 12 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - ECT within last 3 mos; - Suicidal tendencies | D3: 41.3 | | D3: 11 | Yes
Multicenter | Study design: | | Sex (% female): | | Insomnia: | Quality rating:
(5 sites) | RCT | | D1: 50 | | D1: 29 | Fair
Funding: | Overall study N: | | D2: 50 | | D2: 20
SmithKline, Beecham | 128 | | D3: 50 | | D3: 11
| Intervention: | | Race (% white): | | Sexual dysfunction:
| D1: Paroxetine: 20–50 mg/d (initial dosage of 20 mg/d could be increased wkly by 10 mg/d up to 50 mg/d) | | NR | | D1: 25
| D2: Fluoxetine: 20–80 mg/d (initial dosage of 20 mg/d could be increased wkly by 20 mg/d up to 80 mg/d) | | Baseline (HAM-A): | | D2: 7
| D3: placebo | | NR | | D3: 0
| | | Mean HAM-D score at baseline:
| | | D1: 23.1 (3.4)
| | | D2: 23.9 (3.8)
| | | D3: 23.7 (12.2)
Author: | Research objective: | Inclusion criteria: | Mean age (years): | Mean change from baseline (P-values vs. placebo) | Diarrhea: | Overall attrition rate:
FDA Center for Drug Evaluation & Research (Unpublished study SCT-MD-02), 2000 | To assess efficacy and safety of ESC vs. CIT and placebo | - Adults 18 to 80; - MDD diagnosis according to DSM III or IV; - MADRS ≥ 22 | D1: 41.4 | HAM-D | D1: 9.6 | 20%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 42.0 | D1: 10.4 (P = 0.506) | D2: 14.6 | ITT analysis:
US | 8 weeks | - Pregnant; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Suicidal tendencies | D3: 42.3 | D2: 11.4 (P = 0.068) | D3: 8.7 | Yes
Multicenter (22) | Study design: | | Sex (% female): | D3: 9.6 | Fatigue: | Quality rating:
Funding: | RCT | | D1: 52 | MADRS | D1: 12.0 | Fair
Forest Laboratories, Inc. | Overall study N: | | D2: 48 | D1: 12.9 (P = 0.251) | D2: 4.1
| 375 | | D3: 58 | D2: 13.0 (P = 0.151) | D3: 2.4
| Intervention: | | Race (% white): | D3: 11.2 | Headache:
| D1: Escitalopram: 10–20 mg/d | | D1: 82 | MADRS response rate (≥ 50% decrease from baseline): | D1: 21.6
| D2: Citalopram: 20–40 mg/d | | D2: 86 | D1: 46 | D2: 22.8
| D3: placebo | | D3: 82 | D2: 51 | D3: 18.1
| | | Baseline (HAM-A): | D3: 41 | Insomnia:
| | | NR | (P = NR) | D1: 13.6
| | | Mean HAM-D score at baseline: | | D2: 11.4
| | | D1: 24.8 | | D3: 6.3
| | | D2: 25.0 | | Nausea:
| | | D3: 25.0 | | D1: 16.0
| | | Mean MADRS score at baseline: | | D2: 14.6
| | | D1: 28.7 | | D3: 12.6
| | | D2: 28.3 | | Somnolence:
| | | D3: 28.8 | | D1: 10.4
| | | | | D2: 7.3
| | | | | D3: 4.7
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No statistically sig diffs between treatment groups | Overall adverse events: | Overall attrition rate:
Feiger et al., 1996 | To compare safety and efficacy of NEF with SER in outpatients with moderate to severe depression | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20 | D1: 43 | Response rates: | D1: 96 | 24.4%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 44.5 | NEF: 59% | D2: 95 | ITT analysis:
Europe | 6 wks | - Pregnant; - Lactating; - Illicit drug and alcohol abuse; - Investigational drug use; - Suicidal tendencies | Sex (% female): | SER: 57% | Diarrhea: | Yes
Multicenter (4) | Study design: | | D1: 48 | Difficulty with ejaculation: | D1: 9 | Quality rating:
Funding: | RCT | | D2: 55 | SER: had sig AEs on sexual function | D2: 20 | Fair
Bristol Myers Squibb | Overall study N: | | Race (% white): | NEF: no sig AE on sexual function | Dizziness:
| 160 | | D1: 90 | P < 0.01 | D1: 32
| Intervention: | | D2: 79 | | D2: 7
| D1: Nefazodone: 100–600 mg/d | | Baseline (HAM-A): | | Headache:
| D2: Sertraline: 50–200 mg/d | | NR | | D1: 55
| | | Mean HAM-D score at baseline: | | D2: 55
| | | D1: 23.5 | | Insomnia:
| | | D2: 23.5 | | D1: 21
| | | | | D2: 23
| | | | | Nausea:
| | | | | D1: 32
| | | | | D2: 27
| | | | | Somnolence (fatigue):
| | | | | D1: asthenia- 18 somnolence- 23
| | | | | D2: asthenia- 24 somnolence- 21
| | | | | Sweating (increase):
| | | | | D1: 6
| | | | | D2: 17
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig diffs in changes of HAM-D score between treatment groups | NR | Overall attrition rate:
Feighner et al., 1991 | Efficay and safety of BUP and FLUO in depressed outpatients | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20 | D1: 40.9 | No sig diffs in percentage of clinical responders (more than 50% HAM-D scale reduction) between treatment groups: | | 7.3%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 42.9 | BUP: 62.7% | | ITT analysis:
United States | 6 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies | Sex (% female): | FLUO: 58.3% | | Yes
Multicenter (2) | Study design: | | D1: 62 | No sig diffs in changes of CGI-S, CGI-I, and HAM-A scores | | Quality rating:
Funding: | RCT | | D2: 61 | | | Fair
Burroughs Wellcome Co | Overall study N: | | Race (% white):
| 123 | | NR
| Intervention: | | Baseline (HAM-A):
| D1: Bupropion: 225–450 mg/d (382) | | NR
| D2: Fluoxetine: 20–80 mg/d (38) | | Mean HAM-D score at baseline:
| | | D1: 25.3
| | | D2: 26.1
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig diffs in mean total scores for HAM-D, CGI-I or CGI-S, HAM-A, and MADRS at endpoint or any other study point measures | Diarrhea: | Overall attrition rate:
Gagiano, 1993 | Safety and efficacy comparison of PAR and FLUO in patients with MDD | - Adults 18 to 65; - MDD diagnosis according to DSM-III or -IV; - Minimum HAM-D score of 18 | D1: 39.6 | No sig diff in patients responding (at least 50% improvement of HAM-D) between treatment groups (PAR: 70%, FLUO: 63%; no P value reported) | D1: 13.0 | 21%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 37.8 | No sig diffs in groups on HAM-D (item 3) measure for suicidal ideation, both groups showed reduction over six-wk period | D2: 13.0 | ITT analysis:
South Africa | 6 wks | - Pregnant; - Lactating; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - ECT within last 3 mos; - Suicidal tendencies | Sex (% female): | | Headache: | Yes
University hospital | Study design: | | D1: 80 | | D1: 47.0 | Quality rating:
Funding: | RCT | | D2: 80 | | D2: 53.0 | Fair
NR | Overall study N: | | Race (% white): | | Insomnia:
| 90 | | NR | | D1: 20.0
| Intervention: | | Baseline (HAM-A): | | D2: 11.0
| D1: Fluoxetine: 20–60 mg/d | | NR | | Nausea:
| D2: Paroxetine: 20–40 mg/d | | Mean HAM-D score at baseline: | | D1: 33.0
| | | NR | | D2: 36.0
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No statistically sig diffs between DUL and FLUO in response (49% vs. 45%) and remission (43% vs. 30%) | Constipation: | Overall Attrition Rate: 35%
Goldstein et al., 2002 | Evaluation of DUL for efficacy and safety versus placebo and FLUO in patients with major depression | - Adults 19 to 65 yrs; - Minimum HAM-D score of 15; - Mini confirmation of MDD; - Diagnosed with MDD according to DSM-III or -IV | D1: 41.4 | Change from baseline on HAM-D subscale of anxiety was DUL (-2.92) which showed a statistically better result in comparison to placebo (-1.95) P = 0.027 and FLUO (-1.82) (P = 0.041) | D1: 5.7 | ITT analysis
Country and setting: | Duration of study: | Exclusion criteria: | D2: 42.3 | Change from baseline on HAM-A subscale of anxiety was DUL (-6.87) in comparison to placebo (-5.05) P = 0.077 and FLUO (-6.97) (P = NR) | D2: 11.4 | Yes
United States | 8 wks | - Illicit drug and alcohol abuse; - Failed 2 or more courses of antidepressant therapy during current episode; - Additional mental illnesses or organic mental disorder | D3: 39.7 | | D3: 15.2 | Quality rating:
Multicenter (8 sites) | Study design: | | Sex (% female): | | Diarrhea: | Fair
Funding: | RCT | | D1: 68.6 | | D1: 10.0
Eli Lilly and company | Overall study N: | | D2: 62.9 | | D2: 14.3
| 173 | | D3: 57.6 | | D3: 30.3
| Intervention: | | Race (% white): | | Dizziness:
| D1: Placebo | | D1: 81.4 | | D1: 7.1
| D2: Duloxetine: 40–120 mg/d | | D2: 88.6 | | D2: 15.7
| D3: Fluoxetine: 20 mg/d | | D3: 72.7 | | D3: 6.1
| | | Baseline (HAM-A): | | Headache:
| | | D1: 15.4 (4.8) | | D1: 31.4
| | | D2: 14.2 (4.2) | | D2: 20.0
| | | D3: 15.5 (5.8) | | D3: 33.3
| | | Mean HAM-D score at baseline: | | Insomnia:
| | | D1: 19.2 (5.0) | | D1: 7.1
| | | D2: 18.4 (4.0) | | D2: 20.0
| | | D3: 17.9 (4.3) | | D3: 9.1
| | | | | Nausea:
| | | | | D1: 12.9
| | | | | D2: 12.9
| | | | | D3: 18.2
| | | | | Somnolence (fatigue):
| | | | | D1: 10.0
| | | | | D2: 18.6
| | | | | D3: 21.2
| | | | | Sweating (increase):
| | | | | D1: 8.6
| | | | | D2: 18.6
| | | | | D3: 9.1
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Although not statistically sig, at all assessment times higher percentages of patients treated with MIR were classified as responders (≥ 50% reduction) on HAM-D (at endpoint, 62% vs. 52%) and MADRS (at endpoint: 64% vs. 58%). Likewise were percentages of remitters (HAM-D score ≤ 7; MADRS score ≤ 12) also higher in MIR group | Overall adverse events: | Overall attrition rate:
Guelfi et al., 2001 | To compare antidepressant efficacy and tolerability of MIR and VEN in treatment of hospitalized patients with DSM-IV diagnosis of severe depressive episode with melancholic features | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 25; - DSM-IV melancholic features | D1: 45.9 | Q-LES-Q- estimate of treatment diff (MIR minus VEN) = -3.0, 95% CI: -11.0, 4.9 (P = 0.46) | D1: 74.4 | 29.3%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 44.5 | QLDS- estimate of treatment diff (MIR minus VEN) = 2.6, 95% CI: -2.1, 7.3 (P = 0.289) | D2: 65.8 | ITT analysis:
France, Denmark, Belgium, The Netherlands | 8 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Investigational drug use; - ECT within last 3 mos; - Suicidal tendencies; - Current episode > 12 mos; - > 2 previous episodes of major depression that did not respond to AD therapy | Sex (% female): | | Changes in weight (increase): | Yes
Multicenter (33) | Study design: | | D1: 62.8 | | D1: 10.3 | Quality rating:
Funding: | RCT | | D2: 68.4 | | D2: 5.1 | Fair
N.V. Organon, Oss, The Netherlands | Overall study N: | | Race (% white): | | Constipation:
| 157 | | NR | | D1: 3.8
| Intervention: | | Baseline (HAM-A): | | D2: 15.2
| D1: Mirtazapine: 49.5 mg | | NR | | Headache:
| D2: Venlafaxine: 255.0 mg | | Mean HAM-D score at baseline: | | D1: 7.7
| | | D1: 29.5 (3.0) | | D2: 11.4
| | | D2: 29.2 (2.9) | | Nausea:
| | | | | D1: 6.4
| | | | | D2: 10.1
| | | | | Somnolence (fatigue):
| | | | | D1: 7.7
| | | | | D2: 5.1
| | | | | Sweating (increase):
| | | | | D1: 0
| | | | | D2: 19.0
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No diff in mean HAM-D-17 scores after 6 wks | Diarrhea: | Overall attrition rate:
Haffmans et al., 1996 | To evaluate and compare efficacy and tolerability of CIT and FLUV; to determine diff in incidence of gastrointestinal side-effects based on UKU side effects scale | - Adults 18 to 70; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 16; - Reasonable knowledge of Dutch language | D1: 44.2 | Complete Response (HAM-D17) < 7: | higher incidence for FLUV: +13% (P = 0.026) | 23%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 40.2 | CIT: 14% | Nausea: | ITT analysis
The Netherlands | 6 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder not related to depression; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Treated with MAOIs or FLUO within last 3 wks | Sex (% female): | FLUV: 8% | higher incidence for FLUV: +16% (P = 0.017) | Yes
Multicenter | Study design: | | D1: 58 | no sig diff | | Quality rating:
Funding: | RCT | | D2: 60 | Mean % reduction in score at wk 6: | | Fair
Lundbeck | Overall study N: | | Race (% white): | CIT: 33%
| 217 | | NR | FLUV: 26%
| Intervention: | | Baseline (HAM-A): | Responders (reduction in score from baseline > 50%): CIT: 30.5%,
| D1: Citalopram: 20–40 mg/d | | NR | FLUV: 28.4%
| D2: Fluvoxamine: 100–200 mg/d | | Baseline HAM-D:
| | | D1: 24.7
| | | D2: 24.5
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | On 21-item HAM-D, diffs between MIR and placebo were statistically sig at 2, 3, 4, and 6 wks. Using MADRS, statistically sig diffs were found between both active compounds and placebo at wks 2 and 3. MIR and TRA were associated with sig higher frequencies of dizziness and blurred vision as compared to placebo | Cardiovascular adverse events: | Overall attrition rate:
Halikas, 1995 | To assess clinical efficacy and safety of “Org 3770” (MIR) and TRA in treatment of elderly outpatients with moderate to severe depression | - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18; - Age 55+; - Able to complete Zung Self Rating Depression Scale (SDS); - Chloral hydrate (500 mg) at bedtime was permitted | D1: 63 | At wk 6, 51% of MIR and 41% of TRA treated patients were HAM-D responders (not statistically sig) | D1: 2% Tachycardia; 4% Palpitations | 27%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 61 | | D2: 12% Tachycardia; 12% Palpitations | ITT analysis:
United States | 6 wks | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - ECT within last 3 mos of baseline; - Suicidal tendencies; - Rapid placebo responders (reduction of 20%+ in total HAM-D score) | D3: 62 | | D3: 2% Tachycardia; 2% Palpitations | Yes
University | Study design: | | Sex (% female): | | Constipation: | Quality rating:
Funding: | RCT | | D1: 42.9 | | D1: 18 | Fair
Organon, Inc | Overall study N: | | D2: 60.4 | | D2: 24
| 150 | | D3: 59.2 | | D3: 16
| Intervention: | | Race (% white): | | Dizziness:
| D1: Mirtazapine: 5–35 mg | | NR | | D1: 22
| D2: Trazodone: 40–280 mg | | Baseline (HAM-A): | | D2: 27
| D3: placebo | | NR | | D3: 8
| | | Mean HAM-D score at baseline: | | Headache:
| | | D1: 24.6 | | D1: 14
| | | D2: 24.6 | | D2: 20
| | | D3: 23.5 | | D3: 20
| | | | | Nausea:
| | | | | D1: 10
| | | | | D2: 14
| | | | | D3: 14
| | | | | Somnolence (fatigue):
| | | | | D1: 54
| | | | | D2: 55
| | | | | D3: 22
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | NEF sig increased objective sleep efficiency and total sleep time. Total sleep time for PAR: 388; NEF: 396 (P = 0.05) | Constipation: | Overall attrition rate:
Hicks et al., 2002 | Compare NEF and PAR for treatment of depression and sleep in patients with mod-severe MDD | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18 | D1: 42.75 | PAR decreased sleep efficiency in early treatment and some disruption remained at wk 8 | D1: 5 | 20%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 42.95 | % Remission for | D2: 15 | ITT analysis:
UK | 8 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Investigational drug use within last 30 days; - Shift workers; - Current sleep disorders | Sex (% female): | NEF = 23 | Dizziness: | Yes
Outpatient clinic | Study design: | | D1: 60 | PAR = 6% | D1: 25 | Quality rating:
Funding: | RCT | | D2: 55 | (P = 0.1) | D2: 15 | Fair
Bristol Myers Squibb | Overall study N: | | Race (% white): | | Headache:
| 40 | | NR | | D1: 50
| Intervention: | | Baseline (HAM-A): | | D2: 50
| D1: Nefazodone: 400–600 mg/d | | NR | | Sexual dysfunction:
| D2: Paroxetine: 20–40 mg/d | | Mean HAM-D score at baseline: | | D1: 0
| | | D1: 22 | | D2: 20
| | | D2: 22.5 | | Somnolence (fatigue):
| | | | | D1: 40
| | | | | D2: 55
| | | | | Suicidality:
| | | | | D1: 0
| | | | | D2: 5
| | | | | Sweating (increase):
| | | | | D1: 0
| | | | | D2: 35
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig diffs in HAM-D responders (MIR: 58% vs. FLUO: 51%) | Overall adverse events: | Overall attrition rate:
Hong et al., 2003 | To compare efficacy and tolerability of MIR and FLUO treatment in sample population of Chinese patients with moderate-to-severe depression | - Adults 18 to 75; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 15; - Current episode between 1 wk and 1 yr | D1: 47.2 | At day 42, diff in HAM-D remitters (MIR: 35% vs. FLUO: 27%, P = NR) | D1: 71.2 | 39.4%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 47.2 | MIR had more remitters and responders at all time points; however, no statistical significance in diffs was reached | D2: 57.6 | ITT analysis:
Taiwan | 6 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies; - History of seizures; - Epilepsy | Sex (% female): | Based on LOCF approach, approximately 50% of subjects in both treatment groups were CGI responders by endpoint | Changes in weight (decrease): | Yes
Multicenter | Study design: | | D1: 62 | Weight increase ≥ 7% in 8 MIR patients | D2: 3 | Quality rating:
Funding: | RCT | | D2: 64 | Weight decrease ≥ 7% in 2 MIR patients and 2 FLUO patients | Changes in weight (increase): | Fair
NV Organon, Oss, The Netherlands | Overall study N: | | Race (% white): | Mean body weight increase MIR + 1.84 kg | D1: 13.6
| 133 | | D1: 0 | FLUO -0.54 kg | Constipation:
| Intervention: | | D2: 0 | P = 0.0001 | D1: 15.2
| D1: Mirtazapine: 15 mg-45 mg/d | | Baseline (HAM-A): | | D2: 9.1
| D2: Fluoxetine: 20 mg-40 mg/d | | NR | | Dizziness:
| | | Mean HAM-D score at baseline: | | D1: 19.7
| | | D1: 24.6 | | D2: 13.6
| | | D2: 23.1 | | Nausea:
| | | | | D2: 12.1
| | | | | Somnolence (fatigue):
| | | | | D1: 12.1
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Sig greater improvement on 30-item IDS for FLUO than for placebo (-1.19 vs. -0.61; P < 0.02) | Insomnia: | Overall attrition rate:
Judd et al., 2004 | To examine efficacy of FLUO in treatment of outpatients with minor depressive disorder | - Adults 18 or older; - Diagnosed with minor depression according to NIHM Health Diagnostic Interview Schedule; - Healthy with normal physical exam and labs | Overall: 43.5 | Statistically greater rate of improvement in FLUO groups than placebo in 30-item IDS scores (z = 2.40, P < 0.02), 17-item HAM-D (z = 2.06, P = 0.04), and 21-item HAM-D (z = 2.19, P < 0.03). GAF score sig greater in FLUO group (z = 2.10, P < 0.04). At endpoint, 40.5% (FLUO) vs. 24.1%(placebo) patients were rated as “normal/not at all depressed” on CGI-S (chi sq = 6.63, df = 1, P = 0.01) | D1: 24.7 | 27%
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | | | ITT analysis:
United States | 12 wks | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder not related to depression; - Clinically sig medical disease; - Investigational drug use with no response or adverse reaction; - ECT; - Suicidal tendencies; - MDD; - Dysthmymia; - Seizure disorder; - Severe allergies; - Loss of loved one within past yr | Overall: 59.3 | | | Yes
Multicenter | Study design: | | Race (% white): | | | Quality rating:
Funding: | RCT | | Overall: 90.1 | | | Fair
Eli Lilly and Co | Overall study N: | | Baseline (HAM-A):
NIMH grants; Roher fund of University of California, San Diego | 162 | | NR
| Intervention: | | Mean HAM-D score at baseline:
| D1: Fluoxetine: 10–20 mg/d | | D1: 11.7 (3.9)
| D2: placebo | | D2: 11.0 (3.9)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No statistically sig diff in responder rates (95% CI): 87.3% (78.5 – 96.1) in TRA group; 90.6% (82.7 – 98.4) in PAR group. (No P value reported) | Overall adverse events: | Overall attrition rate:
Kasper S., 2005 | To evaluate efficacy and safety of TRA prolonged release vs. PAR in patients with major depression | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV; - HAM-D score of 18–24; - MADRS <30; - Depression symptoms at least 1 mo | D1: 43.5 | No statistically sig diff in remission rates (95% CI): 69.1% (56.9 – 81.3) in trazodone group; 67.9% (55.4 – 80.5) in PAR group. (No P value reported) | D1: 34.5 | 4.6%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 44.3 | | D2: 26.4 | ITT analysis:
Mulitnational | 6 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - ECT; - MDD refractory to treatment; - Psychosis or melancholia; - High risk of suicide | Sex (% female): | | Diarrhea: | Yes
Multicenter | Study design: | | D1: 58 | | D1: 0 | Quality rating:
Funding: | RCT | | D2: 68 | | D2: 1.9 | Fair
ACRAF SpA | Overall study N: | | Race (% white): | | Dizziness:
| 108 | | NR | | D1: 3.6
| Intervention: | | Baseline (HAM-A): | | D2: 1.9
| D1: Trazodone: (prolonged release) 150–450 mg/d | | NR | | Headache:
| D2: Paroxetine: 20–40 mg/d | | Mean HAM-D score at baseline: | | D1: 7.3
| | | D1: 21.0 (SE 0.21) | | D2: 0
| | | D2: 20.9 (SE 0.21) | | Insomnia:
| | | | | D1: 5.5
| | | | | D2: 5.7
| | | | | Nausea:
| | | | | D1: 1.8
| | | | | D2: 11.3
| | | | | Somnolence (fatigue):
| | | | | D1: 1.8
| | | | | D2: 1.9
| | | | | Sweating (increase):
| | | | | D1: 0
| | | | | D2: 1.9
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | With LOCF, “responders” (≥ 50% decrease from baseline in MADRS total score) = 46% ESC group, 47% placebo group, 37% FLUO group (all NS). At last assessment (LOCF), “remitters” (MADRS total score ≤ 12): 40% ESC group, 42% placebo group, 30% FLUO group. Diff between placebo and ESC groups NS, but fewer remitters in FLUO vs. placebo groups (P < 0.05) | Overall adverse events: | Overall attrition rate:
Kasper et al., 2005 | To compare efficacy and tolerability of ESC in a fixed dose of 10 mg with placebo in elderly patients with MDD, using FLUO at fixed dose of 20 mg as a reference drug | - Diagnosed with MDD according to DSM-III or -IV; - Age 65 or more; - MADRS of 22–40; - MMSE 22+ | D1: 75 | | D1: 2.8 | 17.6%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 75 | | D2: 9.8 D3: 12.2 | ITT analysis:
Multinational (11 countries) | 8 wks | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Investigational drug use within last 30 days; - Current ECT; - MADRS score ≥ 5 on Item 10 (suicidal thoughts); - Current behavior therapy or psychotherapy; - History of severe drug allergy or hypersensitivity; - Lack of response to more than one antidepressant treatment (including CIT) during present depressive episode | D3: 75 | | Changes in weight (decrease): | Yes
Multicenter (76 general practice and specialist settings) | Study design: | | Sex (% female): | | D1: 1.1 | Quality rating:
Funding: | RCT | | D1: 76 | | D2: 1.2 D3: 2.4 | Fair
Eli Lilly, Lundbeck, Bristol-Myers Squibb, GlaxoSmith-Kline, Organon, Servier | Overall study N: | | D2: 75 | | Constipation:
| 518 | | D3: 77 | | D1: 4.4
| Intervention: | | Race (% white): | | D2: 1.2 D3: 4.3
| D1: placebo | | D1: 100 | | Diarrhea:
| D2: Escitalopram: 10 mg | | D2: 99 | | D1: 5.0
| D3: Fluoxetine: 20 mg | | D3: 100 | | D2: 1.7 D3: 4.9
| placebo | | Baseline (HAM-A): | | Dizziness:
| | | NR | | D1: 0.6
| | | Mean HAM-D score at baseline: | | D2: 2.9 D3: 3.7
| | | NR | | Headache:
| | | | | D1: 8.3
| | | | | D2: 5.2 D3: 4.3
| | | | | Insomnia:
| | | | | D1: 2.2
| | | | | D2: 2.3 D3: 1.8
| | | | | Nausea:
| | | | | D1: 1.7
| | | | | D2: 6.9 D3: 7.3
| | | | | Somnolence (fatigue):
| | | | | D1: 0.6
| | | | | D2: 2.3 D3: 0
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | HAM-D-21: similar changes in scores over study (both groups showed 50% improvement in scores), no diffs at any point in study | Diarrhea: | Overall attrition rate:
Kavoussi et al., 1997 | To compare efficacy and safety of BUP SR and SER, and to determine whether baseline anxiety predicts antidepressant response | - Adults 18 to 76; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18; - Stable relationship with normal sexual functioning | D1: 39 | CGI-S and CGI-I scores improved steadily throughout treatment phase | D1: 3 | 31.5%
Goes with Rush et al., 2001 | Duration of study: | Exclusion criteria: | D2: 40 | | D2: 22 | ITT analysis:
Country and setting: | 16 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Suicidal tendencies; - History/current diagnosis of eating disorders; - Known predisposition to seizures | Sex (% female): | | Dizziness: | Yes
United States | Study design: | | D1: 48 | | D1: 8 | Quality rating:
Multicenter | RCT | | D2: 48 | | D2: 5 | Fair
Funding: | Overall study N: | | Race (% white): | | Headache:
Glaxo Wellcome, Inc | 248 | | D1: 93 | | D1: 34
| Intervention: | | D2: 94 | | D2: 32
| D1: Bupropion: 100–300 mg/d (mean 238 mg/d) | | Baseline (HAM-A): | | Insomnia:
| D2: Sertraline: 50–200 mg/d (mean 114 mg/d) | | D1: 16.6 (5.2) | | D1: 18
| | | D2: 16.6 (5.2) | | D2: 19
| | | Mean HAM-D score at baseline: | | Nausea:
| | | D1: 24.8 (4.6) | | D1: 10
| | | D2: 24.8 (4.6) | | D2: 30
| | | | | Sexual dysfunction:
| | | | | D1: 10
| | | | | D2: 61
| | | | | Somnolence (fatigue):
| | | | | D1: 2
| | | | | D2: 13
| | | | | Sweating (increase):
| | | | | D1: 2
| | | | | D2: 10
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No statistically sig diff between treatment groups for HAM-D depressed mood item or CGI severity of illness item at each wk or at endpoint | Cardiovascular adverse events: | Overall attrition rate:
Kiev and Feiger, 1997 | To compare FLUV and PAR in treatment of outpatients with major depression | - Adults 18 to 65; - MDD diagnosis according to DSM-III or -IV; - Minimum HAM-D score of 20; minimum score of 2 on “depressed mood” item | D1: 42.7 | No statistically sig treatment diffs in HAM-D retardation and cognitive disturbance factors, HAM-A totoal score or SCL-56 | D1: 13 | 31%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 39.9 | CGI-I mean score at endpoint: | D2: 3 | Overall adverse events:
United States | 7 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies; - Used a drug within 30 days with anticipated major organ toxicity; - Participation in previous FLUV studies; - Transportation difficulties | Sex (% female): | FLUV: 1.93 | Constipation: | D1: 97
Multicenter | Study design: | | D1: 53 | PAR: 2.21 | D1: 7 | D2: 100
(2 centers) | RCT | | D2: 53 | | D2: 13 | ITT analysis:
Funding: | Overall study N: | | Race (% white): | | Diarrhea: | Yes
Solvay Pharmaceuticals, Upjohn | 60 | | D1: 87 | | D1: 13 | Quality rating:
| Intervention: | | D2: 93 | | D2: 30 | Fair
| D1: Fluvoxamine: 50–150 mg/d | | Baseline (HAM-A): | | Dizziness:
| D2: Paroxetine: 20–50 mg/d | | NR | | D1: 20
| | | Mean HAM-D score at baseline: | | D2: 27
| | | D1: 24.35 | | Headache:
| | | D2: 24.36 | | D1: 40
| | | | | D2: 57
| | | | | Insomnia:
| | | | | D1: 30
| | | | | D2: 20
| | | | | Nausea:
| | | | | D1: 37
| | | | | D2: 47
| | | | | Sexual dysfunction:
| | | | | D1: 7
| | | | | D2: 21
| | | | | Somnolence (fatigue):
| | | | | D1: 40
| | | | | D2: 30
| | | | | Sweating (increase):
| | | | | D1: 10
| | | | | D2: 33
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | All 3 treatment groups showed sig improvements in depression and other health related QOL domains (social function, work function, physical function) | NR | Overall attrition rate:
Kroenke et al., 2001 | To compare efficacy of PAR, FLUO. and SER in depressed primary care patients | - Adults 18 or older; - Depressive disorder as determined by PCP; - Had home telephone | D1: 47.2 | No sig diffs between treatment groups in any of 3 and 9 mos outcome measures | | 24.3%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 47.1 | Subgroup analysis showed no diffs in treatment effects for patients with MDD and for patients older than 60 yrs | | ITT analysis:
United States | 9 mos | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Clinically sig medical disease; - Suicidal tendencies | D3: 44.1 | Switch rate to other medication: | | Yes
Primary care (76 physicians) | Study design: | | Sex (% female): | PAR: 22% | | Quality rating:
Funding: | Open-label, randomized trial | | D1: 76 | FLUO: 14% | | Fair
Eli Lilly | Overall study N: | | D2: 86 | SER: 17%
| 601 | | D3: 75
| Intervention: | | Race (% white):
| D1: Paroxetine: 20 mg/d | | D1: 85
| D2: Fluoxetine: 20 mg/d | | D2: 88
| D3: Sertraline: 50 mg/d | | D3: 79
| | | Baseline (HAM-A):
| | | NR
| | | Mean HAM-D score at baseline:
| | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Responders by CGI criterion = 85.3% (MIR) vs. 88.7% (CIT) (P = 0.59) | Changes in weight (increase): | Overall attrition rate:
Leinonen et al., 1999 | To compare andtidepressant, anxiolytic, and QOL effects of MIR and CIT | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 22 | D1: 42.1 | CGI-QOL scale: 77.1% (MIR) vs. 62.4% (CIT) of patients showed any degree of improvement (P = 0.039) | D1: 15.3 | 19.1%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 41.1 | Q-LES-Q: both groups improved; no statistically sig diff between groups; estimate of treatment diff = -0.01 (95% CI -2.65 to -2.63, P = 0.99) | D2: 4.5 | ITT analysis:
Multinational | 8 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Investigational drug use within last 1 to 4 wks; - ECT within last 3 mo; - Suicidal tendencies; - Present depressive episode >12 mos; - Non-responders to antidepressant treatment; - Fast placebo-responders | Sex (% female): | | Diarrhea: | Yes
Funding: | Study design: | | D1: 66.9 | | D1: 2.9 | Quality rating:
Clinical research grant from NV Organon, Oss, The Netherlands | RCT | | D2: 57.1 | | D2: 6.0 | Fair
| Overall study N: | | Race (% white): | | Dizziness:
| 270 | | NR | | D1: 8.8
| Intervention: | | Baseline (HAM-A): | | D2: 4.5
| D1: Mirtazapine: 15–60 mg/d | | D1: 21.1 | | Headache:
| D2: Citalopram: 20–60 mg/d | | D2: 20.9 | | D1: 9.5
| | | Mean HAM-D score at baseline: | | D2: 14.3
| | | NR | | Nausea:
| | | | | D1: 10.2
| | | | | D2: 20.2
| | | | | Somnolence (fatigue):
| | | | | D1: 8
| | | | | D2: 6
| | | | | Sweating (increase):
| | | | | D1: 2.2
| | | | | D2: 15.0
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Sig more ESC patients responded to treatment at study endpoint on MADRS scale than CIT patients (63.7% vs. 52.6%; P = 0.021) | Overall adverse events: | Overall attrition rate:
Lepola et al., 2003 | Efficacy and tolerability of ESC compared to CIT and placebo in depression in primary care setting | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV; - MADRS ≥ 22 | D1: 43 | Sig more ESC than CIT-treated patients were in remission at endpoint (52.1% vs. 42.8%; P < 0.036) | D1: 59.7 | 7%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 43 | ESC was numerically better than CIT at all time points on all 3 efficacy scales | D2: 69.7 | ITT analysis:
Europe and Canada | 8 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Suicidal tendencies | D3: 43 | Analysis of time to response showed that ESC—treated patients were responders 8.1 days faster than CIT-treated patients | D3: 65 | Yes
Primary care | Study design: | | Sex (% female): | | Diarrhea: | Quality rating:
Funding: | RCT | | D1: 69.4 | | D1: 3.2 | Fair
H. Lundbeck A/S | Overall study N: | | D2: 74.8 | | D2: 6.5
| 471 | | D3: 72.1 | | D3: 7.5
| Intervention: | | Race (% white): | | Insomnia:
| D1: Citalopram: 20–40 mg/d (mean 28.4) | | NR | | D1: 1.9
| D2: Escitalopram: 10–20 mg/d (mean 14.0) | | Baseline (HAM-A): | | D2: 6.5
| D3: placebo | | NR | | D3: 4.4
| | | Mean HAM-D score at baseline: | | Nausea:
| | | NR | | D1: 9.1
| | | | | D2: 17.4
| | | | | D3: 14.4
| | | | | Sexual dysfunction:
| | | | | D1: 0
| | | | | D2: 5.1 (male impotence)
| | | | | D3: 0
| | | | | Somnolence (fatigue):
| | | | | D1: 1.3
| | | | | D2: 5.2
| | | | | D3: 3.1
| | | | | Suicidality:
| | | | | D1: 1.9
| | | | | D2: 7.7
| | | | | D3: 5.6
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig diffs in outcome measures between treatment groups | Overall adverse events: | Overall attrition rate:
McPartlin et al., 1998 | To evaluate efficacy and safety of VEN XR and PAR for treatment of depression in general practice | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Symptoms of depression at least 14 days; - Minimum baseline MADRS score of 19 | D1: 45 | Global response (HAM-D, CGI, MADRS rates were at 76% for both treatment groups | D1: 70 | 27.4%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 44 | Remission rates (6 or less on MADRS) were 48% for VEN XR and 46% for PAR | D2: 70 | ITT analysis:
UK | 12 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Investigational drug use within last 30 days; - ECT within last 30 days; - Suicidal tendencies; - Hypersensitive to or previous treatment with VEN or PAR | Sex (% female): | Both treatment groups produced sig improvements on QOL scale without showing diffs between groups | Constipation: | Yes
Multicenter (43 general practice sites) | Study design: | | D1: 68.3 | | D1: 9.9 | Quality rating:
Funding: | RCT | | D2: 68.5 | | D2: 6.8 | Fair
Wyeth-Ayerst International | Overall study N: | | Race (% white): | | Diarrhea:
| 361 | | NR | | D1: 4.4
| Intervention: | | Baseline (HAM-A): | | D2: 5.1
| D1: Venlafaxine: XR 75 mg/d | | NR | | Dizziness:
| D2: Paroxetine: 20 mg/d | | Mean HAM-D score at baseline: | | D1: 16.6
| | | D1: 23 (4) | | D2: 9.6
| | | D2: 23 (4) | | Headache:
| | | | | D1: 8.8
| | | | | D2: 11.9
| | | | | Insomnia:
| | | | | D1: 5.5
| | | | | D2: 4.5
| | | | | Nausea:
| | | | | D1: 25.4
| | | | | D2: 24.9
| | | | | Somnolence (fatigue):
| | | | | D1: 5.5
| | | | | D2: 5.6
| | | | | Sweating (increase):
| | | | | D1: 2.2
| | | | | D2: 6.2
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Both treatment groups showed sig reductions of MADRS, CGI, and HAM-D scores from baseline to wk 8 | Diarrhea: | Overall attrition rate:
Mehtonen et al., 2000 | Efficacy and safety of SER and VEN in outpatients with major depression | - Adults 18 to 65; - Minimum HAM-D score of 18 | D1: 44.1 | Response rates (decrease of 50% on HAM-D) were higher for VEN at wk 6 (74% vs. 59%; P = 0.04) and at endpoint (83% vs. 68%; P = 0.05) | D1: 8.0 | 19%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 41.0 | Remission rates (HAM-D < 10) at endpoint were higher for VEN treated group (68% vs. 45%; P = 0.008) | D2: 13.9 | ITT analysis:
Scandinavia | 8 wks | - Pregnant; - Lactating; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease | Sex (% female): | No sig diffs were noted in response rates on MADRS and CGI scales | Headache: | Yes
Multicenter | Study design: | | D1: 65 | Remission rates for patients who increased dose was higher for VEN group (67% vs. 36%; P < 0.05) | D1: 28.0 | Quality rating:
Funding: | RCT | | D2: 67 | | D2: 29.2 | Good
Wyeth-Ayerst International | Overall study N: | | Race (% white): | | Nausea:
| 147 | | NR | | D1: 36.0
| Intervention: | | Baseline (HAM-A): | | D2: 29.2
| D1: Venlafaxine: 75–150 mg/d | | NR | | Sexual dysfunction:
| D2: Sertraline: 50–100 mg/d | | Mean HAM-D score at baseline: | | D1: 8.0
| | | D1: 25.5 (3.5) | | D2: 5.6
| | | D2: 25.8 (4.5) | | Somnolence (fatigue):
| | | | | D1: 6.7
| | | | | D2: 11.1
| | | | | Sweating (increase):
| | | | | D1: 18.7
| | | | | D2: 11.1
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Rates of respone and remission-equal numbers in both groups of responders and remitters | Overall adverse events: | Overall attrition rate:
Montgomery et al., 2004 | To compare efficacy and tolerability of ESC to VEN XR in primary care patients with MDD | - Adults 18 to 85; - Diagnosed with MDD according to DSM-III or -IV; - MADRS ≥ 18 | D1: 49 | Endpoint: | D1: 67 | 14%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 47 | ESC 77.4% and VEN 79.6% responders | D2: 71 | ITT analysis:
Mulitnational | 8 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies | Sex (% female): | ESC 69.9% and VEN. 69.7% remitters | Constipation: | Yes
Primary care | Study design: | | D1: 73 | | D1: 2 | Quality rating:
Funding: | RCT | | D2: 71 | | D2: 6 | Fair
H. Lundbeck A/S | Overall study N: | | Race (% white): | | Nausea:
| 293 | | NR | | D1: 17
| Intervention: | | Baseline (HAM-A): | | D2: 26
| D1: Escitalopram: 10–20 mg/d (12.1) | | NR | | Sweating (increase):
| D2: Venlafaxine: 75–150 mg/d (95.2) | | Mean HAM-D score at baseline: | | D1: 6
| | | D1: 19.9 | | D2: 12.5
| | | D2: 20.4
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Responders: (50% decrease in MADRS) ESC 76.1% CIT 61.3 (P = 0.008) | Overall adverse events: | Overall attrition rate:
Moore et al., 2005 | Efficacy of ESC vs. CIT in outpatients | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV; - MADRS of at least 30 | D1: 44.1 | Remitters: ESC 56.1% CIT 43.6% (P = 0.04); NNT for remission: 9 | D1: 14.8 | 7.5%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 46.2 | MADRS-S ESC -9.9 CIT -8.6 (P < 0.05) | D2: 16.4 | ITT analysis:
France | 8 wks | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse | Sex (% female): | CGI-S ESC -2.3 CIT -2.12 (P = 0.65) | Changes in weight (increase): | Yes
Psychiatric and general practice | Study design: | | D1: 81.7 | Overall discontinuation was sig higher in CIT (10.6%) than ESC (4.3%) group (P = 0.005) | D1: 1.4 | Quality rating:
Funding: | RCT | | D2: 72 | | D2: 1.3 | Fair
H. Lundbeck A/S | Overall study N: | | Race (% white): | | Dizziness:
| 294 (ITT = 280) | | NR | | D1: 0.7
| Intervention: | | Baseline (HAM-A): | | D2: 1.3
| D1: Escitalopram: 20 mg/d | | NR | | Headache:
| D2: Citalopram: 40 mg/d | | Mean HAM-D score at baseline: | | D1: 4.2
| | | NR | | D2: 5.3
| | | | | Insomnia:
| | | | | D1: 1.4
| | | | | D2: 0.7
| | | | | Nausea:
| | | | | D1: 3.5
| | | | | D2: 3.9
| | | | | Sexual dysfunction:
| | | | | D1: 0
| | | | | D2: 0.7
| | | | | Somnolence (fatigue):
| | | | | D1: 0
| | | | | D2: 2.0
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Overall diffs among treatment groups on HAM-D did not quite reach statistical significance, although diff between VEN and placebo was statistically sig | Constipation: | Overall attrition rate:
Nemeroff et al., 2005 | To assess relative efficacy and safety of VEN and FLUO | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20; - Symptoms present for at least 1 mo | D1: 40.1 | HAM-D response: VEN: 53% vs. FLUO: 45% (P = 0.034); HAM-D remission rates: VEN: 32% vs. FLUO: 28% (P = 0.25) | D1: 10 | 22%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 37.9 | Fluoxetine was sig more effective than placebo according to CGI and PGI definitions in response only; neither active therapy separated sig from placebo on remission definitions | D2: 2 | ITT analysis:
United States | 6 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Investigational drug use within last 30 days; - ECT within last 3 mos; - Suicidal tendencies; - History of nonresponse to VEN or FLUO; - Received VEN within 6 mos | D3: 40.4 | A statistically sig diff observed on only 1 of 5 QOL measures; greater improvement in VEN compared with both FLUO and placebo groups on variable | D3: 5 | Yes
Multicenter (13 university-affiliated and private research clinics) | Study design: | | Sex (% female): | | Diarrhea: | Quality rating:
Funding: | RCT | | D1: 65 | | D1: 9 | Fair
NR | Overall study N: | | D2: 69 | | D2: 13
| 308 | | D3: 56 | | D3: 9
| Intervention: | | Race (% white): | | Dizziness:
| D1: Venlafaxine: 75–225 mg/d | | D1: 91 | | D1: 13
| D2: Fluoxetine: 20–60 mg/d | | D2: 93 | | D2: 8
| D3: placebo | | D3: 92 | | D3: 3
| | | Baseline (HAM-A): | | Headache:
| | | NR | | D1: 36
| | | Mean HAM-D score at baseline: | | D2: 24
| | | D1: 23.5 (3.2) | | D3: 33
| | | D2: 23.7 (3.2) | | Insomnia:
| | | D3: 23.7 (3.3) | | D1: 22
| | | | | D2: 15
| | | | | D3: 14
| | | | | Nausea:
| | | | | D1: 40
| | | | | D2: 22
| | | | | D3: 8
| | | | | Somnolence (fatigue):
| | | | | D1: 10
| | | | | D2: 10
| | | | | D3: 5
| | | | | Sweating (increase):
| | | | | D1: 14
| | | | | D2: 4
| | | | | D3: 2
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Both treatment groups resulted in sig improvements of depression scores compared to baseline | Overall adverse events: | Overall attrition rate:
Nemeroff et al., 1995 | Comparison of efficacy and safety of FLUV and SER in treatment of depression | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20; - HAM-D depressed mood item of at least 2; - Covi anxiety score less than Raskin score; - Minimum score of 8 on Raskin Depression Scale | D1: 41.2 | No sig diff in efficacy between treatment groups | D1: 93.5 | 28%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 38.5 | | D2: 85.7 | ITT analysis:
United States | 7 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Patients itolerant of SSRI side effects | Sex (% female): | | Diarrhea: | Yes
Multicenter | Study design: | | D1: 60.9 | | D1: 23.9 | Quality rating:
Funding: | RCT | | D2: 61.2 | | D2: 14.3 | Fair
Solvay Pharmaceuticals | Overall study N: | | Race (% white): | | Dizziness:
| 95 | | D1: 84.8 | | D1: 15.2
| Intervention: | | D2: 98.0 | | D2: 12.2
| D1: Sertraline: 50–200 mg/d (137.1) | | Baseline (HAM-A): | | Headache:
| D2: Fluvoxamine: 50–150 mg/d (123.8) | | NR | | D1: 32.6
| | | Mean HAM-D score at baseline: | | D2: 26.5
| | | D1: 23.15 (2.77) | | Insomnia:
| | | D2: 24.57 (3.66) | | D1: 34.8
| | | | | D2: 26.5
| | | | | Nausea:
| | | | | D1: 21.7
| | | | | D2: 30.6
| | | | | Sexual dysfunction:
| | | | | D1: 28
| | | | | D2: 10
| | | | | Somnolence (fatigue):
| | | | | D1: 17.4 asthenia-13
| | | | | D2: 24.5 asthenia-6.1
| | | | | Sweating (increase):
| | | | | D1: 10.9
| | | | | D2: 6.1
Author: | Research objective: | Inclusion criteria: | Overall/Subgroup | Overall: | Overall adverse events: | Overall attrition rate:
Newhouse et al., 2000 | To assess efficacy of SER vs. FLUO on depressive symptoms in patients aged 60 or older and 70 or older | - Minimum HAM-D score of 18; - Age ≥ 60 overall; ≥ 70 for subgroup analysis | Mean age (yrs): | No sig diffs in SER and FLUO on primary efficacy measures | D1: 88/93 | 32.2%
Finkel et al., 1999 | Duration of study: | Exclusion criteria: | D1: 68/74 | Responders: | D2: 89/94 | ITT analysis:
Country and setting: | 12 wks | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies; - Failure to respond to either ECT or adequate antidepressant trials | D2: 67/75 | SER: 73% | Nausea: | Yes
United States | Study design: | | Sex (% female): | FLUO: 71% | D1: 14.7/16.7 | Quality rating:
Outpatient | RCT | | D1: 63/57 | Remitters: | D2: 18.6/15.2 | Fair
Funding: | Overall study N: | | D2: 51/49 | SER: 45%
NR | 75 (n = 236 in full trial, subgroup analysis of 75 patients who were 70 or older) | | Race (% white): | FLUO: 46%
| Intervention: | | D1: 96/95 | Sugroup analysis:
| D1: Sertraline: 50–100 mg/d | | D2: 100/100 | Sig more responders in SER group
| D2: Fluoxetine: 20–40 mg/d | | Baseline (HAM-A): | (P = 0.027): 58.5% (SER) vs. 42.4% (FLUO)
| | | D1: NR | Psychological Health subscale: SER group improved from 46.0 (9.2) to 51.4 (8.8) and FLUO group improved from 43.0 (7.0) to 45.3 (9.3). No data given on total Q-LES-Q scores
| | | D2: NR
| | | Mean HAM-D score at baseline:
| | | D1: 25.1/24.2
| | | D2: 25.0/25.4
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No diff in mean MADRS at endpoint or in mean change from baseline; mean change: | Overall adverse events: | Overall attrition rate:
Patris et al., 1996 | To compare CIT with FLUO treatment in patients with unipolar major depression treated in general practice | - Adults 18 to 73; - Diagnosed with MDD according to DSM-III or -IV; - MADRS at least 22 | D1: 44 | CIT: -20.7 | D1: 50 | 12.6%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 43 | FLUO: -19.4 | D2: 52 | ITT analysis:
France | 8 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies; - Dysthymia or cyclothmia; - MAOI treatment within last 2 wks | Sex (% female): | Responders (reduction in score from baseline > 50%) at endpoint: | Changes in weight (decrease): | No
Multicenter (general practices) | Study design: | | D1: 79 | CIT: 78% | D1: 3.5 | Quality rating:
Funding: | RCT | | D2: 76 | FLUO: 76% | D2: 8.2 | Fair
NR | Overall study N: | | Race (% white): | Remitters (MADRS ≤ 12) at endpoint: | Constipation:
| 357 | | NR | CIT: 75% | D1: 1.2
| Intervention: | | Baseline (HAM-A): | FLUO: 86% | D2: 3.3
| D1: Citalopram: 20 mg/d | | NR | (P = 0.26) | Diarrhea:
| D2: Fluoxetine: 20 mg/d | | Mean HAM-D score at baseline: | | D1: 3.5
| | | NR | | D2: 0
| | | | | Headache:
| | | | | D1: 3.5
| | | | | D2: 3.8
| | | | | Insomnia:
| | | | | D1: 4.6
| | | | | D2: 5.4
| | | | | Nausea:
| | | | | D1: 9.8
| | | | | D2: 7.6
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | At endpoint no sig diffs in health outcomes between FLUO and TRA | Overall adverse events: | Overall attrition rate:
Perry et al., 1989 | To compare clinical efficacy of FLUO and TRA in patients with major depression | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20; - Duration of illness ≥ 1 mo; - Outpatient; - Unipolar | D1: 42 | | D1: 43% reported 2+ events | 20%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 39 | | D2: 37% reported 2+ events | ITT analysis:
United States | 6 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Clinically sig medical disease; - Investigational drug use within last 4 wks; - Suicidal tendencies; - Hypertensive patient using guanethidine, reserpine, clonidine, or methyldopa | Sex (% female): | | Cardiovascular adverse events: | Yes
Funding: | Study design: | | D1: Male:female ratio = 9:12 | | D1: 0 | Quality rating:
NR | RCT | | D2: Male:female ratio = 10:9 | | D2: 11 | Fair
| Overall study N: | | Race (% white): | | Diarrhea:
| 40 | | NR | | D1: 14
| Intervention: | | Baseline (HAM-A): | | D2: 0
| D1: Fluoxetine: 20–60 mg/d | | NR | | Dizziness:
| D2: Trazodone: 50–400 mg/d | | Mean HAM-D score at baseline: | | D1: 14
| | | D1: 23.2 (2.8) | | D2: 21
| | | D2: 23.6 (3.0) | | Headache:
| | | | | D1: 29
| | | | | D2: 26
| | | | | Nausea:
| | | | | D1: 24
| | | | | D2: 26
| | | | | Somnolence (fatigue):
| | | | | D1: 19
| | | | | D2: 37
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No statistically sig diffs observed between 2 groups on any efficacy parameter. Medications well tolerated, with only 2 patients in each group terminated because of side effects. FLUV was associated with less nausea than FLUO | Headache: | Overall attrition rate:
Rapaport et al., 1996 | To compare efficacy, safety, and tolerance of FLUV and FLUO in a depressed outpatient population | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20; - Minimum score of 2 on depressed mood item at screening and baseline visits (HAM-D) | D1: 40.0 | | D1: 50 | 16%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 38.6 | | D2: 53 | ITT analysis:
United States | 7 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies: acute (score of ≥ 21 on Modified Scale for Suicidal Ideation); - Previous treatment with FLUO or FLUV; - History of seizure disorder | Sex (% female): | | Insomnia: | Yes
Multicenter | Study design: | | D1: 62 | | D1: 36 | Quality rating:
Funding: | RCT | | D2: 63.2 | | D2: 28 | Fair
Solvay Pharmaceuticals, Inc.; The Upjohn Company | Overall study N: | | Race (% white): | | Nausea:
| 100 | | D1: 92.2 | | D2: 42.5
| Intervention: | | D2: 98 | | Suicidality:
| D1: Fluvoxamine: 100–150 mg; endpoint mean = 101.85 (25.22) | | Baseline (HAM-A): | | D1: 2
| D2: Fluoxetine: 20–80 mg; endpoint mean = 34.17 (18.84) | | D1: 16.0 | | D2: 2
| | | D2: 16.2
| | | Mean HAM-D score at baseline:
| | | D1: 25.2
| | | D2: 25.6
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Number of responders sig higher in SER group | Overall adverse events: | Overall attrition rate:
Ravindran et al., 2000 | To determine safety, tolerability, and efficacy of SER vs. placebo in treatment of dysthymia | - Adults 18 or older; - MDD diagnosis according to DSM-III or -IV; - Minimum HAM-D score of 12; - Dysthymia; - Duration ≥ 5 yrs | D1: 46.0 | HAM-A: SER: 51.9%, placebo: 33.8% (P = 0.001) | D1: 75.3 | 24.2%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 44.2 | MADRS: SER: 53.2%, placebo: 37.5% (P = 0.006) | D2: 64.5 | ITT analysis:
Canada and Europe | 12 wks | - Pregnant; - Lactating; - Additional mental illnesses or organic mental disorder | Sex (% female): | CGI-I: SER: 60.1%, placebo: 39.5%, (P < 0.001) | Constipation: | Yes
Multicenter | Study design: | | D1: 65.8 | Number of remitters was also sig higher in SER group 33.8% vs. 21.6% (P = 0.02) | D1: 6.3 | Quality rating:
Funding: | RCT | | D2: 67.8 | BQOL showed sig greater improvements in 8 of 9 domains in SER group | D2: 3.3 | Fair
Pfizer, Inc | Overall study N: | | Race (% white): | | Diarrhea:
| 310 | | NR | | D1: 12.7
| Intervention: | | Baseline (HAM-A): | | D2: 7.2
| D1: Sertraline: 50–200 mg/d | | NR | | Dizziness:
| D2: placebo | | Mean HAM-D score at baseline: | | D1: 12.7
| | | D1: 19.2 (6.98) | | D2: 3.9
| | | D2: 18.6 (6.62) | | Headache:
| | | | | D1: 30.4
| | | | | D2: 33.6
| | | | | Insomnia:
| | | | | D1: 22.2
| | | | | D2: 16.4
| | | | | Nausea:
| | | | | D1: 20.9
| | | | | D2: 17.8
| | | | | Sexual dysfunction:
| | | | | D1: 9.3
| | | | | D2: 0
| | | | | Somnolence (fatigue):
| | | | | D1: 11.4 fatigue-7.0
| | | | | D2: 7.2 fatigue-2.6
| | | | | Sweating (increase):
| | | | | D1: 13.9
| | | | | D2: 2
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Both treatments induced a sig, sustained, comparable improvement in depressive symptoms and social functioning | Dizziness: | Overall attrition rate:
Rocca et al., 2005 | To compare effect of SER and CIT on depression symptoms and cognitive functions in nondemented elderly patients with minor depressive disorder or sybsyndromal depressive symptomatology | - Minimum HAM-D score of 10; - Nondemented elderly (65 or older); - Minor depressive disorder or subsyndromal depressive disorder according to SCID | D1: 72.4 | Change from baseline to endpoint on HAM-D CIT and SER groups decrease 55% vs. 52.7%; (P = NR) or GDS | D1: 15.2 | 27.5
Country and setting: | Duration of study: | Exclusion criteria: | D2: 71.9 | Remission observed at any timepoint between treatment groups | D2: 9.7 | ITT Analysis:
Italy | 12 mos | - Concomitant psychotheraputic or psychotropic medications; - Clinically sig medical disease; - Any other current Axis I or II psychiatric disorder; - Impairment and decline of global cognitive functions on MMSE; - Score of at least 12 on Alzheimer's Disease Assessment Scale-Cognitive Subscale | Sex (% female): | 12 mos: 53% vs. 42%; P = 0.25 | Headache: | Yes
University clinic | Study design: | | D1: 24.2 | Sig within-group improvements seen in all cognitive measures for both SER and CIT WMS, TMT-A, TMT-B, VF, and MMSE | D1: 10.1 | Quality rating:
Funding: | Nonrandomized controlled trial | | D2: 31.9 | | D2: 9.7 | Fair
University of Turin, Italy | Overall study N: | | Race (% white): | | Nausea:
| 138 | | NR | | D1: 24.2
| Intervention: | | Baseline (HAM-A): | | D2: 18.1
| D1: Citalopram: 20 mg/d | | NR
| D2: Sertraline: 50 mg/d | | Mean HAM-D score at baseline:
| | | D1: 12.9
| | | D2: 12.9
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | HAM-D: | NR | Overall attrition rate:
Rossini et al., 2005 | To compare efficacy and tolerability of FLUV and SER in elderly patients | - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 21; - 59 yrs of age and older; - MDD diagnosed by MD using unstructured interviews and medical records according to DSM-IV, and after a best estimate procedure | D1: 67.80 | No sig diff in final response rates found between 2 treatment groups, 55.6% (25/45) and 71.8% (28/39) for SER and FLUV (P = 0.12). Repeated-measures analysis of variance on HAM-D scores revealed a sig different decrease of depressive symptoms between 2 treatment groups, favoring FLUV (P = 0.007) | | 4.5%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 68.24 | | | ITT analysis:
Italy | 7 wks (after a 7-day single-blind placebo washout) | - Additional mental illnesses or organic mental disorder; - MMSE score <23; - Nonreversible MAOI or slow release neuroleptics within 1 mo of study; - Bipolar patients had to be on mood stabilizers; - Depression or bipolar disorder due to a medical condition or induced by a substance | Sex (% female): | | | Yes
One inpatient center | Study design: | | D1: 61.5 | | | Quality rating:
Funding: | RCT | | D2: 82.2 | | | Fair
NR | Overall study N: | | Race (% white):
| 93 | | NR
| Intervention: | | Baseline (HAM-A):
| D1: Fluvoxamine: 200 mg/d (100mg twice daily) | | NR
| D2: Sertraline: 150 mg/d (75mg twice daily) | | Mean HAM-D score at baseline:
| | | D1: 31.23 (5.12)
| | | D2: 29.23 (3.45)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig diff between VEN and FLUO treatment on 21-HAM-D or MADRS at endpoint in LOCF analysis | Changes in weight (decrease): | Overall attrition rate:
Rudolph and Feiger, 1999 | Comparison of efficacy and tolerability of VEN XR to FLUO | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20 | D1: 40 | At wk 8 of LOCF, 57% of VEN group and 50% of FLUO group (P = 0.07) were HAM-D responders | D1: 9 | 23%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 40 | At end of treatment 37% of VEN group and 22% of FLUO (P ≤ 0.05) group were in remission (HAM-D score ≤ 7) | D2: 10 | ITT analysis:
United States | 8 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder not related to depression; - Illicit drug and alcohol abuse; - Bipolar disorder | D3: 40 | At endpoint in LOCF analysis, VEN patients showed a sig diff from placebo in MADRS, CGI, and HAM-D depressed mood item | Diarrhea: | Yes
Multicenter (12 outpatient psychiatric practices) | Study design: | | Sex (% female): | FLUO patients only showed a sig diff in HAM-D depressed mood item | D1: 14 | Quality rating:
Funding: | RCT | | D1: 73 | | D2: 19 | Fair
Wyeth-Ayerst International | Overall study N: | | D2: 69 | | Dizziness:
| 301 | | D3: 64 | | D1: 26
| Intervention: | | Race (% white): | | D2: 6
| D1: Venlafaxine: XR 75–225 mg/d | | NR | | Nausea:
| D2: Fluoxetine: 20–60 mg/d | | Baseline (HAM-A): | | D1: 36
| D3: placebo | | NR | | D2: 20
| | | Mean HAM-D score at baseline: | | Somnolence (fatigue):
| | | D1: 25 | | D1: 8
| | | D2: 26 | | D2: 12
| | | D3: 25 | | Sweating (increase):
| | | | | D1: 10
| | | | | D2: 8
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No diff in efficacy between groups as measured by change in HAM-D17 | Constipation: | Overall attrition rate:
Rush et al., 1998 | Effect of NEF and FLUO on sleep in patients with MDD | - Adults 19 to 55; - MDD diagnosis according to DSM-III or -IV; - Minimum HAM-D score of 18; - Concomitant condition: sleep disturbances | D1: 36 | Response (< 10 on HAM-D17): | D1: 17 | 17%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 37 | NEF: 47% | D2: 11 | ITT analysis:
United States and Canada | 8 wks | - Pregnant; - Lactating; - Clinically sig medical disease | Sex (% female): | FLUO: 45% | Diarrhea: | Yes
Multicenter | Study design: | | D1: 59 | On EEG: increased sleep efficiency, decreased awakenings and decreased % AMT for NEF as compared to FLUO | D1: 16 | Quality rating:
Funding: | RCT | | D2: 70 | Also sig diffs on sleep disturbance factors of HAM-D and IDS-C and IDS-SR favoring NEF over FLUO | D2: 26 | Fair
please list name: Seay Center for Research (UT Southwestern), NIMH | Overall study N: | | Race (% white): | | Dizziness:
| 125 | | D1: 78 | | D1: 22
| Intervention: | | D2: 85 | | D2: 8
| D1: Nefazodone: 200–500 mg/d (mean = 424) | | Baseline (HAM-A): | | Headache:
| D2: Fluoxetine: 20–40 mg/d (mean = 32) | | NR | | D1: 56
| | | Mean HAM-D score at baseline: | | D2: 48
| | | D1: 22.9 (2.9) | | Insomnia:
| | | D2: 23.3 (2.7) | | D1: 6
| | | | | D2: 11
| | | | | Nausea:
| | | | | D1: 36
| | | | | D2: 25
| | | | | Somnolence (fatigue):
| | | | | D1: 22
| | | | | D2: 21
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | CGI-I responders (CGI-I of much or very much improved) | Overall adverse events: | Overall attrition rate:
Schatzberg et al., 2002 | To compare efficacy and tolerability of MIR with PAR in elderly patients with MDD | - Adults 65 or older; - MDD diagnosis according to DSM-III or -IV; - Minimum HAM-D score of 18; - MMSE above 25% for age and educational level | D1: 71.7 | At endpoint | D1: 79.7 | 26.8%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 72.0 | MIR (80) 64.0% | D2: 82.5 | ITT analysis:
United States | 8 wk acute phase, optional 16 wk continuation phase | - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - ECT within last 6 mos; - Suicide attempts; - MAOIs within 14 days, other psychotropic drugs or herbals within 7 days; - PAR or MIR for current depressive episode; - Patients requiring drugs for memory deficit; - Patients who did not respond to or tolerate MIR or PAR during a previous depressive episode | Sex (% female): | PAR (68) 56.7% | Changes in weight (increase): | Yes
Mutli-center (recruited from advertising, private practice, routine intake at clinics and other healthcare facilities) | Study design: | | D1: 50% | chi square 1.23 (P = 0.267) | D1: 10.9 | Quality rating:
Funding: | RCT | | D2: 53% | | D2: 0 | Fair
Organon Pharmacueticals | Overall study N: | | Race (% white): | | Constipation:
| 255 | | NR | | D1: 11.7
| Intervention: | | Baseline (HAM-A): | | D2: 11.1
| D1: Mirtazapine: 15 mg/d up to 45 mg/d | | NR | | Diarrhea:
| D2: Paroxetine: 20 mg/d up to 40 mg/d | | Mean HAM-D score at baseline: | | D1: 14.8
| | | D1: 22.2 (3.5) | | D2: 17.5
| | | D2: 22.4 (3.5) | | Dizziness:
| | | | | D1: 15.6
| | | | | D2: 14.3
| | | | | Headache:
| | | | | D1: 15.6
| | | | | D2: 24.6
| | | | | Insomnia:
| | | | | D1: 11.7
| | | | | D2: 11.1
| | | | | Nausea:
| | | | | D1: 6.3
| | | | | D2: 19.0
| | | | | Somnolence (fatigue):
| | | | | D1: 30.5
| | | | | D2: 29.4
| | | | | Sweating (increase):
| | | | | D1: 6.3
| | | | | D2: 13.5
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig diff in mean changes on HAM-D or MADRS | Constipation: | Overall attrition rate:
Schone and Ludwig, 1993 | Comparison of efficacy and safety with PAR and FLUO in geriatric outpatients | - Adults 65 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18 | D1: 74.3 | HAM-D responders at wk 6 (i.e., reduction > 50% from baseline HAM-D21) sig greater in PAR group than FLUO group | D1: 5.6 | NR
Country and setting: | Duration of study: | Exclusion criteria: | D2: 73.7 | MADRS responders at wk 6 (i.e., reduction > 50% from baseline MADRS) sig greater in PAR than FLUO | D2: 3.8 | ITT analysis:
Austria and Germany | 6 wks | - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - ECT within last 3 mos | Sex (% female): | | Diarrhea: | Yes
6 centers | Study design: | | D1: 83 | | D1: 1.9 | Quality rating:
Funding: | RCT | | D2: 90 | | D2: 11.5 | Fair
SmithKline, Beecham | Overall study N: | | Race (% white): | | Dizziness:
| 108 | | NR | | D1: 7.4
| Intervention: | | Baseline (HAM-A): | | D2: 3.8
| D1: Paroxetine: 20–40 mg/d | | NR | | Headache:
| D2: Fluoxetine: 20–60 mg/d | | Mean HAM-D score at baseline: | | D1: 7.4
| | | NR | | D2: 5.8
| | | | | Insomnia:
| | | | | D1: 9.3
| | | | | D2: 13.5
| | | | | Nausea:
| | | | | D1: 9.3
| | | | | D2: 11.5
| | | | | Somnolence (fatigue):
| | | | | D1: asthenia 1.9
| | | | | D2: asthenia 7.7
| | | | | Sweating (increase):
| | | | | D1: 7.4
| | | | | D2: 7.7
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Response was observed in 74% in SER patients vs. 64% in FLUO patients on HAM-D | Constipation: | Overall attrition rate:
Sechter et al., 1999 | Comparison of efficacy and safety in patients being treated with SER and FLUO with MDD | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20 | D1: 43.4 | No diff in QOL (SIP) | D1: 1 | 29.2%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 42.5 | | D2: 2 | ITT analysis:
France | 24 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Epilepsy; - FLUO or lactose allergy | Sex (% female): | | Diarrhea: | Yes
Multicenter (45) | Study design: | | D1: 66.7 | | D1: 3 | Quality rating:
Funding: | RCT | | D2: 68.1 | | D2: 2 | Fair
Pfizer, Inc | Overall study N: | | Race (% white): | | Headache:
| 234 | | NR | | D1: 5
| Intervention: | | Baseline (HAM-A): | | D2: 7
| D1: Sertraline: 50–150 (mean = 76.5) | | NR | | Nausea:
| D2: Fluoxetine: 20–60 (mean = 33.6) | | Mean HAM-D score at baseline: | | D1: 23
| | | NR | | D2: 17
| | | | | Somnolence (fatigue):
| | | | | D1: 5
| | | | | D2: 6
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No statistical comparisons between FLUO and VEN (just placebo) | Changes in weight (decrease): | Overall attrition rate:
Silverstone and Ravindran, 1999 | Comparison of VEN XR and FLUO in outpatients with depression and anxiety | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20; - Depression for 1 mo before study | D1: 41.6 | At wk 12 response rates were 67% for VEN and 62% for FLUO (P < 0.05) | D2: 10 | 32%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 41.1 | HAM-D scores in VEN and FLUO groups dropped sig when compared with placebo | D3: 7 | ITT analysis:
Canada | 12 wks | - Pregnant; - Lactating; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Investigational drug; - ECT within last 30 days; - Suicidal tendencies | D3: 43.2 | VEN had sig more HAM-A responders at wk 12 than FLUO | Dizziness: | Yes
Multicenter | Study design: | | Sex (% female): | HAM-D remission rate in VEN group was sig compared to placebo at wks 3, 4, 6, 8, 12 and final | D2: 38 | Quality rating:
Funding: | RCT | | D1: 64 | HAM-D remission rate in FLUO group was sig compared to placebo at wks 8, 12, and final | D3: 18 | Fair
Wyeth-Ayerst International | Overall study N: | | D2: 60 | Patients in VEN group showed a sig decrease in HAM-D and HAM-A scores compared to placebo (P < 0.05) | Insomnia:
| 368 | | D3: 57.6 | | D2: 32
| Intervention: | | Race (% white): | | D3: 25
| D1: placebo | | NR | | Somnolence (fatigue):
| D2: Venlafaxine: 75–225 mg/d (could be increased to 150 mg/d on day 14 and 225 mg/d on day 28) | | Baseline (HAM-A): | | D2: 13
| D3: Fluoxetine: 20–60 mg/d (could be increased to 40 mg/d on day 14 and 60 mg/d on day 28) | | NR | | D3: 14
| | | Mean HAM-D score at baseline: | | Sweating (increase):
| | | D1: 27.6 (5.1) | | D2: 10
| | | D2: 27.0 (4.6) | | D3: 10
| | | D3: 27.1 (4.5)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Efficacy: | Dizziness: | Overall attrition rate:
Sir et al., 2005 | Test for diffs between SER and VEN XR on measures of QOL.Test for efficacy diffs on measures of depressive symptoms and tolerability, including discontinuation symptoms | - Adults 18 or older; - MDD diagnosis according to DSM-III or -IV; - Minimum HAM-D score of 18 | D1: 37.3 | No sig diff exists in terms of efficacy between VEN and SER. | D1: 32.9 | 23%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 36.8 | HAM-D responders: | D2: 26.2 | ITT analysis:
Australia and Turkey | 8 wks then up to 2 wks discontinuation | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Non-response to an adequate trial of 2 ADs in current episode | Sex (% female): | SER: 70.9% | Headache: | Yes
Clinics (Turkey 7 and Australia 6) | Study design: | | D1: 72.2 | VEN: 70.9% (P = 0.95) | D1: 44.3 | Quality rating:
Funding: | RCT | | D2: 66.7 | HAM-D remitters: | D2: 32.1 | Good
Pfizer, Inc | Overall study N: | | Race (% white): | SER: 59.5% | Insomnia:
| 163 | | D1: 96.2 | VEN: 54.4% (P = 0.47) | D1: 35.4
| Intervention: | | D2: 100 | Discontinuation of SER is associated with fewer discontinuation-emergent symptoms than for discontinuation of VEN | D2: 27.4
| D1: Sertraline: 50–150 mg/d | | Baseline (HAM-A): | Change in Q-LES-Q: | Nausea:
| D2: Venlafaxine: 75–225 mg/d | | NR | SER 16.8 + 1.77 | D1: 51.9
| | | Mean HAM-D score at baseline: | VEN 17.5 + 14.5 (P = 0.74) | D2: 47.6
| | | D1: 23.4 (4.4) | | Somnolence (fatigue):
| | | D2: 23.5 (4.4) | | D1: 21.5
| | | | | D2: 26.2
| | | | | Sweating (increase):
| | | | | D1: 31.6
| | | | | D2: 21.4
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | SER group showed sig more responders than placebo (59.0% vs. 44.3%; P < 0.02) | Cardiovascular adverse events: | Overall attrition rate:
Thase et al., 1996 | To evaluate safety and efficacy of SER and IMI in treating dysthymia | - Adults 25 to 65; - Minimum HAM-D score of 12; - Dysthymia; - Early onset dysthmia; - Duration ≥ 5 yrs; - Depression symptom-free mos ≤ 2 | D1: 42 | A sig greater proportion of patients in SER group increased in psychosocial functioning compared to placebo (61% vs. 45%; P = 0.01) as measured by Global Assessment of Functioning Score of 71 or more | D1: 4 | 24.3%
Kocsis et al., 1997 | Duration of study: | Exclusion criteria: | D2: 42 | Sig improvements in family relationships, marital relationships, and parental role functioning | D2: 9 | ITT analysis:
Country and setting: | 12 wks | - Pregnant; - Lactating; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Suicidal tendencies; - Previous nonresponse to at least 2 adequate antidepressant trials; - Concurrent MDD | D3: 42 | Sig more SER patients than placebo patients were classified as harm avoidance responders (P = 0.001) | D3: 2 | Yes
United States | Study design: | | Sex (% female): | | Constipation: | Quality rating:
Multicenter (17 United States centers) | RCT | | D1: 65 | | D1: 16 | Fair
Funding: | Overall study N: | | D2: 65 | | D2: 40
NR | 416 | | D3: 65 | | D3: 9
| Intervention: | | Race (% white): | | Diarrhea:
| D1: Sertraline: 50–200 mg/d | | D1: 95 | | D1: 21
| D2: Imipramine: 50–300 mg/d | | D2: 95 | | D2: 7
| D3: placebo | | D3: 95 | | D3: 10
| | | Baseline (HAM-A): | | Dizziness:
| | | NR | | D1: 14
| | | Mean HAM-D score at baseline: | | D2: 28
| | | D1: 12.7 (4) | | D3: 16
| | | D2: 13.4 (3.8) | | Headache:
| | | D3: 12.7 (3.9) | | D1: 41
| | | | | D2: 39
| | | | | D3: 46
| | | | | Insomnia:
| | | | | D1: 24
| | | | | D2: 12
| | | | | D3: 17
| | | | | Nausea:
| | | | | D1: 27
| | | | | D2: 26
| | | | | D3: 20
| | | | | Somnolence (fatigue):
| | | | | D1: 23
| | | | | D2: 32
| | | | | D3: 12
| | | | | Sweating (increase):
| | | | | D1: 12
| | | | | D2: 28
| | | | | D3: 6
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | A reduction of 50% or more in MADRS scores among 75% of PAR and 78% of FLUO patients. MADRS scores fell to ≤ 11 among 67% of PAR and 64% of FLUO patients | Nausea: | Overall attrition rate:
Tignol, 1993 | To compare PAR and FLUO in treatment of inpatients with major depression | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV; - MADRS total score of 24 or more; - Hospital inpatient at screening and for first 2 wks of trial | D1: 43.0 | After 6 wks of treatment, CGI-S scores were 1 or 2 among 78% of PAR and 73% of FLUO patients | D1: 4 | 1.1%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 44.7 | | D2: 10 | ITT analysis:
France | 6 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Investigational drug use within last 6 mos; - ECT within last 3 mos; - Suicidal tendencies; - Receiving oral anticoagulant; - Severe drug allergy/reaction in past | Sex (% female): | | | Yes
Multicenter | Study design: | | D1: 64 | | | Quality rating:
Funding: | RCT | | D2: 75 | | | Fair
SmithKline Beecham Pharmaceuticals | Overall study N: | | Race (% white):
| 178 | | NR
| Intervention: | | Baseline (HAM-A):
| D1: Paroxetine: 20 mg | | NR
| D2: Fluoxetine: 20 mg | | Mean HAM-D score at baseline:
| | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | MADRS, HAM-D, and CGI scores decreased sig for both treatment groups but there were no sig diffs between treatment groups | Overall adverse events: | Overall attrition rate:
Tylee et al., 1997 | Safety and efficacy of VEN and FLUO in depression treated in general practice | - Adults 18 or older; - MDD diagnosis according to DSM-III or -IV; - Depressive symptoms for more than 2 wks | D1: 43.5 | MADRS, HAM-D, or CGI responders: | D1: 80.7 | 27%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 45.5 | FLUO: 62.8% | D2: 71.8 | ITT analysis:
UK | 12 wks + 7 day post follow-up | - Pregnant; - Lactating; - Additional mental illnesses or organic mental disorder; - ECT within last 1 mo; - Suicidal tendencies | Sex (% female): | VEN: 55.1%(P = NR) | Diarrhea: | Yes
Funding: | Study design: | | D1: 67.8 | MADRS remitters (MADRS ≤ 6): | D1: 4.1 | Quality rating:
Wyeth-Ayerst International | RCT | | D2: 74.7 | FLUO: 34.1% | D2: 6.5 | Fair
| Overall study N: | | Race (% white): | VEN: 35.4%(P = NR) | Dizziness:
| 341 | | NR | | D1: 11.1
| Intervention: | | Baseline (HAM-A): | No sig diffs in effects on sleep | D2: 6.5
| D1: Venlafaxine: 75 mg/d | | NR | | Headache:
| D2: Fluoxetine: 20 mg/d | | Mean HAM-D score at baseline: | | D1: 11.1
| | | NR | | D2: 17.1
| | | | | Nausea:
| | | | | D1: 34.5
| | | | | D2: 18.2
| | | | | Somnolence (fatigue):
| | | | | D1: 7.0
| | | | | D2: 4.7
| | | | | Sweating (increase):
| | | | | D1: 5.8
| | | | | D2: 1.2
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | At 6 wks, 70% of patients with VEN and 66% with FLUO had ≥ 50% reduction in MADRS score, and 70% with VEN and 62% with FLUO had a CGI-I score of 1 or 2. A CGI-I score of 1 was observed in 51% of patients with VEN and 32% with FLUO (P = 0.018). Final HAM-D score < 7 was attained in 41% of VEN and 36% of FLUO patients | Overall adverse events: | Overall attrition rate:
Tzanakaki et al., 2000 | Efficacy and tolerability of VEN and FLUO in patients with major depression and melancholia | - Adults 18 to 64; - Diagnosed with MDD according to DSM-III or -IV; - Concomitant condition: melancholia; - MADRS ≥ 25 | D1: 47 | | D1: 49.1 | 22%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 49 | | D2: 46.3 | ITT analysis:
Greece and Italy | 6 wks | - Pregnant; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Investigational drug use within last 30 days; - ECT within last 30 days; - Suicidal tendencies | Sex (% female): | | Constipation: | Yes
Hospitalized and day care | Study design: | | D1: 75 | | D1: 7.3 | Quality rating:
Funding: | RCT | | D2: 83 | | D2: 1.9 | Fair
Wyeth-Ayerst International | Overall study N: | | Race (% white): | | Dizziness:
| 109 | | NR | | D1: 5.5
| Intervention: | | Baseline (HAM-A): | | D2: 0
| D1: Venlafaxine: 225 mg/d | | NR | | Headache:
| D2: Fluoxetine: 60 mg/d | | Mean HAM-D score at baseline: | | D1: 5.5
| | | D1: 27.8 (5.6) | | D2: 1.9
| | | D2: 27.1 (5.6) | | Insomnia:
| | | | | D1: 12.7
| | | | | D2: 1.9
| | | | | Nausea:
| | | | | D1: 5.5
| | | | | D2: 14.8
| | | | | Sweating (increase):
| | | | | D1: 5.5
| | | | | D2: 3.7
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | ACUTE PHASE | Overall adverse events: | Overall attrition rate:
Van Moffaert et al., 1995 | To evaluate comparative efficacy and tolerability of SER and FLUO in acute and continuation treatment of MDD | - Adults 18 to 80; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18 | D1: 46.1 | % responders/partial responders at end of acute phase (defined as ≥ 50% reduction in HAM-D or MADRS, or a score ≤ 10 on HAM-D, and much/very much improved on CGI-GI and a CGI-S within nonmental illness range): | D1: 48 | 17%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 48.4 | SER = 71% | D2: 54 | ITT analysis:
Belgium, Multicenter trial (15 psychiatric centers, in- and out-patient) | 8 wks acute phase, responders and partial responders could continue in 24 wk continuation phase | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal ideation; - MADRS score greater than 40; - Concomitant serotonergic drugs (including lithium and carbamazepine) | Sex (% female): | FLUO = 77% | Cardiovascular adverse events: | Yes
Funding: | Study design: | | D1: 66.3 | CONTINUATION PHASE | D1: 4 | Quality rating:
Pfizer | RCT | | D2: 65.9 | Relapse rates | D2: 4 | Fair
| Overall study N: | | Race (% white): | SER = 10%
| 165 | | NR | FLUO = 13%
| Intervention: | | Baseline (HAM-A): | Response rate (see defintion above)
| D1: Sertraline: 50–100 mg/d | | NR | SER = 81%
| D2: Fluoxetine: 20–40 mg/d | | Mean HAM-D score at baseline: | FLUO = 80%
| | | D1: 24.5
| | | D2: 23.2
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | MIR had sig higher response rates on HAM-D at study endpoint than TRA (61% vs. 51%; P < NR) | NR | Overall attrition rate:
van Moffaert et al., 1995 | Safety and efficacy of MIR and TRA in depressed hospital patients | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18 | D1: 46.1 | MIR was also more efficacious on other outcome scales (MADRS, Beck, Brief Psychiatric Rating Scale total score, General Psychiatric Impression Global Assessment Scale ) but not all diffs reached statistical significance | | 24.5%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 46.3 | | | ITT analysis:
Belgium | 6 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - ECT; - Suicidal tendencies 3 mos; - > 6 episodes of depression requiring hospitalization | Sex (% female): | | | Yes
Psychiatric centers (6 sites) | Study design: | | D1: 69 | | | Quality rating:
Funding: | RCT | | D2: 71 | | | Fair
NV Organon | Overall study N: | | Race (% white):
| 200 | | NR
| Intervention: | | Baseline (HAM-A):
| D1: Mirtazapine: 24–72 mg/d | | NR
| D2: Trazodone: 150–450 mg/d | | Mean HAM-D score at baseline:
| | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | # of responders at mo 3 (>50% decrease in HAM-D associated with a score of 1 (very much improved) or 2 (much improved) on CGI-I), FLUO = 42 placebo = 14 (P = 0.03) | Overall adverse events: | Overall attrition rate:
Vanelle et al., 1997 | To investigate whether FLUO is effective in treatment of dysthymia | - Adults 18 or older; - Minimum HAM-D score of 16; - Dysthymia; - Dysthymia not secondary to any other axis I disorder | NR | Remission n at mo 3 (HAM-D ≤ 7), FLUO = 32, placebo = 10 (P = 0.07) | D1: 38.5% | 22.1%
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | # of responders at mo 6: FLUO = 33 placebo = 9 (P = 0.48) | D2: 44.9% | ITT analysis:
France, Psychiatric centers | 6 mos (Phase 1 = 3 mos, Phase 2 = 3 mos) | - Additional mental illnesses or organic mental disorder; - MDD, other types of depression; - Uncontrolled serious somatic disease; - FLUO for depressive disorder which had not been effective; - Received a psychotropic drug during previous wk (except for authorized benzodiazepines); - Requiring one of following during study: neuroleptic, lithium, or other mood regulator | D1: 76.9 | Remission n at mo 6: FLUO: 29 placebo: 4 (P = 0.01) | | Yes
Funding: | Study design: | | D2: 73.5 | Increase in GAF scores by mo 3 sig greater in FLUO (P = 0.02); mean score indicated return to functioning level compatible with normal social and relational life (mean GAF score = 70) | | Quality rating:
NR | RCT | | Race (% white): | No sig change in GAF scores from mo 3 to 6 for either treatment group | | Fair
| Overall study N: | | NR
| 140 (randomized) | | Baseline (HAM-A):
| Intervention: | | NR
| D1: Fluoxetine: 20 mg/d (Phase I), 20–40 mg/d (Phase II) | | Mean HAM-D score at baseline:
| D2: placebo | | D1: 20.5 (3.1)
| | | D2: 20.9 (3.0)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig diff in percent of responders at day 56, (MIR: 40.1% vs. FLUO: 41.4 %) | Overall adverse events: | Overall attrition rate:
Versiani et al., 2005 | To compare effectiveness and tolerability of MIR and FLUO in severe MDD and compare effects on anxiety, sleep and QOL | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 25 | D1: 43 | Both treatment groups showed 18 point improvement on QLSQ | D1: 50 | 14%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 47 | | D2: 45 | ITT analysis:
Multinational, Multicenter (30 sites) | 8 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Investigational drug use within last 30 days; - ECT within last 3 mos; - Suicidal tendencies | Sex (% female): | | Changes in weight (increase): | Yes
Funding: | Study design: | | D1: 74 | | D1: 6.9 | Quality rating:
Organon, NV | RCT | | D2: 69 | | D2: 1.3 | Fair
| Overall study N: | | Race (% white): | | Dizziness:
| 299 | | NR | | D1: 9
| Intervention: | | Baseline (HAM-A): | | D2: 12.8
| D1: Mirtazapine: 30–60 mg | | NR | | Headache:
| D2: Fluoxetine: 20–40 mg | | Mean HAM-D score at baseline: | | D1: 19.3
| | | D1: 29 (3) | | D2: 18.8
| | | D2: 28(3) | | Insomnia:
| | | | | D1: 4.8
| | | | | D2: 8.7
| | | | | Nausea:
| | | | | D1: 15.9
| | | | | D2: 24.1
| | | | | Somnolence (fatigue):
| | | | | D1: 13.8
| | | | | D2: 9.4
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig diffs in any outcome measures between treatment groups (LOCF and observed ) | Constipation: | Overall attrition rate:
Weihs et al., 2000 | Comparison of efficacy and safety of BUP and PAR with PAR in treatment of MDD in elderly | - Adults 60+; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18 | D1: 69.2 | Response rates ≥ 50% reduction in HAM-D) were similar in both groups: BUP SR: 71%, PAR: 77% | D1: 4 | 16%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 71.0 | No sig diffs in Quality of Life scales (QLDS, SF-36) between treatment groups at endpoint; overall sig improvement in QLDS and QOL at day 42 (P < 0.0001) | D2: 15 | ITT analysis:
United States | 6 wks | - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies | Sex (% female): | | Diarrhea: | Yes
Multicenter | Study design: | | D1: 54 | | D1: 6 | Quality rating:
Funding: | RCT | | D2: 60 | | D2: 21 | Fair
Glaxo Wellcome | Overall study N: | | Race (% white): | | Dizziness:
| 100 | | D1: 98 | | D1: >10
| Intervention: | | D2: 90 | | D2: >10
| D1: Bupropion: 100–300 mg/d (197) | | Baseline (HAM-A): | | Headache:
| D2: Paroxetine: 10–40 mg/d (22) | | NR | | D1: 35
| | | Mean HAM-D score at baseline: | | D2: 19
| | | NR | | Insomnia:
| | | | | D1: >10
| | | | | D2: >10
| | | | | Nausea:
| | | | | D1: >10
| | | | | D2: >10
| | | | | Somnolence (fatigue):
| | | | | D1: 6
| | | | | D2: 27
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | HAM-D (LOCF) Center 1 | Constipation: | Overall attrition rate:
Weisler et al., 1994 | To compare safety and efficacy of BUP and TRA | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20; - Episode of at least 4 wks but < 2 yrs; - Clinically appropriate for therapy | D1: 40.2 | BUP: at day 42, BUP stat sig better than TRA (P < 0.01) | D1: 9.68 | 40.3%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 40.8 | When centers combined, no statistically sig diffs between TRA and BUP were observed | D2: 11.67 | ITT analysis:
Country NR, appears to be United States | 6 wks (after a 1 wk single-blind placebo lead-in to eliminate placebo responders and placebo nontolerators) | - Pregnant/Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies; - Male with history of priapism or being treated with meds associated with priapism; - Prior treatment with BUP or TRA, currently taking digoxin or phenytoin | Sex (% female): | Responder analysis (responder = > 50% reduction in HAM-D score between baseline and discontinuation) | Diarrhea: | Yes
2 private psycho-pharmacology clinics | Study design: | | D1: 52.4 | BUP = 33 (55.9%) | D1: 4.84 | Quality rating:
Funding: | RCT | | D2: 65.6 | TRA = 21 (40.4%) | D2: 11.67 | Fair
Burroughs Wellcome Co | Overall study N: | | Race (% white): | Remitters (>50% reduction and a HAM-D score<10) | Dizziness:
| 124 | | D1: 90.5 | BUP = 27 (46%) | D1: 20.97
| Intervention: | | D2: 90.2 | TRA = 16 (31%) | D2: 30.00
| D1: Bupropion: 225–450 mg/d | | Baseline (HAM-A): | CGI-I responders | Headache:
| D2: Trazodone: 150–400 mg/d | | NR | BUP = 34 (57.6%) | D1: 33.87
| | | Mean HAM-D score at baseline: | TRA = 24 (46.2%) | D2: 23.33
| | | D1: 25.8 | | Insomnia:
| | | D2: 25.0 | | D1: 14.52
| | | | | D2: 5.00
| | | | | Nausea:
| | | | | D1: 11.29
| | | | | D2: 6.67
| | | | | Somnolence (fatigue):
| | | | | D1: 8.06
| | | | | D2: 45.00
| | | | | Sweating (increase):
| | | | | D1: 9.68
| | | | | D2: 5.00
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | HAM-D responders at endpoint (≥ 50% improvment) | Dizziness: | Overall attrition rate:
Wheatley et al., 1998 | To compare efficacy and tolerability of MIR and FLUO in depressed inpatients and outpatients | - Adults 18 to 75; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 21; - HAM-D item 1 (depressed mood) score ≥ 2; - Depressive episode duration 2 wks to 12 mos | D1: 47.2 | MIR ~65% (n = 39) | D1: 7.6% | 28.6%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 47.5 | FLOU ~45% (n = 28)(P = NS) | D2: 9.0% | ITT analysis:
Multinational | 6 wks (after a 3–7 day single-blind, placebo washout period) | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Nonresponders to antidepressant treatment | Sex (% female): | Remission from depression (HAM-D < 7 at endpoint): | Headache: | Yes
Multicenter | Study design: | | D1: 55 | MIR 23.3% | D1: 9.1% | Quality rating:
Funding: | RCT | | D2: 58.7 | FLUO 25.4%(P = 0.39) | D2: 17.9% | Fair
NV Organon | Overall study N: | | Race (% white): | CGI responders (much or very much approved): | Nausea:
| 133 | | NR | MIR 63.3% | D1: 3.0%
| Intervention: | | Baseline (HAM-A): | FLUO 54.0%(P = 0.677) | D2: 10.4%
| D1: Mirtazapine: 15–60 mg/d | | NR | Q-LES-Q estimated treatment diff (MIR minus FLUO): 2.14 95% CI (-2.30, 6.58) (P = 0.348) | Somnolence (fatigue):
| D2: Fluoxetine: 20–40 mg/d | | Mean HAM-D score at baseline: | | D1: 18.2%
| | | D1: 26.0 (4.4) | | D2: 13.4%
| | | D2: 26.1 (4.3)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Mean decrease in HSCL-D-20: PAR: 0.61 (P = 0.05) placebo: 0.40 (P = 0.05) | Overall adverse events: | Overall attrition rate:
Williams, 2000 | To compare effectiveness of PAR vs. placebo vs. behavioral treatment for dysthymia or minor depression in primary care patients older than 60 yrs | - Minimum HAM-D score of 10; - Dysthymia; - Age 60+ | D1: 71 | Behavior Therapy 0.52 (P = 0.05) | NR | 25.1%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 71 | P = 0.004 for PAR vs. placebo | | TT Analysis:
United States | 11 wk | - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Severe Suicidal tendencies; - MMSE <24; - Current depression treatment | Sex (% female): | PAR only statistically and clinically sig better than placebo for subjects with dysthymia and high baseline mental health function | | Yes
Multicenter, primary care clinics | Study design: | | D1: 39 | HAM-D results NR for ITT population | | Quality rating:
Funding: | RCT | | D2: 45 | | | Fair
Hartford and MacArthur Foundations | Overall study N: | | Race (% white):
| 415 | | D1: 82.5
| Intervention: | | D2: 75.7
| D1: Paroxetine: 10–40, individually titrated | | Baseline (HAM-A):
| D2: placebo | | NR
| | | Mean HAM-D score at baseline:
| | | NR

Evidence Table 2. KQ2: Efficacy or effectiveness of antidepressants for treating remission, nonresponse, or relapse

Study Characteristics | Research Objective | Inclusion/Exclusion | Baseline Characteristics | Health Outcome Results | Adverse Events (%) | Analysis and Quality Rating
| Duration
| Study Design
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Conventional therapy (pooled): | Overall adverse events: | Overall attrition rate:
Baldomero et al., 2005 | To compare efficacy of VEN to conventional treatments in patients that failed to tolerate or respond to initial treatment | - Diagnosed with MDD according to DSM-III or -IV; - Adults 18 and over; - Minimum HAM-D score > 16 | D1: 46.6 | Response 1034 (71%) | D1: 26.4 | 21.3%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 46.0 | Remission 754 (52%) | D2: 28.2 | ITT Analysis
Spain | 24 wks | - Concomitant psychotheraputic or psychotropic medications; - ECT within 30 days; - MAOI or St. Johns Wort in last 14 days | Sex (% female): | CIT 20–40: | Cardiovascular adverse events: | Yes
Psychiatric outpatient centers | Study design: | | D1: 72.8 | Response 209 (71%) | D1: 3.3 | Quality rating:
Funding: | RCT | | D2: 68.9 | Remission 153 (52%) | D2: 1.1 | Fair
Wyeth Pharma, S.A | Overall study N: | | Race (% white): | FLUO 20–40: | Sexual dysfunctional:
| 3502 | | NR | Response 174 (70%) | D1: 8.7
| Intervention: | | Baseline HAM-A: | Remission 128 (52%) | D2: 13.6
| D1: Venlafaxine: 75–225 mg/d | | D1: 22.8 | MIR 30–45:
| D2: Conventional txt: | | D2: 22.2 | Response 75 (65%)
| Citalopram: 20–40 mg/d | | Baseline HAM-D: | Remission 52 (45%)
| Fluoxetine: 20–40 mg/d | | D1: 23.9 (4.9) | PAR 20–40:
| Mirtazapine: 30–45 mg/d | | D2: NR | Response 226 (73%)
| Paroxetine: 20–40 mg/d | | | Remission 161 (52%)
| Sertraline: 50–150 mg/d | | | SER 50–150:
| | | | Response 197 (71%)
| | | | Remission 147 (53%)
| | | | VEN 75–225:
| | | | Response 1262 (78%)
| | | | Remission 963 (59%)
| | | | VEN sig better than conventional therapy on response and remission (P < 0.001)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Response rates = 63.8%(PAR) vs. 69.6% (placebo). HAM-D: declined from 26.2 to 9.9 during short-term trial, then stabalized over 1 yr in PAR group; declined from 26.4 to 10.1 during short-term, then to 6.3 at 1 yr in placebo group. CGI-S: 4.2 baseline to 2.0 at 1 yr (PAR) vs. 4.3 baseline to 1.6 at 1 yr (placebo) | Constipation: | Overall attrition rate:
Claghorn and Feighner, 1993 | To compare effectiveness of PAR vs. IMI and placebo maintaining antidepressant response up to 1 yr after acute treatment response, and to compare tolerability and safety | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18; - Successful completion of 6-wk trial; - Raskin Depression rating of 7+; Raskin score > Covi Anxiety score | D1: 42.2 | Relapse rates in responders: PAR 15%, placebo 25% | D1: 19 | NR
Country and setting: | Duration of study: | Exclusion criteria: | D2: 40.6 | | Diarrhea: | ITT Analysis
United States, outpatient | 1 yr | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Clinically sig medical disease | Sex (% female): | | D1: 17 | Yes
Funding: | Study design: | | D1: 60.6 | | Dizziness: | Quality rating:
SmithKline Beecham | 1-yr extension of a 6-wk placebo-controlled trial | | D2: 28.3 | | D1: 15 | Fair
| Overall study N: | | Race (% white): | | Headache:
| 219 of 717 patients randomized to acute phase continued in double-blind extension | | D1: 87.2 | | D1: 21
| Intervention: | | D2: 89.1 | | Insomnia:
| D1: Paroxetine: 10–50 mg/d | | Baseline HAM-A: | | D1: 20
| D2: Placebo | | NR | | Nausea:
| | | Baseline HAM-D (SD): | | D1: 16
| | | D1: 9.9 | | Sexual dysfunctional (male ejaculation):
| | | D2: 8.7 | | D1: 16
| | | | | Somnolence (fatigue):
| | | | | D1: 20
| | | | | Sweating (increase):
| | | | | D1: 14
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | CGI response rates (score or 1 or 2): | Overall adverse events: | Overall attrition rate:
Cunningham et al., 1994 | To compare efficacy and safety of VEN, TRA, and placebo in outpatients with major depression | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20; - Must have major depression symptoms for at least 1 mo prior to initial visit | Overall: 40.7 | VEN 72% | D1: 18 | 33.78%
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | TRA 60% | D2: 23 | ITT Analysis
5 United States sites and 1 in Montreal, Canada | Short-term study: 6 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Investigational drug use within last 2 yrs; - ECT within last 14 days; - Suicidial tendencies; - No formal psychotherapy allowed during study period | Overall: F:M ratio 2:1 | placebo 55% (P = NR) | D3: 4 | Yes
Multicenter | Long-term study: 1 yr | | Race (% white): | 30 TRA- and 37 VEN-treated clinical responders (CGI-I score of 1 or 2) were allowed to continue on in long-term phase | Constipation: | Quality rating:
Funding: | Study design: | | NR | Relapse rates: | D1: 22 | Fair
Wyeth-Ayerst Research | RCT | | Baseline HAM-A: | TRA 13% | D2: 9
| Overall study N: | | NR | VEN, 8% | D3: 4
| Enrolled: 227 | | Baseline HAM-D: | placebo 14% (P = NR) | Dizziness:
| Analyzed: 225 | | D1: 25.02 | | D1: 17
| Intervention: | | D2: 24.66 | | D2: 36
| Average daily doses after titration: | | D3: 24.41 | | D3: 5
| D1: Venlafaxine: 156–160 mg/d | | | | Nausea:
| D2: Trazodone: 294–300 mg/d | | | | D1: 44
| D3: Placebo | | | | D2: 19
| | | | | D3: 5
| | | | | Somnolence (fatigue):
| | | | | D1: 43
| | | | | D2: 61
| | | | | D3: 12
| | | | | Sweating (increase):
| | | | | D1: 12
| | | | | D2: 3
| | | | | D3: 1
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Statistically sig lower proportion of SER patients relapsed compared to placebo patients (13.0% vs. 45.7%; P < 0.001). Protective effect of SER was maintained throughout 44 wks of double-blind portion of study. SER prevents relapse of index episode of depression as well as recurrence of further episodes and has few side effects | Overall adverse events: | Overall attrition rate:
Doogan and Caillard, 1992 | To investigate whether SER could alter course of affective symptoms and episodes in patients who had satisfactory response to acute therapy | - Adults 18 to 70; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 17 | NR | | D1: 36.8 | 51.2%
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | | D2: 29.1 | ITT Analysis
Multinational (France, Germany, Austria, Switzerland, Great Britain, Ireland), multicenter | 52 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - History of peptic ulceration; - Hypersensitivity or resistance to antidepressant drugs | NR | | Cardiovascular adverse events: | Yes
Funding: | Study design: | | Race (% white): | | D1: < 1 | Quality rating:
Pfizer Central Research | RCT | | NR | | D2: < 1 | Fair
| Overall study N: | | Baseline HAM-A: | | Constipation:
| 480 entered single-blind placebo period; 295 entered double-blind therapy | | NR | | D1: < 1
| Intervention: | | Baseline HAM-D: | | D2: 1.8
| D1: Sertraline: 50–200 mg/d | | D1: 9.4 (6.7) | | Diarrhea:
| D2: Placebo | | D2: 10.2 (6.8) | | D1: 1.1
| | | | | D2: 2.7
| | | | | Dizziness:
| | | | | D1: 4.9
| | | | | D2: 5.5
| | | | | Headache:
| | | | | D1: 5.9
| | | | | D2: 7.3
| | | | | Insomnia:
| | | | | D1: 3.8
| | | | | D2: 4.5
| | | | | Nausea:
| | | | | D1: 3.8
| | | | | D2: < 1
| | | | | Somnolence (fatigue):
| | | | | D1: 3.2
| | | | | D2: 1.85
| | | | | Suicidality:
| | | | | D1: 1 D2: 0
| | | | | Sweating (increase):
| | | | | D1: 0
| | | | | D2: 0
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Kaplan-Meier survival curves show relapse rate sig lower (P = 0.0009) in nefazodone (1.8%) group vs. placebo (18.3%) group | Changes in weight (increase): | Overall attrition rate:
Feiger et al., 1999 | To evaluate efficacy of NEF in prevention of relapse during continuation phase treatment of patients with MDD | - Adults; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20; - Must have responded to 16 wks of single-blind NEF treatment (≤ 10 HAMD-D for 2 consecutive visits) | D1: 40 | Discontinuation due to lack of efficacy 17.3% for NEF and 32.8% for placebo | D1: +0.6kg | 45%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 42.6 | Relative risk of relapse (HAM-D)was sig lower for NEF than placebo overall (0.094; P = 0.003) and stratified by recurrent depression, melancholia, and sex (P < 0.005 for all) | D2: +0.9kg | ITT Analysis
United States; outpatient | 36 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - ECT; - MAOI use in past 4 wks | Sex (% female): | Relative risk of relapse based on discontinuation due to lack of efficacy also was sig lower for NEF than placebo (0.445; P = 0.04) | Headache: | Yes
Funding: | Study design: | | D1: 72 | | D1: 20 | Quality rating:
Bristol Meyers Squibb | RCT | | D2: 71 | | D2: 14 | Fair
| Overall study N: | | Race (% white): | | Nausea:
| 131 | | D1: 94 | | D1: 12
| Intervention: | | D2: 98 | | D2: 8
| D1: Nefazodone: 400–600 mg/d | | Baseline HAM-A:
| D2: Placebo | | NR
| | | Baseline HAM-D:
| | | D1: 24.4 (0.3)
| | | D2: 24.2 (0.3)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | At end of 1 yr, conditional probability of recurrence was 30.3% for NEF-treated patients, compared with 47.5% for placebo-treated patients | Changes in weight (decrease): | Overall attrition rate:
Gelenberg et al., 2003 | Comparison of nefazodone and placebo in prevention of depression recurrence | - Adults 18 to 75; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20 | D1: 44.4 | | D1: 14.1 | 50.6%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 44.1 | | D2: 9.5 | ITT Analysis
United States | 52 wks | - Pregnant; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - ECT within last 3 mos; - Suicidial tendencies | D3: 44.0 | | Changes in weight (increase): | Yes
Multiclinic | Study design: | | Sex (% female): | | D1: 4.7 | Quality rating:
Funding: | RCT | | D1: 69.7 | | D2: 14.3 | Fair
Bristol-Myers-Squibb | Overall study N: | | D2: 65.5 | | Headache:
| 165 for maintenance phase | | D3: 67.5 | | D1: 41.0
| Intervention: | | Race (% white): | | D2: 32.2
| D1: Nefazodone: 300–600 mg/d (495.2) | | Overall: 96.5 | | Insomnia:
| D2: Placebo | | Baseline HAM-A: | | D1: 17.9
| D3: Overall | | NR | | D2: 19.5
| | | Baseline HAM-D: | | Nausea:
| | | NR | | D1: 10.3
| | | | | D2: 6.9
| | | | | Sexual dysfunctional (male ejaculation):
| | | | | D1: 2.6
| | | | | D2: 3.4
| | | | | Somnolence (fatigue):
| | | | | D1: 15.4
| | | | | D2: 4.6
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | 20% recurrence rate with FLUO vs. 40% with placebo (P = 0.010); symptom-free period sig longer for FLUO vs. placebo (295 days vs. 192 days, P = 0.002); mean end-point HAMD sig lower in FLUO vs. placebo (6.5 ± 8.6 vs. 9.9 ± 9.4; P = 0.027) | Overall adverse events: | Overall attrition rate:
Gilaberte et al., 2001 | To evaluate efficacy and safety of FLUO compared to placebo in maintenance treatment of recurrent unipolar depression | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18; - At least one prior depressive episode in last 5 yrs; - CGI-S score at least 4 in index episode | D1: 44.4 | | D1: 62.9 | 44.3%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 43.8 | | D2: 68.6 | ITT Analysis
Spain; multicenter (10) | 1 yr for maintenance (2 yrs total) | - Pregnant; - Lactating; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Suicidial tendencies; - Previous resistance to pharmacologic treatment | Sex (% female): | | Changes in weight (decrease): | Yes
Funding: | Study design: | | D1: 78.6 | | D1: 11.4 | Quality rating:
Eli Lilly and Co | RCT | | D2: 78.6 | | D2: 7.1 | Fair
| Overall study N: | | Race (% white): | | Dizziness:
| 140 (double-blind maintenance phase) | | NR | | D1: 10.0
| Intervention: | | Baseline HAM-A: | | D2: 17.1
| D1: Fluoxetine: 20–40 mg/d | | NR | | Headache:
| D2: Placebo | | Baseline HAM-D: | | D1: 20
| | | D1: 2.8 (2.0) | | D2: 27.1
| | | D2: 3.1 (2.7) | | Insomnia:
| | | | | D1: 21.4
| | | | | D2: 14.3
| | | | | Nausea:
| | | | | D1: 12.9
| | | | | D2: 12.9
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Time to recurrence was longer in patients taking CIT than in patients taking placebo CIT 24/132 (18.2%); placebo 59/132 (44.7%) (P < 0.001). Prophylactic treatment well tolerated. | Cardiovascular adverse events: | Overall attrition rate:
Hochstrasser et al., 2001 | To compare prophylactic efficacy of CIT vs. placebo in unipolar, recurrent depression following response to treatment with CIT in previous study periods | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV; - MADRS ≥ 22; - Two or more previous depressive episodes (one within last 5 yrs) | D1: 43.8 (9.7) | Risk ratio related to recurrence of depression (CIT / placebo) estimated at 0.321 (95% CI: 0.199–0.516). | D1: 5.3 | NR
Country and setting: | Duration of study: | Exclusion criteria: | D2: 42.4 (11.5) | Diff in time to recurrence between CIT and placebo groups statistically sig at all dose levels (log rank test: 20 mg, P = 0.0043; 40 mg, P = 0.0008; 60 mg, P = 0.0157). | D2: 2.9 | ITT Analysis
Multinational, multicenter | 48–77 wks | - Pregnant; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - ECT within last 3 days to 8 wks; - Suicidial tendencies; - MADRS item 10 ≥ 5; - Current depressive episode longer than 6 mos; - Family history of bipolar disorder | Sex (% female): | In Period III of study, AE profile of CIT was comparable to placebo group | Diarrhea: | Yes
Funding: | Study design: | | D1: 67.4 | | D1: 3.8 | Quality rating:
H. Lundbeck A/S | RCT | | D2: 75 | | D2: 2.2 | Fair
| Overall study N: | | Race (% white): | | Dizziness:
| (For period III): 269 | | NR | | D1: 8.3
| Intervention: | | Baseline HAM-A: | | D2: 16.1
| D1: Citalopram: 20, 40, or 60 mg (3 groups + placebo) | | NR | | Headache:
| D2: Placebo | | Baseline HAM-D: | | D1: 16.7
| | | NR | | D2: 15.3
| | | | | Insomnia:
| | | | | D1: 15.9
| | | | | D2: 14.6
| | | | | Nausea:
| | | | | D1: 6.1
| | | | | D2: 10.2
| | | | | Somnolence (fatigue):
| | | | | D1: 8.3
| | | | | D2: 7.3
| | | | | Sweating (increase):
| | | | | D1: 6.1
| | | | | D2: 8.8
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Recurrence %: | Overall adverse events: | Overall attrition rate:
Keller et al., 1998 | To determine if maintenance therapy with SER can effectively prevent recurrence of depression in patients with chronic major depression or double depression | - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18; - MDD with or without dysthymic disorder; - Chronic depression defined as depression of at least 2 yrs duration; - This was a 3 phase study | D1: 40.8 | By strict protocol criteria: SER = 6%, placebo = 23% (P = 0.002) | D1: 80.5 | 63.4%
Kocsis et al., 2002 | Duration of study: | Exclusion criteria: | D2: 42.4 | By consensus agreement: SER = 26%, placebo = 50% (P = 0.001) | Changes in weight (increase): | ITT Analysis
Country and setting: | 76 wks | NR | Sex (% female): | Showed first symptoms of recurrence by consensus agreement: SER = 34%, placebo = 60% (P = 0.001) | D1: 15.6 | No, time to event of the full population
United States | Study design: | | D1: 62 | Patients receiving placebo were 2.18 (1.27, 3.74) times as likely to experience reemergence of depression and 4.07 (1.51, 10.95) times as likely to experience depression recurrence as patients taking ser during maintenance therapy, adjusted for pooled study site, type of depression, and randomization strata (P < 0.02 for both outcomes) | Diarrhea: | Quality rating:
(10) outpatient psychiatric clinics and (2) academic centers | RCT | | D2: 69 | | D1: 15.6 | Fair
Funding: | Overall study N: | | Race (% white): | | Dizziness:
Pfizer | 161 | | NR | | D1: 11.7
| Intervention: | | Baseline HAM-A: | | Headache:
| D1: Sertraline: 50–200 mg/d | | NR | | D1: 28.6
| D2: Placebo | | Baseline HAM-D: | | Insomnia:
| | | D1: 5.5 (4.2) | | D1: 19.5
| | | D2: 6.3 (3.7) | | Nausea:
| | | | | D1: 13
| | | | | Sexual dysfunctional (male ejaculation):
| | | | | D1: 0
| | | | | Somnolence (fatigue):
| | | | | D1: 11.7
| | | | | Sweating (increase):
| | | | | D1: 15.6
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Nineteen of 60 patients (32%) using CIT and 41 of 61 patients (67%) using placebo had recurrence. Time to recurrence was sig different between CIT-and placebo-patients, in favour of CIT (log-rank test, P < 0.0001) | Overall adverse events: | Overall attrition rate:
Klysner et al., 2002 | To compare prophylactic efficacy of CIT and placebo in elderly patients: to evaluate long-term tolerability of CIT | - Diagnosed with MDD according to DSM-III or -IV; - Adults 65 or older; - MADRS score of 22 or greater | D1: 74 | | D1: 5.4 | 76%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 75 | | D2: 12.2 | ITT Analysis
Denmark | 48 wks | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - FLUO within 5 wks; - Other antidepressants within 3 days; - ECT within last 8 wks; - Suicidial tendencies MADRS item 10 ≥ 10; - Severe somatic disorders | Sex (% female): | | Diarrhea: | Yes
Single center study - out patient | Study design: | | D1: 82 | | D1: 5 | Quality rating:
Funding: | RCT | | D2: 72 | | D2: 4.9 | Fair
H. Lundbeck A/S | Overall study N: | | Race (% white): | | Dizziness:
| 230 in acute; 172 entered continuation phase; 121 entered maintenance phase | | NR | | D1: 1.7
| Intervention: | | Baseline HAM-A: | | D2: 6.6
| D1: Citalopram: 20–40 mg/d | | NR | | Headache:
| D2: Placebo | | Baseline HAM-D: | | D1: 1.7
| | | NR | | D2: 6.6
| | | | | Insomnia:
| | | | | D1: 0
| | | | | D2: 4.9
| | | | | Nausea:
| | | | | D1: 0
| | | | | D2: 3.3
| | | | | Sexual dysfunctional:
| | | | | D1: 0
| | | | | D2: 0
| | | | | Somnolence (fatigue):
| | | | | D1: 16.7
| | | | | D2: 9.8
| | | | | Sweating (increase):
| | | | | D1: 6.7
| | | | | D2: 4.9
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Recurrences were sig lower in SER groups compared with placebo (SER, 50 mg: 16 [16.8%] of 95; SER, 100 mg: 16 [17.0%] of 94; placebo: 33 [33.3%] of 99). Patients treated with SER also had sig longer time until recurrence compared with placebo-treated patients | Overall adverse events: | Overall attrition rate:
Lepine et al., 2004 | To determine whether SER prevents recurrence of major depressive disorder among patients with recurrent depression who had been treated to remission with medications other than SER | - Adults; - Diagnosed with MDD according to DSM-III or -IV; - At least 3 documented episodes in previous 4 yrs; - Treated for at least 4 mos, currently in full remission | D1: 47.3 | | D1: 76 | 41.1%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 48.0 | | D2: 80 | ITT Analysis
France | 20 mos | - Pregnant; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder | D3: 45.5 | | D3: 71 | Yes
Psychiatric centers (83 sites) | 18 mos double-blind phase | | Sex (% female): | | Headache: | Quality rating:
Funding: | Study design: | | D1: 60.0 | | D1: 11.2 | Good
Pfizer | RCT | | D2: 77.7 | | D2: 7.1
| Overall study N: | | D3: 73.7 | | D3: 7.8
| 299 | | Race (% white): | | Insomnia:
| Intervention: | | NR | | D1: 12.2
| D1: Sertraline 50 | | Baseline HAM-A: | | D2: 11.2
| D2: Sertraline 100 | | NR | | D3: 12.6
| D3: Placebo | | Baseline HAM-D: | | Nausea:
| | | NR | | D1: 6.1
| | | | | D2: 10.2
| | | | | D3: 4.9
| | | | | Somnolence (fatigue):
| | | | | D1: 6.1 asthenia- 9.2
| | | | | D2: 5.1 asthenia- 10.2
| | | | | D2: 6.8 asthenia-5.8
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Survival analysis determined a 22% cumulative probability of recurrence in VEN-treated patients after 12 mos compared with 55% for placebo group (P < 0.001) | Overall adverse events: | Overall attrition rate:
Montgomery et al., 2004 | Long-term efficacy and safety of prophylactic VEN treatment in patients with recurrent major depression | - Adults; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20 | D1: 43.8 | More than twice as many placebo-treated patients (48%) as VEN-treated patients (21%) discontinued treatment because of lack of efficacy (P < 0.001) | D1: TAES- 80 | 63%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 43.5 | | D2: TAES- 79 | ITT Analysis
United States and Europe | 12 mos double-blind phase | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Hypersensitivity to VEN; - HAM-D score >12 after acute and continuation treatment | Sex (% female): | | Diarrhea: | Yes
Psychiatric centers (31 sites) | Study design: | | D1: 71 | | D1: 12 | Quality rating:
Funding: | RCT | | D2: 67 | | D2: 7 | Fair
Wyeth Research | Overall study N: | | Race (% white): | | Dizziness:
| 235 (ITT = 225) | | NR | | D1: 17
| Intervention: | | Baseline HAM-A: | | D2: 25
| D1: Venlafaxine: 100–200 mg/d | | NR | | Headache:
| D2: Placebo | | Baseline HAM-D: | | D1: 27
| | | NR | | D2: 21
| | | | | Nausea:
| | | | | D1: 19
| | | | | D2: 14
| | | | | Somnolence (fatigue):
| | | | | D1: asthenia-11
| | | | | D2: asthenia-7
Author: | Research objective: | Inclusion criteria: | Mean age (years): | PAR 16% vs. placebo 43% in reappearance of depression (P < 0.01) and in time to reappearance (P < 0.001) over 1-year study. Sig advantage was seen for PAR 3% vs. placebo 19% in first 4mos in relapse prevention (P < 0.01) and in time to relapse (P < 0.005), and later period of treatment in preventing recurrence PAR 14% vs. placebo 30% (P < 0.05) | Dizziness | Overall attrition rate:
Montgomery and Dunbar 1993 | Efficacy of PAR in relapse prevention and prophylaxis of depression | - Adults 18 to 65; - Diagnosed with MDD according to DSM III or IV; - Minimum HAM-D score of 18; - Recurrence of at least 3 episodes | D1: 45.9 | | D1: 4 Vertigo | NR
Country and setting: | Duration of study: | Exclusion criteria: | D2: 48.3 | | Insomnia: | ITT Analysis
NR (UK) | 1 year | - Pregnant; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - ECT within last 3 mos; - Neuroleptics | Sex (% female): | | D1: 13 | Yes
5 psychiatric outpatient centers | Study design: | | D1: 79 | | Nausea: | Quality rating:
Funding: | RCT | | D2: 78 | | D1: 8 | Fair
Second author is with SmithKline Beecham | Overall study N: | | Race (% white): | | Suicidality:
NR | 135 | | NR | | D1: 1 Suicide
| Intervention: | | Baseline (HAM-A): | | Sweating (increase):
| D1: Paroxetine: 20–30 mg/d | | NR | | D1: 5
| D2: Placebo | | Baseline HAM-D:
| | | D1: 5.5 (1.9)
| | | D2: 5.7 (1.8)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | CIT 20 and 40 mg groups showed a sig advantage in relapse(overall 10.5% ciotalopram 20 8% and CIT 40 12%) compared with placebo (31%) (P < 0.05) and in survival analysis of time to relapse (P = 0.01 and P = 0.02, respectively) | NR | Overall attrition rate:
Montgomery et al., 1993 | A total of 147 patients who had responded in a placebo-controlled study to 6 wks treatment of an episode of DSM-III-R major depression with either 20 mg or 40 mg CIT were randomized double-blind to continue on same dose of CIT or to receive placebo during a 24-wk study of efficacy of CIT in prevention of relapse | - Adults 18 to 70; - Diagnosed with MDD according to DSM-III or -IV; - MADRS of at least 22 in initial study; - Had response to CIT (20 or 40 mg) resulting in MADRS score of 12 or less | NR | | | 26.5% for reasons other than relapse
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | | | ITT Analysis
NR | 24 wks | - Pregnant; - Lactating; - Concomitant psychotherapeutic or psychotropic medications; - Duration of depression more than 12 mos | NR | | | Yes
Multicenter (18) | Study design: | | Race (% white): | | | Quality rating:
Funding: | RCT | | NR | | | Fair
H Lundbeck A/S employs second author | Overall study N: | | Baseline HAM-A:
| 147 | | NR
| Intervention: | | Baseline HAM-D:
| D1: Citalopram: 20 mg/d | | NR
| D2: Citalopram: 40 mg/d
| D3: Placebo
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | HAM-D Response: | Overall adverse events: | Overall attrition rate:
Poirier and Boyer, 1999 | To compare efficacy and safety of PAR and VEN in patients with treatment resistant depression | - Diagnosed with MDD according to DSM-III or -IV; - Depression duration less than 8 mos; - For current episode, history of resistance to 2 previous antidepressant treatments, 2nd of which had to have been prescribed by investigator prior to study; - Adults 19 to 60; - HAM-D ≥ 18 | D1: 42.5 | VEN 45% | D1: 69 | 11.4%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 44.1 | PAR 36% | D2: 63 | ITT Analysis
France inpatients and outpatients | 4 wks | - Pregnant/Lactating; - Suicidal tendencies; - Illicit drug or alcohol abuse; - Concomitant psychotheraputic or psychotropic medications; - ECT; - Additional mental illnesses or organic mental disorder not related to depression; - VEN or PAR during current episode | Sex (% female): | (P = 0.07) | Diarrhea: | Yes
Funding: | Study design: | | D1: 73.8 | HAM-D Remission: | D1: 2.9 | Quality rating:
Wyeth-Lederle | RCT | | D2: 69.4 | VEN 37% | D2: 4.2 | Fair
| Overall study N: | | Race (% white): | PAR 18% | Headache:
| 123 | | NR | (P = 0.02) | D1: 6.7
| Intervention: | | Baseline HAM-A: | Mean change in HAM-D: | D2: 4.2
| D1: Paroxetine: 30–40 mg/d | | NR | VEN -11.1 (8.5) | Insomnia:
| D2: Venlafaxine: 200–300 mg/d | | Baseline HAM-D: | PAR -10.2 (6.8) | D1: 4.8
| | | D1: 24.6 (3.9) | (P = 0.55) | D2: 1.0
| | | D2: 24.5 (4.1) | CGI-I improvement (1 or 2): | Nausea:
| | | | VEN 73% | D1: 14.3
| | | | PAR 84% | D2: 15.6
| | | | (P = 0.39) | Somnolence (fatigue):
| | | | | D1: 2.9
| | | | | D2: 9.4
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Time to depression relapse was sig longer (P = 0.013) and cumulative rate of relapse was sig lower in patients who received ESC (26% ESC vs. 40% placebo; hazard ratio = 0.56; P = 0.01). ESC-treated subjects had sig lower depression ratings than placebo-treated patients | Headache: | Overall attrition rate:
Rapaport et al., 2004 | Evaluation of efficacy and safety of continuation ESC treatment | - Adults 18 to 81; - Diagnosed with MDD according to DSM-III or -IV; - MADRS of 22 or more | D1: 42.9 | | D1: 8.8 | 55%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 41.8 | | D2: 8.6 | ITT Analysis
United States | 36 wks | - Pregnant; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Suicidial tendencies | Sex (% female): | | Insomnia: | Yes
Multicenters (53 sites) | Study design: | | D1: 60.2 | | D1: 5.5 | Quality rating:
Funding: | RCT | | D2: 62.4 | | D2: 7.5 | Fair
Forest Labs | Overall study N: | | Race (% white): | | Nausea:
| 274 | | D1: 86.7 | | D1: 5.5
| Intervention: | | D2: 84.9 | | D2: 4.3
| D1: Escitalopram: 10–20 mg/d | | Baseline HAM-A:
| D2: Placebo | | NR
| | | Baseline HAM-D:
| | | D1: 7.7 (4.6)
| | | D2: 6.6 (4.6)
| | | (P < = 0.05)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Relapse rates lower among patients who continued to take FLUO compared with those transferred to placebo in both first interval, after 24 total wks of treatment (FLUO, 26.4%; placebo, 48.6%, P < 0.001), and second interval, after 38 total wks of treatment (FLUO, 9.0%; placebo, 23.2% P < 0.04) | NR | Overall attrition rate:
Reimherr et al., 1998 | To determine prospectively optimal length of therapy in long-term, placebo-controlled continuation study of patients who responded to acute FLUO treatment for major depression | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 16; - Type II bipolar disorder | D1: 40.1 | In third interval, after 62 total wks of treatment, rates were not sig different between groups (FLUO, 10.7%; placebo, 16.2% P = 0.54) | | N/A
Country and setting: | Duration of study: | Exclusion criteria: | D2: 40.3
United States | 50 wks | - Type I bipolar disorder | D3: 40.3 | | | ITT Analysis
5 outpatient psychiatric clinics | Study design: | | D4: 40.5 | | | Yes
Funding: | RCT | | Sex (% female): | | | Quality rating:
Lilly Research Laboratories | Overall study N: | | D1: 64.9 | | | Fair
| 395 (randomized) | | D2: 70
| Intervention: | | D3: 62.7
| D1: Fluoxetine 20 mg/d 14 wks | | D4: 80.2
| D2: Fluoxetine 20 mg/d 38 wks | | Race (% white):
| D3: Fluoxetine 20 mg/d 50 wks | | D1: 97.9
| D4: Placebo | | D2: 96
| | | D3: 93.1
| | | D4: 87.5
| | | Baseline HAM-A:
| | | NR
| | | Baseline HAM-D:
| | | D1: 20.5 (3.4)
| | | D2: 20.5 (3.6)
| | | D3: 20.5 (3.6)
| | | D4: 21.5 (3.7)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | # relapses (defined as a MADRS>25 and clinical judgment of investigator): | Constipation: | Overall attrition rate:
Robert et al., 1995 | To evaluate whether there was therapeutic benefit in continuation treatment for patients with depression who had responded favorably to CIT | - Diagnosed with MDD according to DSM-III or -IV; - MADRS < 12 after 8 wks on CITor placebo | D1: 49.5 | CIT = 21 (13.8%) | D1: 15 | N/A
Country and setting: | Duration of study: | Exclusion criteria: | D2: 46.5 | placebo = 18 (24.3%) P = 0.04 | D2: 5 | ITT Analysis
France, multicenter outpatient trial | 6 mos (24 wks) | - Concomitant psychotheraputic or psychotropic medications; - Depression lasted for >3 mos | Sex (% female): | | | Yes
Funding: | Study design: | | D1: 69% | | | Quality rating:
NR | RCT | | D2: 73% | | | Fair
| Overall study N: | | Race (% white):
| 226 | | NR
| Intervention: | | Baseline HAM-A:
| D1: Citalopram: 20–60 mg/d | | NR
| D2: Placebo | | Baseline HAM-D:
| | | D1: 4.7 (3.6)
| | | D2: 5 (3.4)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | HAM-D Remission at end of study: | NR | Overall attrition rate:
Rush et al., 2006 | To compare remission rates among three antidepressants in patients with major depressive disorder that did not respond or tolerate an SSRI (CIT) | - Adults 18 and over; - QIDS-C-16 > 5 | D1: 41.9 | - BUP 21.3%; - SER 17.6%; - VEN XR 24.8% (P = 0.16) | | NR
Country and setting: | Duration of study: | Exclusion criteria: | D2: 42.6 | QIDS-SR-16 Remission: | | ITT Analysis
United States | 14 wks | - NR | D3: 41.1 | - BUP 25.5%; - SER 26.6%; - VEN XR 25.0% (P = NR; ns) | | Yes
Primary and psychiatric public and private practices | Study design: | | Sex (% female): | QIDS-SR-16 Response: | | Quality rating:
Funding: | RCT | | D1: 56.9 | - BUP 26.1%; - SER 26.7%; - VEN XR 25.0% (P = NR; ns) | | Good
NIMH | Overall study N: | | D2: 55.0 | | | Effectiveness trial
| 727 | | D3: 64.0
| Intervention: | | Race (% white):
| D1: Bupropion: SR 150–400 mg/d | | D1: 74.9
| D2: Sertraline: 50–200 mg/d | | D2: 78.2
| D3: Venlafaxine: XR 37.5–375 mg/d | | D3: 74.4
| | | Baseline HAM-A:
| | | NR
| | | Baseline HAM-D:
| | | D1: 18.5 (7.7)
| | | D2: 19.3 (6.9)
| | | D3: 18.9 (7.3)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Relapse rates 25 wks: | Diarrhea: | Overall attrition rate:
Schmidt et al., 2000 | To assess efficacy of FLUO 20 mg daily vs. FLUO 90 mg wkly vs. placebo in continuation treatment of MDD | - Minimum HAM-D score of 18; - Diagnosed with MDD according to DSM-III or -IV; - Adults 18 or older; - CGI-S > 4 | D1: 40.9 | - FLUO 90 37%; - FLUO 20 26%; - placebo 50% | D1: 8.4 | NA
Dinan et al and Schmidt et al. 2002 and 2001 | Duration of study: | Exclusion criteria: | D2: 41.7 | | D2: 1.6 | ITT Analysis
Country and setting: | 25 wks | - Pregnant; - Lactating; - Additional mental illnesses or organic mental disorder; - Clinically sig medical disease | D3: 42 | | D3: 4.9 | Yes
United States | Study design: | | Sex (% female): | | Dizziness: | Quality rating:
Multicenter | RCT | | D1: 68.4 | | D1: 5.3 | Fair
Funding: | Overall study N: | | D2: 70.9 | | D2: 5.8
Eli Lilly | 501 | | D3: 63.9 | | D3: 4.9
| Intervention: | | Race (% white): | | Headache:
| D1: Fluoxetine 90 mg/wk | | D1: 91.6 | | D1: 10.5
| D2: Fluoxetine 20 mg/wk | | D2: 86.8 | | D2: 12.2
| D3: Placebo | | D3: 91.0 | | D3: 9.0
| | | Baseline HAM-A: | | Insomnia:
| | | NR | | D1: 7.4
| | | Mean HAM-D score at baseline: | | D2: 5.3
| | | NR | | D3: 4.1
| | | | | Nausea:
| | | | | D1: 6.3
| | | | | D2: 4.2
| | | | | D3: 7.4
| | | | | Somnolence (fatigue):
| | | | | D1: 8.4
| | | | | D2: 10.6
| | | | | D3: 8.2
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | HAM-D-6.4 (at day 56) placebo 6.5 (at day 56) VEN XR | Overall adverse events: | Overall attrition rate:
Simon et. al., 2004 | To evaluate efficacy of VEN XR in prevention of relapse of depression by continuation treatment | - Adults 18+; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of >20; - No greater than 20% decrease in HAM D between evaluations | D1: 43 | MADRS-7.2 (56 day) placebo 7.4 (day 56) VEN XR | D1: 97% | 62%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 41 | 6-mo relapse rates were sig higher for placebo (52%) than for VEN XR (28%) (P < 0.001) | D2: 93% | ITT Analysis
United States | 8 wk acute phase; 6 mo continuation phase | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Clinically sig medical disease; - Investigational drug use; - Suicidial tendencies; - Seizure; - Antipsychotic medication; - FLUO within 30 days | Sex (% female): | | Cardiovascular adverse events: | Yes
Multicenter study | Study design: | | D1: 102 (66%) | | D1: 6% | Quality rating:
Funding: | RCT | | D2: 86 (62%) | | D2: 2% | Fair
Wyeth | Overall study N: | | Race (% white): | | Constipation:
| 318 entered relapse prevention study (490 in acute phase) | | NR | | D1: 7%
| Intervention: | | Baseline HAM-A: | | D2: 3%
| D1: Venlafaxine XR 75–225 mg/d | | NA | | Sexual dysfunctional:
| D2: Placebo | | Baseline HAM-D: | | D1: 5%
| | | D1: 6.5 | | D2: 2%
| | | D2: 6.4 | | Sweating (increase):
| | | | | D1: 11%
| | | | | D2: 5%
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Incidence of recurrence was lower in FLUV (12.7%) than placebo (35.1%) (P < 0.001) | Changes in weight (decrease): | Overall attrition rate:
Terra and Montgomery, 1998 | To evaluate efficacy of FLUV in reducing risk of new episodes of depression | - Adults 18 to 70; - Diagnosed with MDD according to DSM-III or -IV; - Acute phase:, MADRS>25; - History of at least 2 episodes of major depression in previous 5 yrs | D1: 44.5 | Highly sig diff between FLUV and placebo in distribution of time to recurrence (P < 0.001). time to recurrence sig longer for FLUV and placebo (181 vs. 96 days, P < 0.005) | D1: 1 | NR
Country and setting: | Duration of study: | Exclusion criteria: | D2: 45.0 | | Headache: | ITT Analysis
France | 1 yr | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications, but benzos and hypnotics were also allowed during acute/continuation phases if started more than 3 mos before start; - Clinically sig medical disease; - ECT within last 2 wks; - Epilepsy or history of convulsions,; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse | Sex (% female): | | D1: 5 | Yes
Multicenter, outpatient | Study design: | | D1: 70 | | Sexual dysfunctional: | Quality rating:
Funding: | RCT | | D2: 77.7 | | D1: 0 | Fair
NR | Overall study N: | | Race (% white): | | Somnolence (fatigue):
| 204 (number enrolled in double-blind prophylactic treatment phase) | | NR | | D1: 4
| Intervention: | | Baseline HAM-A:
| D1: Fluvoxamine: 100 mg/d | | NR
| D2: Placebo | | Baseline HAM-D:
| | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Relapse rates during 40-wk double blind continuation phase were 19.7% for MIR and 43.8% for placebo (P < 0.001) | Overall adverse events: | Overall attrition rate:
Thase et al., 2001 | Evaluate efficacy and safety of mirazapine in continuation phase therapy | - Adults 18 and up; - Diagnosed with MDD according to DSM-III or -IV | D1: 40.1 | Between group diff in distribution of relapse risk over time was statistically sig(P < 0.001) | D1: 36 | 46% in acute phase 11.8% in continuation phase
Country and setting: | Duration of study: | Exclusion criteria: | D2: 40.7 | Mean HAM-D for MIR was 6.1(7.2) and for placebo 10.7(8.8) | D2: 30 | ITT Analysis
United States | Acute Phase- 8–12 wks | - Pregnant; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Investigational drug use | Sex (% female): | | Cardiovascular adverse events: | Yes
Multicenter (12) | Continuation Phase- up to 40 wks | | D1: 52.6 | | D1: 21 | Quality rating:
Outpatient | Study design: | | D2: 48.8 | | D2: 23 | Fair
Funding: | RCT | | Race (% white): | | Changes in weight (increase):
Organon Inc | Overall study N: | | D1: 93.4 | | D1: 7.9
| 410 for open-label; 156 randomized to continuation treatment | | D2: 86.3 | | D2: 7.3
| Intervention: | | Baseline HAM-A: | | Dizziness:
| D1: Mirtazapine: 15–45 mg/d | | NR | | D1: 3
| D2: Placebo | | Baseline HAM-D: | | D2: 4
| | | D1: 5.0 (4.0) | | Headache:
| | | D2: 7.7 (6.7) | | D1: 12
| | | | | D2: 16
| | | | | Somnolence (fatigue):
| | | | | D1: 4
| | | | | D2: 1
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Relapse during 32 wk continuation | Overall adverse events: | Overall attrition rate:
Van Moffaert et al., 1995 | To evaluate comparative efficacy and tolerability of SER and FLUO in acute and continuation treatment of MDD | - Adults 18 to 80; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18 | D1: 46.1 | SER 10/49 (20%) | D1: 48 | 17%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 48.4 | FLUO 13/53 (23%) | D2: 54 | ITT Analysis
Belgium, multicenter trial (15 psychiatric centers, in- and out-patient) | 8 wks acute phase, responders and partial responders could continue in 24 wk continuation phase | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidial ideation; - MADRS score greater than 40; - History of mania, hypomania or psychosis; - Concomitant serotonergic drugs (including lithium and carbamazepine | Sex (% female): | Partial relapse during 32 wk continuation | Cardiovascular adverse events: | Yes
Funding: | Study design: | | D1: 66.3 | SER 6/49 (12%) | D1: 4 | Quality rating:
Pfizer | RCT | | D2: 65.9 | FLUO 2/53 (4%) | D2: 4 | Fair
| Overall study N: | | Race (% white):
| Acute 165 | | NR
| Continuation 105 | | Baseline HAM-A:
| Intervention: | | NR
| D1: Sertraline: 50–100 mg/d | | Baseline HAM-D:
| D2: Fluoxetine: 20–40 mg/d | | D1: 24.5
| | | D2: 23.2
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | 423 patients were randomized to continuation treatment | Overall adverse events: | Overall attrition rate:
Weihs et al., 2002 | To evaluate safety and efficacy of BUP SR for decreasing risk for relpase of depression in patients who responded to BUP SR | - Adults 18 to 18 and older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18 | D1: 39.4 | A statistically sig diff in favor of BUP SR (37% relapse) over placebo (52% relapse) was seen in time to treatment intervention for depression when survival curves were compared (log-rank test, P = 0.004) | D1: 54 | 75.7%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 39.9 | Statistically sig separation between BUP SR and palcebo began at double-blind wk 12 (P < 0.05) | D2: 46 | ITT Analysis
United States outpatient, mulitcenter | Up to one yr (52 wks) | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Investigational drug use; - Suicidial tendencies; - Propensity for seizures | Sex (% female): | AEs in BUP SR-treated patients accounted for 9% and 4% of discontinuations from open-label and double-blind phases, respectively | Cardiovascular adverse events: | Yes
Funding: | Study design: | | D1: 66 | | D1: mean sbp -1.1 | Quality rating:
GlaxoSmithKline | RCT | | D2: 64 | | D2: Mean sbp +2.1 | Fair
| Overall study N: | | Race (% white): | | Changes in weight (decrease):
| 828 in open label phase; 423 entered double-blind phase | | D1: 88 | | D1: -2.5 lbs
| Intervention: | | D2: 86 | | D2: 0
| D1: Bupropion: 300 mg/d | | Baseline HAM-A: | | Constipation:
| D2: Placebo | | NR | | D1: 1
| | | Baseline HAM-D: | | D2: 1
| | | NR | | Diarrhea:
| | | | | D1: 1
| | | | | D2: 5
| | | | | Dizziness:
| | | | | D1: 1
| | | | | D2: 3
| | | | | Headache:
| | | | | D1: 16
| | | | | D2: 13
| | | | | Insomnia:
| | | | | D1: 3
| | | | | D2: 3
| | | | | Nausea:
| | | | | D1: 4
| | | | | D2: 2
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | ANALYSIS OF RECURRENCE Kaplan Meier analysis, SER vs placebo, log rank test = 1.55, df = 1, (P = 0.21) Cumulative survival function SER = 39%, median survival 92 wks placebo 31%, median survival 48 wks | NR | Overall attrition rate:
Wilson et al., 2003 | To examine efficacy of SER in preventing recurrence of depression in older people living in community | - Adults 65 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18; - Geriatric Mental State AGECAT depression ≥ 3 | D1: 76.6 | Reduction in risk of recurrence: 8.4% over 100 wks (SER vs. placebo) | | 72.6%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 76.8 | % experiencing recurrence in first 26 wks: | | ITT Analysis
UK, outpatient clinic(s) | 8 wk treatment phase and a 16–20 wk continuation phase (open-label ser) 100 wk randomized, double-blind phase (ser and placebo) (article focuses on results of this maintenance phase) | - Concomitant psychotheraputic or psychotropic medications; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Sig suicidal or delusional experiences; - MMSE ≤ 11; - Concomitant drugs excluded include psychotropic drugs, warfarin, and anticonvulsants | Sex (% female): | SER = 57% | | N/A because recurrence trial
Funding: | Study design: | | D1: 66.1 | placebo = 60% | | Quality rating:
NR | RCT | | D2: 75.4 | % experiencing recurrence between wks 27 and 52 | | Fair
| Overall study N: | | Race (% white): | SER = 16%
| 113 (randomised to double-blind phase) | | NR | placebo = 32%
| Intervention: | | Baseline HAM-A: | Cox regression model predicting recurrence:
| D1: Sertraline: 50–100 mg/d | | NR | hazard ratio (95% CI) included variables:
| D2: Placebo | | Baseline HAM-D: | SER vs. placebo = 1.21 (0.704, 2.082)
| | | D1: 20.7 (3.7)
| | | D2: 20.3 (3.3)

Evidence Table 3. KQ3: Efficacy or effectiveness of antidepressants for treating depression and its accompanying symptoms

Study Characteristics | Research Objective | Inclusion/Exclusion | Baseline Characteristics | Health Outcome Results | Adverse Events (%) | Analysis and Quality Rating
| Duration
| Study Design
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Anxiety outcomes: | Overall adverse events: | Overall attrition rate:
Baldwin et al., 1996 | To compare efficacy of NEF and PAR for treatment of moderate-severe major depression | - Adults 18 or older; - Outpatients; - MDD according to DSM-III-R; - Minimum HAM-D-17 score of 18; - Rated at least moderately ill on CGI-S | D1: 38.3 | Improvement in HAM-A score was 6.5 for NEF vs. 8.0 for PAR (95% CI for diff between groups: -0.7 to 3.8) | D1: 84 | 23.1%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 37.9 | | D2: 78 | ITT Analysis:
Europe, multicenter (20 psychiatric clinics) | 8 wks | - Additional mental illnesses or organic mental disorder; - Concomitant psychotherapeutic medications; - ECT within 6 mos; - Substance abuse or dependence (within 1 yr); - Clinically sig medical disease; - Pregnant or lactating; - Suicidal (serious risk); - Lack of response of current MDD episode to 2 prior courses of therapy | Sex (% female): | | Dizziness: | Yes
Funding: | Study design: | | D1: 60 | | D1: 17 | Quality rating:
Bristol-Myers Squibb | RCT | | D2: 50 | | D2: 9 | Fair
| Overall study N: | | Race (% white): | | Headache:
| 206 randomized; 196 included in analysis | | D1: NR | | D1: 35
| Intervention: | | D2: NR | | D2: 25
| D1: Nefazodone 200–600 mg/d (mean 472) | | Baseline HAM-D-17: | | Nausea:
| D2: Paroxetine 20–40 mg/d (mean 32.7) | | D1: 24.6 | | D1: 27
| | | D2: 24.8 | | D2: 30
| | | Baseline HAM-A: | | Somnolence:
| | | D1: 19 | | D1: 16
| | | D2: 18.3 | | D2: 24
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Sleep outcomes | Diarrhea: | Overall attrition rate:
Beasley et al., 1991 | To compare FLUO and TRA for treatment of major depression and to evaluate activation and sedation effects | - Adults 18 or older; - Outpatients; - MDD according to DSM-III; - Minimum HAM-D-21 score of 20; - Duration at least 4 wks | D1: 40.0 | Improvement in HAM-D Sleep Disturbance Factor was 1.6 points in FLUO-treated group vs. 2.7 points in TRA group (P = 0.001) | D1: 7.7 | 34.1%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 40.0 | | D2: 3.3 | ITT Analysis:
United States, multicenter (3 sites) | 6 wks | - Additional mental illnesses or organic mental disorder; - Concomitant psychotherapeutic medications; - Substance abuse (within one yr); - Placebo response during lead-in | Sex (% female): | | Dizziness: | Yes
Funding: | Study design: | | D1: 64.6 | | D1: 6.2 | Quality rating:
Eli Lilly and Company | RCT | | D2: 68.8 | | D2: 21.3 | Fair
| Overall study N: | | Race (% white): | | Headache:
| 126 randomized; 120 included in analysis | | D1: 98.5 | | D1: 21.5
| Intervention: | | D2: 98.4 | | D2: 27.9
| D1: Fluoxetine 20–40 mg/d (median 20 mg/d) | | Baseline HAM-D-21: | | Insomnia:
| D2: Trazodone 50–400 mg/d (median 250 mg/d) | | D1: 23.4 (2.7) | | D1: 9.2
| | | D2: 24.3 (3.6) | | D2: 3.3
| | | Baseline HAM-D Sleep Factor: | | Nausea:
| | | D1: 3.8 (1.7) | | D1: 27.7
| | | D2: 3.8 (1.8) | | D2: 24.6
| | | Baseline HAM-A: | | Somnolence:
| | | NR | | D1: 20.0
| | | | | D2: 45.9
| | | | | Sweating (increase):
| | | | | D1: 4.6
| | | | | D2: 0
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Depression outcomes in patients with pain: | Cardiovascular adverse events (high systolic BP): | Overall attrition rate:
Brannan et al., 2005 | To evaluate efficacy of DUL for treatment of pain and depression in patients with major depression and painful physical symptoms | - Adults 18 or older; - Outpatients; - MDD according to DSM-IV; - Minimum HAM-D-17 score of 15; - CGI-S of 4 or more; - BPI average pain score of 2 or more | D1: 40.8 | Mean HAM-D-17 improvement was similar for both groups (-10.9 for DUL vs. -10.3 for placebo, P = 0.544). Response rates were similar for DUL and placebo (42% vs. 40%, P = 0.901). Remission rates were also similar (23% vs. 24%, P = 0.887) | D1: 4.1 | NR
Country and setting: | Duration of study: | Exclusion criteria: | D2: 40.3 | Pain outcomes: | D2: 4.1 | ITT Analysis
United States, multicenter (25 psychiatry clinics) | 7 wks | - Additional mental illness or organic mental disorder; - Substance abuse or dependence; - Clinically sig medical disease; - Suicidal (serious risk); - Primary pain disorder with diagnosis such as arthritis, migraine, or fibromyalgia; - Treatment resistant depression or lack of response of current MDD episode to 2 prior courses of therapy | Sex (% female): | Mean reduction in BPI average pain was 2.32 (0.21) for DUL-treated patients compared to 1.80 (0.20) for those receiving placebo (P = 0.066). Mean changes in BPI worst pain, least pain, and current pain did not differ between groups (P > 0.10 for all). Mean changes in VAS overall pain did not differ between groups (values NR and P = NR) | (high diastolic BP): | Yes
Funding: | Study design: | | D1: 68.1 | | D1: 1.6 | Quality rating:
Eli Lilly and Company | RCT | | D2: 62.4 | | D2: 5.5 | Fair
| Overall study N: | | Race (% white): | | Changes in weight (decrease):
| 282 randomized; 268 included in analysis | | D1: 81.6 | | D1: 7.1
| Intervention: | | D2: 79.4 | | D2: 0.7
| D1: Duloxetine 60 mg/d | | Baseline HAM-D-17: | | Constipation:
| D2: Placebo | | D1: 23.4 (3.5) | | D1: 9.2
| | | D2: 22.4 (3.4) | | D2: 6.4
| | | BPI average pain: | | Diarrhea:
| | | D1: 4.85 (1.69) | | D1: 17.7
| | | D2: 4.62 (1.54) | | D2: 10.6
| | | Baseline 100mm VAS (overall pain): | | Dizziness:
| | | D1: 49.8 (22.2) | | D1: 9.9
| | | D2: 46.8 (19.7) | | D2: 5.7
| | | Baseline HAM-A: | | Headache:
| | | NR | | D1: 14.2
| | | | | D2: 13.5
| | | | | Insomnia:
| | | | | D1: 10.6
| | | | | D2: 6.4
| | | | | Nausea:
| | | | | D1: 39.7
| | | | | D2: 9.9
| | | | | Fatigue:
| | | | | D1: 16.3
| | | | | D2: 1.4
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Anxiety outcomes | Changes in weight (decrease): | Overall attrition rate:
Chouinard et al., 1999 | To evaluate antidepressant and anxiolytic efficacy of FLUO and PAR in patients with major depression | - Outpatients; - MDD according to DSM-III-R; - Minimum HAM-D-21 score of 20 and score of 2 on HAM-D item 1; - Depression symptoms for at least 1 mo | D1: 41.2 | Improvements in Covi Anxiety Scale, State-Trait Anxiety Inventory, and HAM-D Anxiety/Somatization Factor were similar in 2 treatment groups (scores NR; P = NR) | D1: 11.9 | 36%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 40.6 | Mean improvement from baseline in HAM-D Psychic Anxiety item was 1.21 for FLUO and 1.17 for PAR (P = 0.823). Improvement from baseline in HAM-D Agitation item was 0.39 for FLUO and 0.40 for PAR (P = 0.978) | D2: 2.9 | ITT Analysis:
Canada, multicenter (8 sites) | 12 wks | - Additional mental illnesses or organic mental disorder; - Concomitant or recent psychotherapeutic drugs; - ECT within 2 mos; - Concurrent formal psychotherapy; - Illicit drug or alcohol abuse (past or present); - Suicidal (sig risk); - Pregnant or lactating; - Clinically sig medical disease | Sex (% female): | | (increase): | Yes
Funding: | Study design: | | D1: 59.4 | | D1: 13.9 | Quality rating:
SmithKline Beecham | RCT | | D2: 63.7 | | D2: 10.8 | Fair
| Overall study N: | | Race (% white): | | Constipation:
| 203 randomized; 198 included in analysis | | D1: 98.0 | | D1: 4.0
| Intervention: | | D2: 95.1 | | D2: 17.7
| D1: Fluoxetine 20–80 mg/d (mean 27.5) | | Baseline HAM-D-21: | | Diarrhea:
| D2: Paroxetine 20–50 mg/d (mean 25.5) | | D1: 25.45 (0.46) | | D1: 18.8
| | | D2: 25.91 (0.46) | | D2: 11.8
| | | Baseline HAM-A: | | Headache:
| | | NR | | D1: 36.6
| | | | | D2: 36.3
| | | | | Insomnia:
| | | | | D1: 22.8
| | | | | D2: 26.5
| | | | | Nausea:
| | | | | D1: 31.7
| | | | | D2: 37.3
| | | | | Sexual dysfunction:
| | | | | D1: 7.3 of males
| | | | | D2: 10.8 of males
| | | | | Somnolence:
| | | | | D1: 16.8
| | | | | D2: 18.6
| | | | | Suicidality:
| | | | | D1: 2.0
| | | | | D2: 2.0
| | | | | Sweating (increase):
| | | | | D1: 5.9
| | | | | D2: 13.7
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Depression outcomes in patients with melancholia: | Headache: | Overall attrition rate:
Clerc et al., 1994 | To compare efficacy and short-term safety of VEN and FLUO in hospitalized patients with MDD and melancholia | - Adults 18 or older; - Hospitalized patients; - MDD with melancholia according to DSM-III-R; - Depression duration at least 1 mo; - MADRS at least 25 | D1: 53.6 | Mean decrease in HAM-D score was sig better for VEN (-18) compared to FLUO (-12.4) (P = 0.027) | D1: 9 | 23%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 49.0 | HAM-D response rates were 73% in VEN-treated group compared to 50% in FLUO-treated group. Diff not statistically sig (P = NR) | D2: 3 | ITT Analysis
France and Belgium, multicenter (hospitals) | 6 wks | - Clinically sig medical disease; - Concurrent ECT; - Concurrent psychotherapy | Sex (% female): | | Insomnia: | Yes
Funding: | Study design: | | NR | | D1: 9 | Quality rating:
Wyeth-Ayerst | RCT | | Race (% white): | | D2: 9 | Poor
| Overall study N: | | NR | | Nausea: | High differential attrition
| 68 | | Baseline HAM-D-21: | | D1: 12
| Intervention: | | D1: 29.7 (4.2) | | D2: 9
| D1: Fluoxetine 40 mg/d | | D2: 29.1 (5.2)
| D2: Venlafaxine 200 mg/d | | Baseline HAM-A:
| | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Sleep outcomes | Constipation: | Overall attrition rate:
Cunningham et al., 1994 | To compare efficacy and safety of TRA, VEN, and placebo in outpatients with major depression | - Adults 18 or older; - Outpatients; - MDD according to DSM-III-R; - Minimum HAM-D-21 score of 20; - Depression duration at least 1 mo | Overall: 40.7 | HAM-D Sleep Factor scores at endpoint were sig better for TRA (1.42) than for VEN (2.22; P < 0.05) and placebo (1.95; P < 0.05) | D1: 9 | 33.78%
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | | D2: 22 | ITT Analysis:
United States and Canada, multicenter (6 sites) | 6 wks | - Additional mental illnesses or organic mental disorder; - Concomitant or recent psychotherapeutic drugs; - Drug or alcohol dependence (within 2 yrs); - ECT within 14 days; - Investigational drug use within 2 yrs; - Suicidal (serious risk); - Pregnant, lactating, or child-bearing potential without contraception; - Unstable medical disease; - History of seizure disorder; - Placebo response during washout (20% improvement on HAM-D) | NR | | D3: 4 | Yes
Funding: | Study design: | | Race (% white): | | Dizziness: | Quality rating:
Wyeth-Ayerst | RCT | | NR | | D1: 36 | Fair
| Overall study N: | | Baseline HAM-D-21: | | D2: 17
| 227 randomized; 225 included in analysis | | D1: 24.66 | | D3: 5
| Intervention: | | D2: 25.02 | | Nausea:
| D1: Trazodone 150–400 mg/d | | D3: 24.41 | | D1: 19
| D2: Venlafaxine 75–200 mg/d | | Baseline HAM-D Sleep Factor: | | D2: 44
| D3: Placebo | | D1: 3.60 | | D3: 5
| | | D2: 3.52 | | Somnolence:
| | | D3: 3.20 | | D1: 61
| | | Baseline HAM-A: | | D2: 43
| | | NR | | D3: 12
| | | | | Sweating (increase):
| | | | | D1: 3
| | | | | D2: 12
| | | | | D3: 1
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Response and remission rates did not differ sig among DUL 120 mg (71%; 52%), DUL 80 mg (65%; 46%) and PAR (74%; 44%) (P = NR) | Headache: | Overall attrition rate:
Detke, 2004 | To determine comparative efficacy and safety of DUL and PAR for treatment of MDD | - Adults 18 or older; - Met DSM-IV and MINI criteria for MDD; - CGI-S rating > 4; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 15 | D1: 43.1 | PGI scores were sig superior in patients receiving PAR than patients receiving 80 mg/d DUL (P < 0.05) | D1: 5.3 | 13.3%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 44.7 | Improvments in pain scores similar between active medications: DUL 80 mg and placebo (P = 0.063), DUL 120 mg and placebo (P = 0.086). Improvement in pain was superior to placebo (P = 0.035) | D2: 5.4 | ITT analysis:
United States Multicenter, university clinics | 8 wks | - Pregnant; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies | D3: 42.0 | | D3: 4.7 | Yes
Funding: | Study design: | | D4: 42.0 | | Nausea: | Quality rating:
Eli Lilly | RCT | | Sex (% female): | | D1: 12.6 | Fair
| Overall study N: | | D1: 70 | | D2: 5.4
| 367 | | D2: 70 | | D3: 11.6
| Intervention: | | D3: 58 | | Somnolence (fatigue):
| D1: Duloxetine 80 mg/d | | D4: 58 | | D1: 2.1
| D2: Duloxetine 120 mg/d | | Race (% white): | | D2: 7.5
| D3: Paroxetine: 20 mg/d | | D1: 95 | | D3: 5.8
| D4: placebo | | D2: 92 | | Sweating (increase):
| | | D3: 86 | | D1: 4.2
| | | D4: 86 | | D2: 8.6
| | | Baseline (HAM-A): | | D3: 5.8
| | | D1: 17.8
| | | D2: 18.0
| | | D3: 18.5
| | | D4: 17.9
| | | Mean HAM-D score at baseline:
| | | D1: 19.9 (3.6)
| | | D2: 20.2 (3.4)
| | | D3: 20.3 (4.1)
| | | D4: 19.9
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Pain outcomes: | Cardiovascular adverse events (new hypertension): | Overall attrition rate:
Detke et al., 2002 | To evaluate efficacy of DUL vs. placebo for treatment of MDD and associated painful symptoms | - Adults 18 or older; - MDD according to DSM-IV; - Minimum HAM-D-17 score of 15; - Other: CGI-S of 4 or more | D1: 42.44 | Mean reduction in 100mm VAS for overall pain was statistically sig greater for duloxetine (~8.5 mm) compared to placebo (~2.5 mm) (Mean change estimated from figure; P = 0.019) | D1: 0.8 | NR
Country and setting: | Duration of study: | Note: Painful symptoms not required for inclusion | D2: 42.34 | | D2: 0 | ITT Analysis
United States, multicenter (18 sites) | 9 wks | Exclusion criteria: | Sex (% female): | | Constipation: | Yes
Funding: | Study design: | - Additional mental illness or organic mental disorder; - Psychotherapy within 6 wks; - Substance abuse or dependence (within 1 yr); - Clinically sig medical disease; - Treatment resistant depression or lack of response of current MDD episode to 2 prior courses of therapy | D1: 65.0 | | D1: 13 | Quality rating:
Eli Lilly and Company | RCT | | D2: 68.0 | | D2: 1.6 | Fair
| Overall study N: | | Race (% white): | | Diarrhea:
| 245 | | D1: 87.0 | | D1: 18.7
| Intervention: | | D2: 84.4 | | D2: 6.6
| D1: Duloxetine 60 mg/d | | Baseline HAM-D-17: | | Dizziness:
| D2: Placebo | | D1: 21.42 (4.11) | | D1: 20.3
| | | D2: 21.14 (3.72) | | D2: 8.2
| | | Baseline 100mm VAS (overall pain): | | Insomnia:
| | | D1: 29.02 (25.10) | | D1: 15.4
| | | D2: 28.16 (23.21) | | D2: 5.7
| | | Baseline HAM-A: | | Nausea:
| | | NR | | D1: 46.3
| | | | | D2: 9.0
| | | | | Sexual dysfunction:
| | | | | NR but 2.4% of DUL-treated patients dropped out due to abnormal ejaculation
| | | | | Somnolence:
| | | | | D1: 21.1
| | | | | D2: 4.9
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Pain outcomes: | Cardiovascular adverse events (new hypertension): | Overall attrition rate:
Detke et al., 2002 | To evaluate efficacy of DUL compared to placebo for treatment of emotional and painful physical symptoms of MDD | - Adults 18 or older; - MDD according to DSM-IV; - Minimum HAM-D-17 score of 15; - CGI-S of 4 or more | D1: 41 | Mean reduction in VAS for overall pain was ~10 mm for DUL compared to ~6 mm for placebo at endpoint (change score estimated from figure; P = 0.037) | D1: 0.8 | 36.3%
Country and setting: | Duration of study: | Note: Painful symptoms not required for inclusion | D2: 41 | | D2: 0 | ITT Analysis
United States, multicenter (21 psychiatric clinical sites) | 9 wks | Exclusion criteria: | Sex (% female): | | Constipation: | Yes
Funding: | Study design: | - Additional mental illness or organic mental disorder; - Psychotherapy within 6 wks; - Substance abuse or dependence (within 1 yr); - Clinically sig medical disease; - Treatment resistant depression or lack of response of current MDD episode to 2 prior courses of therapy | D1: 66 | | D1: 14.1 | Quality rating:
Not reported but authors worked for Eli Lilly and Company | RCT | | D2: 71 | | D2: 5.0 | Fair
| Overall study N: | | Race (% white): | | Diarrhea:
| 267 | | D1: 78.1 | | D1: 10.2
| Intervention: | | D2: 78.4 | | D2: 7.9
| D1: Duloxetine 60 mg/d | | Baseline HAM-D: | | Dizziness:
| D2: Placebo | | D1: 20.33 (3.39) | | D1: 14.8
| | | D2: 20.46 (3.39) | | D2: 2.9
| | | Baseline 100mm VAS (overall pain): | | Headache:
| | | D1: 25.40 (23.98) | | D1: 25.8
| | | D2: 26.20 (23.10) | | D2: 22.3
| | | Baseline HAM-A: | | Insomnia:
| | | NR | | D1: 16.4
| | | | | D2: 13.7
| | | | | Nausea:
| | | | | D1: 29.7
| | | | | D2: 11.5
Author: | Research objective: | Inclusion criteria: | Mean age (yrs) in sleep disturbance subgroup: | Depression outcomes in patients with sleep disturbance: | Changes in weight (increase 7%): | Overall attrition rate:
Fava et al., 2002 | To compare efficacy and tolerability of FLUO vs. PAR and SER for treatment of depression associated with sleep disturbance | - Adults 18 or older; - Outpatients; - MDD according to DSM-IV; - Minimum HAM-D-17 score of 16 | D1: 42.2 | No statistically sig diffs between FLUO, PAR and SER in HAM-D-17 total score improvement (overall P = 0.853) | D1: 1.6 | 49%
Country and setting: | Duration of study: | Note: Sleep disturbance defined as HAM-D Sleep Disturbance Factor score of at least 4 | D2: 41.9 | Sleep outcomes: | D2: 9.0 | ITT Analysis:
United States, multicenter (15 sites) | 10 to 16 wks (depending on response to initial dose; all received 6 wks of therapy at effective dose) | Exclusion criteria: | D3: 43.0 | Improvement in HAM-D Sleep Disturbance factor was similar for all 3 groups: FLUO (-3.1), PAR (-2.9), SER (-3.1) (overall P = 0.852) | D3: 2.9 | Yes
Funding: | Study design: | - Additional mental illness or organic mental disorder; - Concomitant psychotropic medications; - Substance use or dependence (within 6 mos); - Pregnant, lactating, or child-bearing potential without contraception; - Clinically sig medical disease; - Suicide risk (serious); - Seizure within 1 yr; - Response to placebo in lead-in phase | Sex (% female) in sleep disturbance subgroup: | | Diarrhea: | Quality rating:
Eli Lilly and Company | RCT | | D1: 60.5 | | D3: 26.0 | Fair
| Overall study N: | | D2: 65.2 | | Headache:
| 284 overall; 125 in sleep disturbance subgroup | | D3: 63.4 | | D1: 25.0
| Intervention: | | Race (% white): | | D2: 21.9
| D1: Fluoxetine: 20–60 mg/d | | NR | | D3: 28.1
| D2: Paroxetine: 20–60 mg/d | | Baseline HAM-D-17 in sleep disturbance subgroup: | | Insomnia:
| D3: Sertraline: 50–200 mg/d | | D1: 23.4 (3.9) | | D2: 20.8
| | | D2: 22.6 (4.2) | | D3: 26.0
| | | D3: 23.5 (3.9) | | Nausea:
| | | Baseline HAM-D Sleep Disturbance factor in sleep disturbance subgroup: | | D2: 25.0
| | | D1: 5.1 (0.9) | | D3: 20.8
| | | D2: 4.8 (0.8) | | Sexual dysfunction (abnormal ejaculation):
| | | D3: 5.1 (0.8) | | D2: 20.0 (of males)
| | | Baseline HAM-A:
| | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Depression outcomes in patients with anxiety: | Diarrhea: | Overall attrition rate:
Fava et al., 2000 | To compare efficacy and tolerability of FLUO vs. PAR and SER for treatment of anxious depression | - Adults 18 or older; - Outpatients; - MDD according to DSM-IV; - Minimum HAM-D-17 score of 16 | D1: 40.3 | No statistically sig diffs between FLUO, SER and PAR in improvement on HAM-D-17 total scores (overall P = 0.323) | D2: 20.0 | NR
Country and setting: | Duration of study: | Note: High anxiety defined as HAM-D Anxiety/Somatization Factor score of at least 7 | D2: 41.4 | Response rates were similar for FLUO, PAR, and SER (73%, 77%, and 86%, overall P = 0.405). Remission rates were also similar (53%, 50%, and 62%, overall P = 0.588) | D3: 25.6 | ITT Analysis
United States, multicenter (15 sites) | 10 to 16 wks (depending on response to initial dose; all received 6 wks of therapy at effective dose) | Exclusion criteria: | D3: 44..1 | Anxiety outcomes: | Headache: | Yes
Funding: | Study design: | - Additional mental illness or organic mental disorder; - Concomitant psychotropic medications; - Substance use or dependence (within 6 mos); - Pregnant, lactating, or child-bearing potential without contraception; - Clinically sig medical disease; - Suicide risk; - Seizure within 1 yr; - Response to placebo in lead-in phase | Sex (% female): | No statistically sig diffs between FLUO, SER and PAR in improvement on HAM-D Anxiety/Somatization Factor scores (overall P = 0.199) | D1: 22.9 | Quality rating:
Eli Lilly and Company | RCT | | D1: 65.7 | | D2: 23.3 | Fair
| Overall study N: | | D2: 66.7 | | D3: 25.6
| 108 (subset of patients with high anxiety from larger trial involving 284 patients with MDD) | | D3: 62.8 | | Insomnia:
| Intervention: | | Race (% white): | | D1: 17.1
| D1: Fluoxetine: 20–60 mg/d (mean 44) | | NR | | D2: 23.3
| D2: Paroxetine: 20–60 mg/d (mean 36) | | Baseline HAM-D-17: | | D3: 23.3
| D3: Sertraline: 50–200 mg/d (mean 104) | | D1: 23.6 (3.9) | | Nausea:
| | | D2: 25.0 (3.8) | | D2: 26.7
| | | D3: 23.9 (3.4) | | Somnolence:
| | | Baseline HAM-D Anxiety/Somatization factor: | | D1: 11.4
| | | D1: 7.8 (0.9) | | D2: 10.0
| | | D2: 8.2 (1.3) | | D3: 16.3
| | | D3: 8.1 (1.3)
| | | Baseline HAM-A:
| | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Anxiety outcomes: | Cardiovascular adverse events: | Overall attrition rate:
Fava et al., 1998 | To evaluate efficacy of FLUO vs. PAR vs. placebo for treatment of depression | - Outpatients; - Minimum HAM-D-17 score of 18; - Raskin Depression score of 8 or more; - Raskin score higher than Covi Anxiety Scale score | Overall: 41.3 | Improvement in Covi Anxiety was similar for FLUO (1.2), PAR (1.2) and placebo (1.1; P = NR) | D1: 11 | 28%
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | | D2: 5 | ITT Analysis:
United States, multicenter (5 sites) | 12 wks | - Additional mental illnesses or organic mental disorder; - Concomitant psychotherapeutic medications; - Alcohol or drug abuse (within 6 mos); - ECT within 3 mos; - Investigational drug within 1 mo; - Suicidal (high risk); - Clinically sig medical disease; - Pregnant, lactating, or child-bearing potential without contraception; - Placebo response during washout (25% improvement on HAM-D) | Overall: 50 | | D3: 11 | Yes
Funding: | Study design: | | Race (% white): | | Insomnia: | Quality rating:
SmithKline Beecham | Pooled analysis of data from 5 sites of 2 multicenter trials | | NR | | D1: 20 | Fair
| Overall study N: | | Baseline HAM-D-17: | | D2: 29
| 128 | | D1: 23.9 (3.8) | | D3: 11
| Intervention: | | D2: 23.1 (3.4) | | Sexual dysfunction:
| D1: Fluoxetine 20–80 mg/d | | D3: 23.7 (2.7) | | D1: 7
| D2: Paroxetine 20–50 mg/d | | Baseline Covi Anxiety score: | | D2: 25
| D3: Placebo | | D1: 6.3 (1.7) | | D3: 0
| | | D2: 6.2 (1.7) | | Somnolence:
| | | D3: 5.8 (1.2) | | D1: 26
| | | Baseline HAM-A: | | D2: 35
| | | NR | | D3: 11
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Depression results in patients with melancholia: | Overall adverse events: | Overall attrition rate:
Flament et al., 1999 | To compare response rates of FLUO vs. SER for treatment of depression in subgroups of patients with depression | - Adults 18 or older; - Outpatients; - MDD or bipolar, depressed by DSM-III-R criteria; - Minimum HAM-D-17 score of 18; - Raskin Depression score higher than Covi Anxiety score | D1: 49.9 | Mean HAM-D change did not differ between groups (-9.8 FLUO vs. -11.0 SER). Response rates were higher for SER (59%) vs. FLUO (44%) (P < 0.05) | D1: 60 | 13.3%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 49.9 | Depression results in anxiety: | D2: 57 | ITT Analysis:
UK, multicenter (20 psychiatric clinics) | 6 wks | - Additional mental illnesses or organic mental disorder; - Concomitant psychotherapeutic drugs; - Concomitant ECT or psychotherapy; - Substance use or dependence (within 6 mos); - Pregnant, lactating, or child-bearing potential without contraception; - Clinically sig medical disease; - Suicide risk; - Placebo response during washout; - Previous use of study drugs | Sex (% female): | FLUO and SER groups had similar HAM-D mean change (-10.6 vs. -9.7) and response rates (48% vs. 47%; P = NR) | | Yes
Funding: | Study design: | | D1: 65 | Depression results in psychomotor change: | | Quality rating:
Not reported, but 2^nd^ author employed by Pfizer Inc | RCT | | D2: 57 | In retardation, HAM-D change and response were similar (Change/response: -10.7/46% for FLUO vs. -9.1/48% for SER; P = NR). In agitation, HAM-D improvement was 8.7 for FLUO vs. 12.4 for SER (P = 0.02); response rate was 39% for FLUO vs. 62% for SER (P = 0.04) | | Fair
| Overall study N: | | Race (% white):
| 286 randomized; 248 included in analysis; 174 in melancholia subgroup (defined by DSM-III-R criteria); 131 in anxiety subgroup (7 or more on Covi Anxiety Scale); 47 in psychomotor retardation group (HAM-D item 8 ≥2 and item 9 ≤ 1); 78 in psychomotor agitation subgroup (HAM-D item 8 ≤ 1 and item 9 ≥2) | | NR
| Intervention: | | Baseline HAM-D-17:
| D1: Fluoxetine 20–40 mg/d (mean 25) | | D1: 23.4
| D2: Sertraline 50–100 mg/d (mean 62.5) | | D2: 23.2
| | | Baseline HAM-A:
| | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Anxiety outcomes: | Diarrhea: | Overall attrition rate:
Gagiano, 1993 | To evaluate efficacy of FLUO and PAR in patients with MDD | - Adults 18 to 65; - Outpatients; - MDD according to DSM-III-R; - Minimum HAM-D-21 score of 18 | D1: 39.6 | Improvement in HAM-A scores was similar for FLUO and PAR groups (P = NR) | D1: 13 | 21%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 37.8 | | D2: 13 | ITT Analysis:
South Africa | 6 wks | - Additional mental illness or organic mental disorder; - Recent psychotherapeutic medications; - ECT within 3 mos; - Alcohol or drug abuse; - Pregnant or lactating; - Clinically sig medical disease; - Suicidal (severe risk) | Sex (% female): | | Headache: | Yes
University hospital | Study design: | | D1: 80 | | D1: 47 | Quality rating:
Funding: | RCT | | D2: 80 | | D2: 53 | Fair
NR | Overall study N: | | Race (% white): | | Insomnia:
| 90 | | NR | | D1: 20
| Intervention: | | Baseline HAM-D-21: | | D2: 11
| D1: Fluoxetine 20–60 mg/d | | D1: 24.5 (5.0) | | Nausea:
| D2: Paroxetine 20–40 mg/d | | D2: 25.0 (4.7) | | D1: 33
| | | Baseline HAM-A: | | D2: 36
| | | D1: 22.6 (5.1)
| | | D2: 23.4 (5.5)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Pain outcomes: | Constipation: | Overall attrition rate:
Goldstein et al., 2004 | To evaluate DUL vs. PAR and placebo for treatment of emotional and painful physical symptoms in patients with MDD | - Adults 18 or older; - MDD according to DSM-IV; - Minimum HAM-D-17 score of 15; - CGI-S of 4 or more | D1: 41 | Median change in VAS overall pain was 0 for placebo, -4 mm for DUL 40 mg (P vs. placebo = 0.172), -7.5 mm for DUL 80 mg (P vs. placebo = 0.005), and -3 for placebo (P vs. placebo = 0.088) | D1: 8.1 | 41%
Country and setting: | Duration of study: | Note: Painful symptoms not required for inclusion | D2: 41 | | D2: 8.8 | ITT Analysis:
United States, multicenter (19 psychiatric research centers) | 8 wks | Exclusion criteria: | D3: 40 | | D3: 13.8 | Yes
Funding: | Study design: | - Additional mental illnesses or organic mental disorder (except anxiety disorders); - Substance abuse or dependence (within 1 yr); - Positive urine drug screen; - Lack of response of current MDD episode to 2 prior courses of therapy | D4: 40 | | D4: 3.4 | Quality rating:
Eli Lilly and Company | RCT | | Sex (% female): | | Dizziness: | Poor: High overall attrition
| Overall study N: | | D1: 56 | | D1: 4.7
| 353 | | D2: 62 | | D2: 16.5
| Intervention: | | D3: 64 | | D3: 10.3
| D1: Duloxetine 40 mg/d | | D4: 64 | | D4: 5.6
| D2: Duloxetine 80 mg/d | | Race (% white): | | Insomnia:
| D3: Paroxetine 20 mg/d | | D1: 84 | | D1: 17.4
| D4: Placebo | | D2: 85 | | D2: 19.8
| | | D3: 74 | | D3: 8.0
| | | D4: 83 | | D4: 5.6
| | | Baseline HAM-D-17: | | Nausea:
| | | D1: 18.74 (5.97) | | D1: 22.1
| | | D2: 17.86 (4.66) | | D2: 25.3
| | | D3: 17.83 (5.19) | | D3: 16.1
| | | D4: 17.20 (5.08) | | D4: 2.2
| | | Baseline HAM-A: | | Somnolence:
| | | D1: 15.24 (5.87) | | D1: 17.4
| | | D2: 14.70 (4.83) | | D2: 11.0
| | | D3: 14.70 (6.00) | | D3: 8.0
| | | D4: 14.47 (5.3) | | D4: 2.2
| | | Median baseline 100mm VAS (overall pain): | | Sweating (increase):
| | | D1: 17.5 | | D1: 9.3
| | | D2: 18.0 | | D2: 12.1
| | | D3: 15.0 | | D3: 6.9
| | | D4: 15.0 | | D4: 0.0
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Depression outcomes in patients with anxiety: | NR | Overall attrition rate:
Joliat et al., 2004 | To assess efficacy of FLUO 20 mg daily vs. FLUO 90 mg wkly vs. placebo in continuation treatment of depression in patients with MDD and associated anxiety who initially responded to therapy | - Adults 18 to 65 (Study 1) and 18 to 80 (Study 2); - Outpatients; - MDD according to DSM-III-R or IV; - Minimum HAM-D-17 score of 16 for Study 1 and 18 for Study 2. Study 2 also required CGI-S score of 4 or more; - Duration of 1 mo or more | D1: 40.6 | Relapse rates for patients with anxiety were 28.5% in FLUO wkly group, 27.8% in FLUO daily group, and 53.3% in placebo-treated group (P = NR) | | NR
Pooled data from; 1 Reimherr et al., 1998; 2 Schmidt et al., 2000 | Duration of study: | Note: High anxiety defined as score of 7 or more on HAM-D Anxiety-Somatization subscale | D2: 40.8 | Anxiety outcomes: | | ITT Analysis
Country and setting: | 25 wks | Exclusion criteria: | D3: 41.5 | HAM-D Anxiety-Somatization scores increased (worsened) 1.92 and 1.93 in FLUO daily and wkly groups, respectively, and 3.12 points in placebo group (P = NR) | | Yes
United States, multicenter | Study design: | - Additional mental illness or organic mental disorder; - Substance abuse (within 1 yr); - Pregnant or lactating; - Unstable medical conditions; - Lack of response of current episode to FLUO or to 2 prior courses of therapy | Sex (% female): | | | Quality rating:
Funding: | Pooled analysis of data from 2 RCTs | | D1: 72.1 | | | Fair
Eli Lilly and Company | Overall study N: | | D2: 70.1
| 374 with anxiety (data for 425 patients without anxiety not considered for KQ 3) | | D3: 76.2
| Intervention: | | Race (% white):
| D1: Fluoxetine 20 mg/d | | D1: 84.3
| D2: Fluoxetine 90 mg/wk | | D2: 91.8
| D3: Placebo | | D3: 86.7
| | | Baseline HAM-D:
| | | D1: 3.79(2.56)
| | | D2: 4.17(2.77)
| | | D3: 3.45(2.34)
| | | Baseline HAM-A:
| | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Anxiety outcomes in patients with anxiety: | Dropouts due to dizziness: | Overall attrition rate:
Khan et al., 1998 | To evaluate efficacy of 3 different doses of VEN vs. placebo for treatment of MDD or MDD with associated anxiety | - Adults 18 or older; - Outpatients; - MDD according to DSM-III -R; - Minimum HAM-D-21 score of 20; - Depression symptoms for at least 1 mo | D1: 43.3 | All 3 VEN-treated groups had statistically sig improvement in HAM-D Anxiety-Psychic Item and Anxiety-Somatization Factor scores compared to placebo group (P < 0.05) | D1: 5 | NR
Country and setting: | Duration of study: | Note: Anxiety defined as score of 2 or more on HAM-D Anxiety-Psychic Item | D2: 40.0 | | D2: 2 | ITT Analysis
United States, multicenter (12 sites) | 12 wks | Exclusion criteria: | D3: 43.6 | | D3: 6 | Yes
Funding: | Study design: | - Additional mental illnesses or organic mental disorder; - Concomitant or recent psychotherapeutic drugs or ECT; - Drug or alcohol dependence (within 2 yrs); - Suicidal; - Women with child-bearing potential; - Clinically sig medical disease; - Decrease of >20% in HAM-D during palcebo washout | D4: 40.2 | | D4: 1 | Quality rating:
Not reported but 3 authors employed by Wyeth-Ayerst | RCT | | Sex (% female): | | Dropouts due to insomnia: | Fair
| Overall study N: | | D1: 68 | | D1: 5
| 403 randomized; 353 in modified ITT analysis; 346 with associated anxiety | | D2: 64 | | D2: 3
| Intervention: | | D3: 60 | | D3: 5
| D1: Venlafaxine 75 mg/d | | D4: 61 | | D4: 0
| D2: Venlafaxine 150 mg/d | | Race (% white): | | Dropouts due to nausea:
| D3: Venlafaxine 200 mg/d | | NR | | D1: 8
| D4: Placebo | | Baseline HAM-D: | | D2: 7
| | | D1: 24.3 | | D3: 17
| | | D2: 24.5 | | D4: 1
| | | D3: 24.8 | | Dropouts due to somnolence:
| | | D4: 25.1 | | D1: 7
| | | Baseline HAM-A: | | D2: 4
| | | NR | | D3: 4
| | | | | D4: 0
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Somatization severity outcomes: | Dropouts due to changes in weight (increase): | Overall attrition rate:
Kroenke et al., 2001 | To compare effectiveness of PAR, FLUO and SER for treatment of depression in primary care | - Adults 18 or older; - Depressive disorder diagnosed by primary care physician; - Access to telephone at home | D1: 47.1 | Scores on Patient Health Questionnaire Somatization Severity scale (possible range 0–28) improved similarly in all 3 treatment groups. Scores decreased 3.1, 3.2, and 4.1 points for FLUO, PAR, and SER-treated groups (nonsig diff; P value NR) | D1: 0 | 24.3%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 47.2 | | D2: 1 | ITT Analysis
United States, multicenter (37 primary care clinics) | 9 mos | - Concomitant psychotherapeutic medications (SSRI within 2 mos or current non-SSRI antidepressant); - Suicidal tendencies (active); - Bipolar disorder, severe cognitive impairment, terminal illness; - Active cocaine or opiate abuse; - Pregnant, lactating or pregnancy planned within 9 mos; - Unable to read, write, or speak English | D3: 44.1 | | D3: 1 | Yes
Funding: | Study design: | | Sex (% female): | | Dropouts due to gastrointestinal symptoms: | Quality rating:
Eli Lilly and Company | RCT | | D1: 86 | | D1: 4 | Fair
| Overall study N: | | D2: 76 | | D2: 8
| 601 randomized; 546 included in analysis | | D3: 75 | | D3: 4
| Intervention: | | Race (% white): | | Dropouts due to headache:
| D1: Fluoxetine: 20 mg/d (mean 23.4) | | D1: 88 | | D1: 2
| D2: Paroxetine: 20 mg/d (mean 23.5) | | D2: 85 | | D2: 3
| D3: Sertraline: 50 mg/d (mean 72.8) | | D3: 79 | | D3: 1
| | | Baseline HAM-D: | | Dropouts due to sexual dysfunction:
| | | NR | | D1: 1
| | | Baseline HAM-A: | | D2: 2
| | | NR | | D3: 0
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Depression outcomes in patients with sleep problems | Insomnia: | Overall attrition rate:
Lader et al., 2005 | To evaluate effect of ESC vs. CIT and placebo on sleep in patients with depression | - Adults 18 to 65 (Study 1, 3), 18 to 80 (Study 2); - Outpatients; - MDD according to DSM-IV; - Minimum MADRS score of 22 | D1: 42 | Mean improvement in MADRS total score was 16.47 points for ESC group (P < 0.05 vs. CIT; P < 0.05 vs. placebo) compared to 14.02 for CIT (P vs. placebo not sig) and 12.2 for placebo | D1: 8.6 | 16.7%
Pooled data from; 1 Burke et al., 2002; 2 Rapaportet al., 2004; 3 Lepola et al., 2003 | Duration of study: | Note: Sleep problems defined as MADRS item 4 score of 4 or more (possible range 0–6) | D2: 41 | Sleep outcomes: | D2: 9.2 | ITT Analysis
Country and setting: | 8 wks | Exclusion criteria: | D3: 42 | Mean improvement in MADRS item 4 was 1.65 points for ESC (P < 0.01 vs. CIT; P < 0.01 vs. placebo), 1.31 for CIT (P vs. placebo not sig), and 1.26 for placebo. Rate of improvement (end MADRS sleep score of 0 or 1) was 43.6% for ESC vs. 28.4% for CIT and 24.4% for placebo (P < 0.001) | D3: 3.9 | Yes
United States and Europe | Study design: | - Concomitant psychotherapeutic medications; - Full criteria not reported | Sex (% female): | | Somnolence: | Quality rating:
Funding: | Pooled analysis of 3 RCTs | | D1: 61 | | D1: 4.7 | Fair
H. Lundbeck A/S, Forest Laboratories | Overall study N: | | D2: 67 | | D2: 6.9
| 1321 included in analysis; 638 with sleep problems | | D3: 64 | | D3: 2.2
| Intervention: | | Race (% white):
| D1: Citalopram: 20–40 mg/d (mean 28.9) | | NR
| D2: Escitalopram: 10–20 mg/d (mean 13.3) | | Baseline HAM-D:
| D3: Placebo | | NR
| | | Baseline MADRS:
| | | D1: 28.9 (4.6)
| | | D2: 28.7 (4.5)
| | | D3: 29.0 (4.6)
| | | Baseline HAM-A:
| | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Anxiety outcomes: | Overall adverse events: | Overall attrition rate:
Leinonen et al., 1999 | To evaluate efficacy of MIR vs. CIT for treatment of major depression | - Adults 18 to 65; - Outpatient and inpatient; - MDD according to DSM-IV; - Minimum MADRS score of 22; - Duration of current depression episode less than 12 mos | D1: 41.1 | Mean reduction in HAM-A scores was similar (approximately -13 points) in both treatment groups (change estimated from figure; P = 0.75) | D1: 70.7 | 19.1%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 42.1 | | D2: 66.4 | ITT Analysis
European, multicenter (21 psychiatric sites) | 8 wks | - Additional mental illnesses or organic mental disorder; - Concomitant or recent psychotherapeutic medications; - ECT within 3 mos; - Substance abuse (within 12 mos); - Pregnant or lactating; - Clinically sig medical disease; - Suicidal (high risk); - Lack of response of current MDD episode to 2 prior courses of therapy; - Placebo response during washout (25% improvement on MADRS) | Sex (% female): | | Changes in weight (increase): | Yes
Funding: | Study design: | | D1: 57.1 | | D1: 4.5 | Quality rating:
Organon | RCT | | D2: 66.9 | | D2: 15.3 | Fair
| Overall study N: | | Race (% white): | | Diarrhea:
| 270 randomized; 269 included in analysis | | NR | | D1: 6.0
| Intervention: | | Baseline HAM-D: | | D2: 2.9
| D1: Citalopram 20–60mg/d (mean 36.6) | | NR | | Dizziness:
| D2: Mirtazapine 15–60mg/d (mean 35.9) | | Baseline MADRS: | | D1: 4.5
| | | D1: 29.1 (4.5) | | D2: 8.8
| | | D2: 29.6 (4.9) | | Headache:
| | | Baseline HAM-A: | | D1: 14.3
| | | D1: 20.9 (6.1) | | D2: 9.5
| | | D2: 21.1 (6.2) | | Nausea:
| | | | | D1: 20.2
| | | | | D2: 10.2
| | | | | Somnolence:
| | | | | D1: 6
| | | | | D2: 8
| | | | | Fatigue:
| | | | | D1: 13.5
| | | | | D2: 12.4
| | | | | Sweating (increase):
| | | | | D1: 15.0
| | | | | D2: 2.2
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Depression outcomes in patients with melancholia: | NR | Overall attrition rate:
Mallinckrodt et al., 2005 | To compare efficacy of DUL for treatment of depression in patients with melancholia to those without melancholia | - Adults 18 or older; - MDD according to DSM-IV; - Minimum HAM-D-17 score of 15; - CGI-S score of 4 or more | All melancholic: 42.1 | Mean reduction in HAM-D-17 score was 8.97 for DUL-treated group and 6.57 for those receiving placebo (P < 0.001) | | NR
Country and setting: | Duration of study: | Note: Melancholic features defined by DSM-IV criteria | Sex (% female): | | | ITT Analysis
United States, multicenter | 9 wks | Exclusion criteria: | All melancholic: 69.5 | | | Yes
Funding: | Study design: | - Additional mental illness or organic mental disorder; - Concomitant psychotherapeutic or chronic prescription analgesic drugs; - Substance abuse or dependence (within one yr); positive urine drug screen; - Clinically sig medical disease; - Suicidal (serious risk); - Lack of response of current MDD episode to 2 prior courses of therapy | Race (% white): | | | Quality rating:
Eli Lilly and Company | Pooled analysis of 8 RCTs (all RCTs included in DUL's New Drug Application to FDA) | | NR | | | Fair
| Overall study N: | | Baseline HAM-D:
| 1572 with melancholia | | All melancholic: 22.3 (3.9)
| Intervention: | | Baseline HAM-A:
| D1: Duloxetine 40–120 mg | | NR
| D2: Placebo
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Depression outcomes in patients with insomnia: | Constipation: | Overall attrition rate (%):
Rush et al., 1998 | To evaluate effects of FLUO vs. NEF on sleep in patients with depression and insomnia | - Adults 19 to 55; - Outpatients; - MDD according to DSM-III-R; - Minimum HAM-D-17 score of 18; - One of following sleep problems was required: difficulty falling asleep, waking up during night, or inability to fall asleep again after getting up | D1: 37 | Mean improvement in HAM-D-17 was 12.2 for FLUO-treated group and 11.4 for NEF-treated group (95% CI for diff: -1.7, 2.8) | D1: 11 | 17%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 36 | Response rates were similar for FLUO (45%) and NEF (47%; P = NR) | D2: 17 | ITT Analysis
United States, multicenter (10 sites) | 8 wks | - Additional mental illness or organic mental disorder; - Substance use disorder (within 1 yr); - Clinically sig medical disease; - Pregnant, lactating, or child-bearing potential without contraception; - Shift-workers; sleep/wake disorder on polysomnograph | Sex (% female): | Sleep outcomes: | Diarrhea: | Yes
Funding: | Study design: | | D1: 70 | Mean improvement in HAM-D Sleep Disturbance Factor was 1.6 points for FLUO-treated group and 2.3 for NEF-treated group (P < 0.05) | D1: 26 | Quality rating:
Bristol-Myers Squibb | Pooled analysis of 3 RCTs | | D2: 59 | Improvement in IDS-SR Sleep Factor was 1.7 points for FLUO-treated group and 2.4 for NEF-treated group (P < 0.01) | D2: 16 | Fair
| Overall study N: | | Race (% white): | | Dizziness:
| 125 randomized; 122 included in analysis | | D1: 85 | | D1: 8
| Intervention: | | D2: 78 | | D2: 22
| D1: Fluoxetine 20–40 mg/d (mean 32) | | Baseline HAM-D: | | Headache:
| D2: Nefazodone 200–500 mg/d (mean 424) | | D1: 23.3 (2.7) | | D1: 48
| | | D2: 22.9 (2.9) | | D2: 56
| | | Baseline HAM-D Sleep Disturbance Factor: | | Insomnia:
| | | D1: 4.2 (1.3) | | D1: 11
| | | D2: 4.2 (1.3) | | D2: 6
| | | Baseline Depression Symptomatology-Self Report (IDS-SR) Sleep Factor: | | Nausea:
| | | D1: 5.8 (2.1) | | D1: 25
| | | D2: 5.3 (2.2) | | D2: 36
| | | Baseline HAM-A: | | Sexual dysfunction:
| | | NR | | D1: 11 of males
| | | | | D2: 0 of males
| | | | | Somnolence:
| | | | | D1: 21
| | | | | D2: 22
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Depression outcomes in patients with high anxiety: | Diarrhea: | Overall attrition rate (%):
Rush et al., 2001 (original report: Kavoussi, 1997) | To determine whether baseline anxiety levels are associated with response to BUP SR and SER | - Adults 18 or older; - MDD according to DSM-IV; - Minimum HAM-D-21 score of 18; - Depression duration 1 to 24 mos | D1: 39 | In patients with high anxiety (top quartile of HAM-A scores), response and remission rates were similar for BUP SR and SER (estimated from figure: approximately 60% remission and 70% response in both groups, P = NR) | D1: 3 | 31%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 40 | Anxiety outcomes in all patients: | D2: 22 | ITT Analysis
United States, multicenter | 16 wks | - Concomitant or recent psychotherapeutic drugs; - Suicidal (active); - Pregnant or lactating; - History of eating disorder or predisposition to seizures; - Previous treatment with BUP or SER | Sex (% female): | Mean reduction in HAM-A was 9.7 for BUP-treated group and 10.0 for SER treated group (P = NR) | Dizziness: | Yes
Funding: | Study design: | | D1: 48 | | D1: 8 | Quality rating:
Glaxo-Wellcome | RCT | | D2: 48 | | D2: 5 | Fair
| Overall study N: | | Race (% white): | | Headache:
| 248 | | D1: 93 | | D1: 34
| Intervention: | | D2: 94 | | D2: 32
| D1: Bupropion SR 100–300 mg/d | | Baseline HAM-D: | | Insomnia:
| D2: Sertraline 50–200 mg/d | | D1: 24.8 (4.6) | | D1: 18
| | | D2: 24.8 (4.6) | | D2: 19
| | | Baseline HAM-A: | | Nausea:
| | | D1: 16.6 (5.2) | | D1: 10
| | | D2: 16.6 (5.4) | | D2: 30
| | | | | Sexual dysfunction (orgasm in men):
| | | | | D1: 10
| | | | | D2: 61
| | | | | Sexual dysfunction (orgasm in women):
| | | | | D1: 7
| | | | | D2: 41
| | | | | Somnolence:
| | | | | D1: 2
| | | | | D2: 13
| | | | | Sweating (increase):
| | | | | D1: 2
| | | | | D2: 10
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Depression outcomes in anxiety subgroup: | Dizziness: | Overall attrition rate (%):
Sir et al., 2005 | To evaluate diffs in efficacy between SER and VEN XR on measures of QOL, depression, anxiety and pain in patients with major depression | - Adults 18 or older; - Outpatients; - MDD according to DSM-IV; - Minimum HAM-D-17 score of 18 | D1: 37.3 | Mean reduction in HAM-D was 17.3 for SER and 14.8 for VEN XR (P = 0.70) | D1: 32.9 | 23%
Country and setting: | Duration of study: | Note: Anxious depression subgroup defined by HAM-D Anxiety-Somatization score of 7 or more | D2: 36.8 | Response rates SER 79.6% VEN 68.9% (P = 0.26) | D2: 26.2 | ITT Analysis:
Australia and Turkey (13 sites) | 8 wks | Exclusion criteria: | Sex (% female): | Remission rates were SER 63.0% VEN 54.1 (P = 0.44) | Headache: | Quality rating:
Funding: | Study design: | - Additional mental illnesses or organic mental disorder; - Substance abuse or dependence (within 6 mos); - Pregnant or child-bearing potential without contraception; - Lack of response of current MDD episode to 2 prior courses of therapy; - History of nonresponse to SER or VEN | D1: 72.2 | Anxiety outcomes: | D1: 44.3 | Fair
Pfizer, Inc | RCT | | D2: 66.7 | In overall study population, mean reduction in HAM-A was similar for treatment groups: 14.1 for SER vs. 12.9 for VEN XR (P = 0.32) | D2: 32.1
| Overall study N: | | Race (% white): | In high-anxiety subgroup, response on HAM-D Anxiety-Somatization subscale was similar for treatment arms: 83.3% for SER, 70.5% for VEN (P = 0.12) | Insomnia:
| 163 overall; 120 in anxiety subgroup | | D1: 96.2 | | D1: 35.4
| Intervention: | | D2: 100 | | D2: 27.4
| D1: Sertraline 50–150 mg/d | | Baseline HAM-D: | | Nausea:
| D2: Venlafaxine XR 75–225 mg/d | | D1: 23.4 (4.4) | | D1: 51.9
| | | D2: 23.5 (4.4) | | D2: 47.6
| | | Baseline HAM-A: | | Somnolence:
| | | NR | | D1: 21.5
| | | | | D2: 26.2
| | | | | Sweating (increase):
| | | | | D1: 31.6
| | | | | D2: 21.4
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Depression outcomes in patients with anxiety: | Dizziness: | Overall attrition rate:
Trivedi et al., 2001 and Rush et al., 2001 | To compare effects of bupropion SR and SER on anxiety in patients with MDD | - Adults 18 or older; - MDD according to DSM-IV; - Recurrent major depression episode of 2 to 24 mo duration; - Minimum HAM-D-21 score of 18 | D1: 37 | Response rates were similar for BUP SR, SER, and placebo (approximately 70%, 64% and 58%; rates estimated from figure; P = NR). Remission rates were also similar for all 3 treatment groups (P = NR) | D1: 7 | 28%
Country and setting: | Duration of study: | Note: Anxiety subgroup defined as top quartile on HAM-A (score > 24) | D2: 37 | Anxiety outcomes in all patients: | D2: 8 | ITT Analysis
United States, multicenter | 8 wks | Exclusion criteria: | D3: 38 | Mean reduction in HAM-A was similar for BUP SR and SER-treated groups (9.9 and 9.4 points) and slightly less for those receiving placebo (8.4 points). No statistically sig diff between active drug groups (P > 0.41). Diff between active drug and placebo was statistically sig for BUP group (P = 0.04) but not for SER (P = NR) | D3: 5 | Yes
Funding: | Study design: | - Additional mental illness or organic mental disorder (except GAD); - Concomitant psychotherapeutic medications (within one wk); - Substance abuse or dependence (within one yr); - Pregnant or lactating; - Prior treatment with BUP or SER | Sex (% female): | | Insomnia: | Quality rating:
Glaxo Wellcome Inc | Analysis of pooled data from 2 RCTs | | D1: 53 | | D1: 16 | Fair
| Overall study N: | | D2: 51 | | D2: 18
| 724 randomized; 692 included in analysis | | D3: 55 | | D3: 5
| Intervention: | | Race (% white): | | Somnolence:
| D1: Bupropion SR 150–400 mg/d | | D1: 87 | | D1: 3
| D2: Sertraline 50–200 mg/d | | D2: 91 | | D2: 13
| D3: Placebo | | D3: 88 | | D3: 5
| | | Baseline HAM-D:
| | | D1: 25.2 (5.2)
| | | D2: 25.2 (5.2)
| | | D3: 24.9 (5.2)
| | | Baseline HAM-A:
| | | D1: 18.8 (7.3)
| | | D2: 18.6 (7.4)
| | | D3: 18.6 (7.1)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Depression outcomes in melancholia: | Overall adverse events: | Overall attrition rate:
Tzanakaki et al., 2000 | To evaluate efficacy of FLUO vs. VEN in patients with major depression and melancholia | - Adults 18 to 64; - Outpatient or hospitalized; - MDD with melancholia according to DSM-IV; - MADRS of 25 or more; - Depression symptoms for one mo or more | D1: 49 | Response rates were similar for FLUO-treated group (58%) and VEN group (65%; P = NR). Remission rates were similar for FLUO (36%) and VEN (41%; P = NR) | D1: 46.3 | 22%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 47 | | D2: 49.1 | ITT Analysis
Greece and Italy, multicenter | 6 wks | - Additional mental illnesses or organic mental disorder; - Concomitant or recent psychotherapeutic drugs; - ECT within 30 days; - Drug or alcohol dependence (within 2 yrs); - Pregnant or without contraception; - Clinically sig medical disease; - Investigational drug use within 30 days; - Suicidal (acute) | Sex (% female): | | Constipation: | Yes
Funding: | Study design: | | D1: 83 | | D1: 1.9 | Quality rating:
Wyeth-Ayerst International | RCT | | D2: 75 | | D2: 7.3 | Fair
| Overall study N: | | Race (% white): | | Dizziness:
| 109 | | NR | | D1: 0
| Intervention: | | Baseline HAM-D: | | D2: 5.5
| D1: Fluoxetine 60 mg/d | | D1: 27.1 (5.6) | | Headache:
| D2: Venlafaxine 225 mg/d | | D2: 27.8 (5.6) | | D1: 1.9
| | | Baseline HAM-A: | | D2: 5.5
| | | NR | | Insomnia:
| | | | | D1: 1.9
| | | | | D2: 12.7
| | | | | Nausea:
| | | | | D1: 14.8
| | | | | D2: 5.5
| | | | | Sweating (increase):
| | | | | D1: 3.7
| | | | | D2: 5.5
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Sleep outcomes: | Overall adverse events: | Overall attrition rate:
Versiani, 2005 | To compare efficacy and tolerability of MIR and FLUO in severe MDD | - Adults 18 to 65; - MDD according to DSM-IV; - Minimum HAM-D-17 score of 25 | D1: 47 | Scores on Leeds Sleep Evaluation Questionnaire improved similarly for both groups | D1: 45 | 14%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 43 | | D2: 50 | ITT Analysis
Europe and South America, multicenter (30 sites) | 8 wks | - Current depression episode duration >12 mos; - Additional mental illnesses or organic mental disorder; - Concomitant or recent psychotherapeutic drugs; - Investigational drug use within 30 days; - ECT within 3 mos; - Alcohol or substance abuse (within 6 mos); - Pregnant or lactating; - Clinically sig medical disease; - Suicidal risk; - Response during placebo washout (25% improvement in HAM-D-17) | Sex (% female): | | Changes in weight (increase): | Yes
Funding: | Study design: | | D1: 69 | | D1: 1.3 | Quality rating:
Organon | RCT | | D2: 74 | | D2: 6.9 | Fair
| Overall study N: | | Race (% white): | | Dizziness:
| 299 randomized; 292 included in analysis | | NR | | D1: 12.8
| Intervention: | | Baseline HAM-D: | | D2: 9
| D1: Fluoxetine 20–40 mg/d | | D1: 28 (3) | | Headache:
| D2: Mirtazapine 30–60 mg/d | | D2: 29 (3) | | D1: 18.8
| | | Baseline HAM-A: | | D2: 19.3
| | | NR | | Insomnia:
| | | | | D1: 8.7
| | | | | D2: 4.8
| | | | | Nausea:
| | | | | D1: 24.1
| | | | | D2: 15.9
| | | | | Somnolence:
| | | | | D1: 9.4
| | | | | D2: 13.8

Evidence Table 4. KQ4: Safety, adverse events or adherence of antidepressants

Study Characteristics | Research Objective | Inclusion/Exclusion | Baseline Characteristics | Health Outcome Results | Adverse Events (%) | Analysis and Quality Rating
| Duration
| Study Design
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Response | Constipation: | Overall attrition rate:
Aberg-Wistedt et al., 2000 | SER vs. PAR clinical outcomes after 6 mos of continuous therapy | - Adults 18 or older; - MDD diagnosis according to DSM-III or -IV | Overall: 43 | 8 wks- | D1: 5.7 | 35.4%
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | SER: 63% | D2: 16.4 | ITT analysis:
Sweden | 24 wks | - Pregnant; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Suicidal tendencies | Overall: 67.4 | PAR: 63% | Diarrhea: | Yes
Multicenter | Study design: | | Race (% white): | LOCF at 24 wks: | D1: 35.2 | Quality rating:
Funding: | RCT | | NR | SER: 72% | D2: 15.2 | Fair
Pfizer, Inc | Overall study N: | | Baseline (HAM-A): | PAR: 69% | Libido decrease (men):
| 353 | | NR | Response-Observed Cases at 24 wks: | D1: 12.7
| Intervention: | | Mean HAM-D score at baseline: | SER: 89% | D2: 3.8
| D1: Sertraline 50–150 mg/d | | NR | PAR: 89% | Libido decrease (women):
| D2: Paroxetine 20–40 mg/d | | | Remission | D1: 1.8
| | | | No sig diff at endpoint or at any other study point measures | D2: 8.8
| | | | 8 wks: | P ≤ 0.05
| | | | SER: 51.6%
| | | | PAR: 57.3%
| | | | 24 wks:
| | | | SER: 80.2%
| | | | PAR: 73.7%
| | | | No sig diff in CGI severity change score or improvement score
| | | | Relapse during wks 9 to 24:
| | | | PAR 8.6%
| | | | SER 1.9%
| | | | (P-value NR)
| | | | No sig diffs on BQOL
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Onset of action faster in MIR group | Overall adverse events: | Overall attrition rate:
Behnke et al., 2003 | To compare onset of antidepressant efficacy of MIR and SER | - Adults 18 to 70; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18 | D1: 42 | At all assessments during first 2 wks mean change of HAM-D from baseline sig greater in MIR group than in SER group (P < 0.05) | D1: 64 | 20.8%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 41 | After wk 2 diff remained greater with MIR but lacked statistical significance | D2: 68 | ITT analysis:
Multinational | 8 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies; - Epilepsy; - History of seizure disorder or anticonvulsant treatment; - Current eating disorders diagnosis; - Previous postpartum depression or anxiety disorder diagnosis | Sex (% female): | HAM-D response rate showed similar findings | Diarrhea: | Yes
Multicenter | Study design: | | D1: 55.7 | HAM-D remission rate higher with MIR than SER at all assessments; diff reached statistical significance at day 14 | D1: 4 | Quality rating:
Funding: | RCT | | D2: 61.5 | Reduction in sleep disturbance was sig greater in MIR group at all assessments (P ≤0.01) | D2: 9.5 | Fair
NV Organon | Overall study N: | | Race (% white): | CGI scores not sig diff | Dizziness:
| 346 | | NR | | D1: 6.8
| Intervention: | | Baseline (HAM-A): | | D2: 10.1
| D1: Mirtazapine: 30–45 mg/d | | NR | | Headache:
| D2: Sertraline: 50–150 mg/d | | Mean HAM-D score at baseline: | | D1: 14.2
| | | NR | | D2: 18.3
| | | | | Insomnia:
| | | | | D1: 5.1
| | | | | D2: 8.9
| | | | | Nausea:
| | | | | D1: 7.4
| | | | | D2: 22.5
| | | | | Somnolence (fatigue):
| | | | | D1: 19.9
| | | | | D2: 7.7
| | | | | Sweating (increase):
| | | | | D1: 1.1
| | | | | D2: 5.3
| | | | | Libido decrease:
| | | | | D1: 1.1
| | | | | D2: 5.9
| | | | | P = 0.02
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Benkert-MIR and PAR equally effective in reducing mean HAM-D-17 score (58.3% vs. 53.7%) | Overall adverse events: | Overall attrition rate:
Benkert et al., 2000 | Safety and efficacy of MIR and PAR in treatment of major depression | - Adults 18 to 70; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18 | D1: 47.2 | Szegedi-Improvement occurred in majority of analyzed patients within 2 wks, MIR: 72.7% PAR: 64.9% | D1: 68.1 | 23%
Szegedi et al., 2003 | Duration of study: | Exclusion criteria: | D2: 47.3 | Early improvement was highly sensitive predictor of later stable response or stable remission for both drugs | D2: 63.4 | ITT analysis:
Country and setting: | 6 wks | - Pregnant; - Additional mental illnesses or organic mental disorder; - Suicidal tendencies | Sex (% female): | At endpoint, 40.9% of MIR group and 34.1% of PAR group were considered HAM-D remitters (score ≤ 7) | Changes in weight (increase): | Yes
Germany | Study design: | | D1: 63 | | D1: 14.8 | Quality rating:
Multicenter (50) | RCT | | D2: 65 | | D2: 3.7 | Fair
Funding: | Overall study N: | | Race (% white): | | Constipation:
Organon, GmBH, Munich, Germany | 275 | | NR | | D1: 7.4
| Intervention: | | Baseline (HAM-A): | | D2: 6.7
| D1: Mirtazapine: 15–45 mg/d (32.7) | | NR | | Dizziness:
| D2: Paroxetine: 20–40 mg/d (22.9) | | Mean HAM-D score at baseline: | | D1: 8.9
| | | D1: 22.4 (3.3) | | D2: 8.2
| | | D2: 22.4 (3.2) | | Headache:
| | | | | D1: 9.6
| | | | | D2: 10.4
| | | | | Nausea:
| | | | | D1: 4.4
| | | | | D2: 11.2
| | | | | Somnolence (fatigue):
| | | | | D1: 11.1 fatigue-8.9
| | | | | D2: 7.5 fatigue-8.2
| | | | | Sweating (increase):
| | | | | D1: 2.2
| | | | | D2: 7.5
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Among second generation antidepressants, VEN had highest fatal toxicity index (deaths/million prescriptions): | NR | Overall attrition rate:
Buckley et al., 2005 | To establish relative frequency with which venlafaxine and other new antidepressants result in fatal poisoning | - Deaths due to acute poisoning of a single drug | NR | VEN: 13.2 (9.2–18.5) | | N/A
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | FLUV: 3.0 (0.3–10.9) | | ITT Analysis
United Kingdom | 1993-1999 data | NR | NR | CIT: 1.9 (0.6–4.5) | | NR
Database | Study design: | | Race (% white): | SER: 1.2 (0.5–2.4) | | Quality rating:
Funding: | NR | | NR | FLUO: 0.9 (0.5–1.4) | | N/A
NR | Overall study N: | | Baseline HAM-A: | PAR: 0.7 (0.4–1.3)
| 121,927 | | NR | NEF: 0 (0–6.4)
| Intervention: | | Baseline HAM-D: | Highest rate of fatal toxicity for VEN
| TCAs and related drugs | | NR
| Serotoninergic drugs
Author: | Research objective: | Inclusion criteria: | Mean age (years): | Overall population: BUP IR (22%) and SR (25%) and NEF (28%) were associated with lowest risk for sexual dysfunction | N/A | Overall attrition rate:
Clayton et al., 2002 | To estimate prevalence of sexual dysfunction among patients taking newer antidepressants | - Adults 18+; - Taking monotherapy for depression (no trazodone in addition, e.g. with one of newer antidepressants earlier specified, sexually active within last 12 mos, willing to discuss his/her sexual functioning with physician | NR | Highest rates in PAR (43%) and MIR (41%) groups | | NR
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | CSFQ scores averaged 24% for all antidepressants combined and ranged from 7% (BUP SR) to 30% (CIT and VEN XR) | | ITT Analysis
US | N/A | - Concomitant psychotheraputic or psychotropic medications; - Taking monotherapy antidepressants for reason other than treatment of depression | NR | Patients aged 50–59 had sigly higher odds of having sexual dysfunction compared with reference age group of 20 to 29 yr. old patients. OR 1.42 (95 CI 1.14–179) | | N/A
Multicenter 1101 primary care clinics) | Study design: | | Race (% white): | | | Quality rating:
Funding: | Cross-sectional survey | | NR | | | Fair
Glaxo Wellcome Inc. | Overall study N: | | Baseline (HAM-A):
| 6297 | | NR
| Intervention: | | Baseline HAM-D:
| Bupropion: IR: 255.0; SR: 273.7
| Citalopram: 24.9
| Fluoxetine: 25.5
| Mirtazapine: 28.6
| Nefazodone: 293.2
| Paroxetine: 23.3
| Sertraline: 81.4
| Venlafaxine: Regular: 124.9; XR: 114.9
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | More BUP SR remitters (47%) compared to placebo (32%) | Diarrhea: | Overall attrition rate:
Coleman et al., 2001 | Comparison of BUP, FLUO and placebo on safety, efficacy and sexual functioning in patients with recurrent major depression | - Adults; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20; - Have sexual activity at least once every 2 wks; - Currently experiencing episode lasting 2 to 24 mos; - Currently in a stable relationship | D1: 37.1 | Orgasm dysfunction occurred sig more in FLUO patients compared with placebo or BUP SR patients (P < 0.001) | D1: 12 | 34%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 36.6 | At endpoint, more FLUO treated patients had sexual desire disorder than BUP SR treated patients (P < 0.05) | D2: 9 | ITT Analysis
United States | 8 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Illicit drug and alcohol abuse; - Suicidal tendencies | D3: 36.7 | Sig more buproion SR-treated patients were satisfied with sexual function (analysis only for patients satisfied at baseline; no data reported) P<0.05 | D3: 9 | Yes
Multicenter (15 centers) | Study design: | | Sex (% female): | Compliance: 96.8% to 98.8% in all groups | Headache: | Quality rating:
Funding: | RCT | | D1: 66 | | D1: 31 | Fair
Glaxo Wellcome | Overall study N: | | D2: 63 | | D2: 28
| 456 | | D3: 61 | | D3: 20
| Intervention: | | Race (% white): | | Insomnia:
| D1: Fluoxetine: 20–60 mg/d (26) | | D1: 82 | | D1: 15
| D2: Bupropion: 150–400 mg/d (319) | | D2: 83 | | D2: 21
| D3: Placebo | | D3: 82 | | D3: 10
| | | Baseline (HAM-A): | | Nausea:
| | | NR | | D1: 12
| | | Baseline HAM-D: | | D2: 21
| | | D1: 24.6 | | D3: 16
| | | D2: 24.5 | | Somnolence (fatigue):
| | | D3: 24.4 | | D1: 11
| | | | | D2: 3
| | | | | D3: 4
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Mean HAM-D scores in BUP SR but not SER group were statistically better than placebo (by day 28 P < 0.05) | Diarrhea: | Overall attrition rate:
Coleman et al., 1999 | To compare sexual functioning as well as safety and efficacy of BUP SR and SER | - Adults 18+; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18; - Be in a stable relationship, have normal sexual functioning, and sexual activity at least once every 2 wks; - Currently experiencing recurrent major episode of depression | D1: 38.3 | Sig fewer BUP SR patients had sexual desire disorder than SER patients (P < 0.05) | D1: 12 | 30%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 38.1 | Orgasm dysfunction occurred sig more in SER patients compared with placebo or BUP SR patients (P < 0.05) | D2: 18 | ITT Analysis
United States | 8 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Illicit drug and alcohol abuse; - Suicidal tendencies | D3: 38.5 | Diagnosed with at least one sexual dysfunction: SER: 39%, BUP SR: 13%, placebo: 17% | Headache: | Yes
Multicenter (9 centers) | Study design: | | Sex (% female): | Sig more BUP patients were satisfied with their sexual functioning (endpoint BUP 85% vs. SER 62%; P< 0.05) | D1: 34 | Quality rating:
Funding: | RCT | | D1: 54 | Mean Compliance: Tablet: placebo: 96.1%, BUP 96.4%, SER 97.1% | D2: 27 | Fair
Glaxo Wellcome Inc | Overall study N: | | D2: 56 | Capsule: placebo: 98.4%, 97.9%, SER 98.3% | Insomnia:
| 364 | | D3: 59 | | D1: 20
| Intervention: | | Race (% white): | | D2: 17
| D1: Sertraline: 50–200 mg/d | | D1: 92 | | Nausea:
| D2: Bupropion: 150–400 mg/d | | D2: 87 | | D1: 19
| D3: Placebo | | D3: 88 | | D2: 23
| | | Baseline (HAM-A): | | Sexual dysfunction:
| | | NR | | D1: 39
| | | Baseline HAM-D: | | D2: 13
| | | D1: 34.5
| | | D2: 34.8
| | | D3: 34.0
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Adjusted OR (95% CI) for breast cancer and breast cancer association = 1.1 (0.8, 1.7) | NR | Overall attrition rate:
Coogan et al., 2005 | To evaluate SSRI use and breast cancer risk | - Adults 18 to 79; - Concomitant condition: breast cancer for cases; - Able to complete interview; - Lived in eligible zip code | NR | OR for use of SSRI for 4 or more yrs = 0.7 (0.4, 1.5) | | N/A
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | OR for recent use of SSRIs = 1.2 (0.8, 1.8) | | ITT Analysis
United States, inpatient, multicenter (3 hospitals) | Enrollment was from 1998 to 2002. Duration of treatment was not specified and use ranged from <2 yrs to ge 4 yrs | - Patients did not have certain excluded diagnoses (e.g., psychiatric diagnoses) | 100 | OR for SSRI use stopped at least a yr prior to interview = 1.1 (0.5, 2.6) | | Not applicable-observational study
Funding: | Study design: | | Race (% white): | OR for sporadic SSRI use = 1.1 (0.6, 2.1) | | Quality rating:
Not reported | Case control study | | NR | | | Fair
| Overall study N: | | Baseline (HAM-A):
| 4,996 | | NR
| Intervention: | | Baseline HAM-D:
| D1: Fluoxetine | | NR
| D2: Paroxetine
| D3: Sertraline
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Mean HAM-D scores in both BUP and SER group were statistically better than placebo (P < 0.05) | Diarrhea: | Overall attrition rate:
Croft et al., 1999 | Comparison of efficacy and effects on sexual functioning of depressed patients using BUP, SER, or placebo | - Adults 18 and over; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18; - In stable relationship; - Have normal sexual functioning and sexual activity at least once every 2 wks; - Current depressive episode of 8 wks to 24 mos | D1: 36.0 | At day 56, both BUP and SER had higher sexual arousal disorder (P < 0.05) than placebo | D1: 26 | 32%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 35.9 | Orgasmic dysfunction occurred sig more in SER patients compared with placebo or BUP patients (P < 0.001) | D2: 7 | ITT Analysis
United States | 8 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Illicit drug and alcohol abuse; - Suicidal tendencies | D3: 37.4 | Beginning at day 7 through day 42 sig more BUP patients were satisfied with their overall sexual functioning. At day 56 no sig diff between treatment groups (BUP 75% vs SER 65%; P < 0.05) | D3: 11 | Yes
Multicenter (8 centers) | Study design: | | Sex (% female): | Compliance: | Headache: | Quality rating:
Funding: | RCT | | D1: 50 | BUP 98% | D1: 40 | Fair
Glaxo Wellcome | Overall study N: | | D2: 51 | SER 97.2% | D2: 34
| 360 | | D3: 50 | Placebo 97.9% | D3: 30
| Intervention: | | Race (% white): | Endpoint: | Insomnia:
| D1: Sertraline: 50–200 mg/d (mean = 121) | | D1: 87 | RRR: 0.29 | D1: 18
| D2: Bupropion: 150–400 mg/d (mean = 293) | | D2: 86 | RD: 0.10 | D2: 13
| D3: Placebo | | D3: 88 | NNT: 10 | D3: 4
| | | Baseline (HAM-A): | | Nausea:
| | | NR | | D1: 31
| | | Baseline HAM-D: | | D2: 18
| | | NR | | D3: 10
| | | | | Somnolence (fatigue):
| | | | | D1: 17
| | | | | D2: 3
| | | | | D3: 6
Author: | Study design: | Characteristics of Included Studies: | Study Results: | N/A | Publication Bias: | Standard Method of Study Appraisals:
CSM Expert Working Group, 2004 | Systematic review | - Studies that included safety information on suicide, withdrawal, and dose response | Suicide | | No- however review was designed to eliminate publication bias | Yes
Country and setting: | Number of Patients: | Characteristics of Included Populations | No diffs in risk among second-generation antidepressants | | Heterogeneity: | Comprehensive Search Strategy:
UK | NR | - Individuals taking SSRIs | Withdrawal | | Yes | Clinical trial data from pharmaceutical companies, spontaneous reporting data, GPRD, expert evidence, regular searches of published literature
Funding: | Studies Included: | Characteristics of Interventions: | Based on observational studies, spontaneous reporting data, and clinical trials data, experts concluded that discontinuation syndromes occur most commonly with PAR and VEN and least commonly with FLUO | | | Quality Rating:
Not reported | All published and unpublished trials including output from GPRD- 477 studies | SSRIs | | | | Good
Research objective: | Intervention:
Evaluating safety of SSRI antidepressants (CIT, ESC, FLUO, FLUV, MIR, PAR, SER, VEN) | D1: Venlafaxine
| D2: Other SSRIs
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Acute Phase Treatment-Emergent Dysfunction (ASEX) in 475 patients who did not have sexual dysfunction at baseline, incidence of treat-emergent sexual dysfunction was sig higher for DUL vs. placebo | Overall adverse events: | Overall attrition rate:
Delgado et al., 2005 | To assess sexual functioning in patients receiving DUL or PAR | - Diagnosed with MDD according to DSM-III or -IV | NR | DUL = 46.4% | NR | NR
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | placebo = 28.8% | | ITT Analysis
Country not reported, pooled analysis of 4 studies - setting not described in article | 8 wk acute phase followed by a 26 wk extension phase (for 2 of 4 studies) | NR | NR | t = 2.69, df = 1337, P = 0.007 | | Yes
Funding: | Study design: | | Race (% white): | PAR vs. Placebo | | Quality rating:
Eli Lilly | Pooled analysis of 4 RCTs | | NR | PAR = 61.4% | | Fair
| Overall study N: | | Baseline (HAM-A): | placebo = 28.8%
| 1,466 | | NR | P < 0.001
| Intervention: | | Baseline HAM-D: | DUL vs. PAR,
| D1: Duloxetine: 40, 80, or 120 mg/d | | NR | P = 0.015 (incidence for DUL sig lower than incidence for PAR)
| D2: Paroxetine: 20 mg/d
| D3: Placebo
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig increase in suicides for SSRIs as a class: OR 1.28; 95% CI 0.38–4.35 | Not Reported | Overall attrition rate:
Didham et al., 2005 | Identify incidence and risk of suicide and self-harm among patients prescribed ADs | - Patients that received a prescription for an anti-depressant from 1996 to 2001 | Median- 46 | No sig diff in suicides between drugs | | N/A
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | FLUO: 0.80 (0.22–2.89) | | ITT Analysis
New Zealand | 120 days | - Concomitant psychotheraputic or psychotropic medications; - Less than 10 yrs old | Overall: 68.1 | PAR: 2.25 (0.47–10.72) | | Not applicable-observational study
RNZCGP Research Unit Database | Study design: | | Race (% white): | Self-harm SSRIs vs. TCAs incidence rate 2.57 95% CI 2.03–3.28 | | Quality rating:
Funding: | Observational | | NR | Increased risk of self-harm for SSRIs as a class OR 1.66 95% CI 1.23–2.23 | | Fair
New Zealand Government | Overall study N: | | Baseline (HAM-A): | No sig diffs in self-harm between drugs
| 57,361 | | NR | FLUO; 1.30 (0.96–1.75)
| Intervention: | | Baseline HAM-D: | PAR 1.21 (0.84–1.72)
| Citalopram | | NR
| Fluoxetine
| Paroxetine
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Observed seizure rate during 8-wk acute phase was 2 seizures in 3094 evaluable patients, or 0.06% and for acute and continuation phases combined was 3 seizures in 3094 patients, or 0.10% | Overall adverse events: | Overall attrition rate:
Dunner et al., 1998 | Safety of BUP sustained-release in acute and continuation treatment, especially in regards to seizures | - Adults 18+; - Diagnosed with MDD according to DSM-III or -IV; - Bipolar I or II depression; depression not otherwise specified bipolar depression not otherwise specified | D1: 42 | Survival analysis yielded cumulative seizure rate of 0.08% for acute phase and 0.15% for both phases combined | D1: 50 patients experienced 54 serious AEs | 34%
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | Rate of seizures for BUP within range of other antidepressants | | ITT Analysis
United States | Acute phase of 8 wks with continuation up to one yr | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Clinically sig medical disease; - Suicidal tendencies; - Known predisposition for seizures or previous treatment with BUP; - History or current diagnosis of bulimia and/or anorexia | D1: 62.4 | | | No, Survival analysis
Multicenter (105 sites) | Study design: | | Race (% white): | | | Quality rating:
Funding: | Uncontrolled, open-label trial | | D1: 89.5 | | | Fair
Glaxo Wellcome Inc | Overall study N: | | Baseline (HAM-A):
| 3100 | | NR
| Intervention: | | Baseline HAM-D:
| D1: Bupropion: 100–300 mg/d | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Both treatment groups showed sig decreases in MADRS and CGI scores from baseline at all wks starting at wk 2 | Overall adverse events: | Overall attrition rate:
Ekselius et al., 1997 | To compare efficacy and safety of SER with CIT in patients with major depression | - Adults 18 to 70; - Diagnosed with MDD according to DSM-III or -IV; - MADRS at least 21 | D1: 47.0 | No sig diffs between treatment groups in any primary outcome variables at any time | D1: 90 D2: 85.5 | 22%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 47.2 | Response rates | Cardiovascular adverse events: | ITT analysis:
Sweden | 24 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies; - Previous treatment with SER or CIT w/o sig effect | Sex (% female): | Wk 12: | D1: 3 D2: 4 | Yes
Multicenter (general physicians) | Study design: | | D1: 71 | SER: 69.5% | Changes in weight (decrease): | Quality rating:
Funding: | RCT | | D2: 72.5 | CIT: 68.0% | D1: 4.5 D2: 9.5 | Good
Swedish Medical Research Council, Pfizer | Overall study N: | | Race (% white): | Wk 24: | Changes in weight (increase):
| 400 | | NR | SER: 75.5% | D1: 15 D2: 13
| Intervention: | | Baseline (HAM-A): | CIT: 81.0% | Constipation:
| D1: Sertraline: 50–100 mg/d | | NR | Compliance: | D1: 3 D2: 2
| D2: Citalopram: 20–60 mg/d | | Mean HAM-D score at baseline: | SER 90.3% | Diarrhea:
| | | NR | CIT 94.5% | D1: 8.5 D2: 5.5
| | | | | Headache:
| | | | | D1: 9 D2: 6.5
| | | | | Insomnia:
| | | | | D1: 3.5 D2: 6
| | | | | Nausea:
| | | | | D1: 6 D2: 2.5
| | | | | Sexual dysfunction:
| | | | | D1: 4 D2: 6.5
| | | | | Somnolence (fatigue):
| | | | | D1: 5 D2: 4.5
| | | | | Sweating (increase):
| | | | | D1: 13 D2: 17
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No statistically sig diffs between SER and CIT in magnitude or frequency of adverse sexual side effects | Overall adverse events: | Overall attrition rate:
Ekselius et al., 2001 | Examination of occurance and severity of sexual dysfunction symptoms in depressed patients before and after 6 mos of treatment | - Adults 18 and over; - Diagnosed with MDD according to DSM-III or -IV; - MADRS of 21 or more | NR | Female patients reporting no sexual dysfunction at baseline, 11.8% reported decreased sexual desire and 14.3% reported orgasmic dysfunction | NR | N/A
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | Male patients reporting no sexual dysfunction at baseline, 16.7% reported decreased sexual desire, 18.9% reported orgasmic dysfunction, 25% experienced ejaculatory dysfunction | | ITT Analysis
Sweden | 24 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Clinically sig medical disease | NR | | | No, completers analysis
General practice | Study design: | | Race (% white): | | | Quality rating:
Funding: | RCT, completers only analysis | | NR | | | Fair for adverse event reporting
Pfizer AB Swedish Medical Research Council | Overall study N: | | Baseline (HAM-A):
| 308 | | NR
| Intervention: | | Baseline HAM-D:
| D1: Citalopram: 20–60 mg/d (33.9) | | NR
| D2: Sertraline: 50–150 mg/d (82.4)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No statistically sig diffs between FLUO, SER and PAR in baseline-to-endpoint improvement in HAM-D total (overall P = 0.323) | Diarrhea: | Overall attrition rate:
Fava et al., 2000 | To compare tolerability and efficacy of FLUO, PAR and SER in treatment of anxious depression | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 16; - HAM-D-Anxiety/ Somatization Factor score of at least 7 | D1: 40.3 | No sig diffs in efficacy and tolerability of FLUO, SER, and PAR in treating anxious depression | D2: 25.6 | NR
Country and setting: | Duration of study: | Exclusion criteria: | D2: 44.1 | For all treatments, incidence of substantial emergence or any worsening was low with improvement at highest frequency for all HAM-D items | D3: 20.0 | ITT analysis:
United States | 10 to 16 wks (4 wks with additional wks determined by response on CGI) | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies; - Presence of seizure disorder with seizure in last yr; - History of allergy to study drugs; - Use of MAOIs within 2 wks of active therapy | D3: 41.4 | | Headache: | Yes
Multicenter (15 sites) | Study design: | | Sex (% female): | | D1: 22.9 | Quality rating:
Funding: | RCT | | D1: 65.7 | | D2: 25.6 | Fair
Eli Lilly Research | Overall study N: | | D2: 62.8 | | D3: 23.3
| 108 (drawn from larger sample of 284 MDD outpatients) | | D3: 66.7 | | Insomnia:
| Intervention: | | Race (% white): | | D1: 17.1
| D1: Fluoxetine: 20–60 mg/d | | NR | | D2: 23.3
| D2: Sertraline: 50–200 mg/d | | Baseline (HAM-A): | | D3: 23.3
| D3: Paroxetine: 20–60 mg/d | | NR | | Nausea:
| | | Mean HAM-D score at baseline: | | D3: 26.7
| | | D1: 23.6 (3.9) | | Somnolence (fatigue):
| | | D2: 23.9 (3.4) | | D1: 11.4
| | | D3: 25.0 (3.8) | | D2: 16.3
| | | | | D3: 10.0
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig diffs among 3 treatment groups in degree of depression and anxiety improvement | Cardiovascular adverse events: | Overall attrition rate:
Fava et al., 1998 | Efficacy and tolerability of PAR and FLUO | - Minimum HAM-D score of 18; - Raskin Depression score of > 8 (and larger in value than Covi anxiety scale) | D1: 41.3 | | D1: 5 | 28%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 41.3 | | D2: 11 | ITT analysis:
United States | 12 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - ECT within last 3 mos; - Suicidal tendencies | D3: 41.3 | | D3: 11 | Yes
Multicenter (5 sites) | Study design: | | Sex (% female): | | Insomnia: | Quality rating:
Funding: | RCT | | D1: 50 | | D1: 29 | Fair
SmithKline, Beecham | Overall study N: | | D2: 50 | | D2: 20
| 128 | | D3: 50 | | D3: 11
| Intervention: | | Race (% white): | | Sexual dysfunction:
| D1: Paroxetine: 20–50 mg/d (initial dosage of 20 mg/d could be increased wkly by 10 mg/d up to 50 mg/d) | | NR | | D1: 25
| D2: Fluoxetine: 20–80 mg/d (initial dosage of 20 mg/d could be increased wkly by 20 mg/d up to 80 mg/d) | | Baseline (HAM-A): | | D2: 7
| D3: placebo | | NR | | D3: 0
| | | Mean HAM-D score at baseline:
| | | D1: 23.1 (3.4)
| | | D2: 23.9 (3.8)
| | | D3: 23.7 (12.2)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig diffs in changes of HAM-D score between treatment groups | NR | Overall Attrition rate:
Feighner et al., 1991 | Efficacy and safety of BUP and FLUO in depressed outpatients | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20 | D1: 40.9 | No sig diffs in percentage of clinical responders (more than 50% HAM-D scale reduction) between treatment groups, BUP: 62.7%, FLUO: 58.3% | | 7.3%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 42.9 | No sig diffs in changes of CGI-S, CGI-I, and HAM-A scores | | ITT Analysis:
United States | 6 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies | Sex (% female): | Higher rate of impotence (4.7% vs 0%), anorgasmia (1.7% vs 0%), and libido decrease (1.7% vs 0%) for FLUO (P = NR) | | Yes
Multicenter (2 sites) | Study design: | | D1: 62 | | | Quality rating:
Funding: | RCT | | D2: 61 | | | Fair
Burroughs Wellcome Co | Overall study N: | | Race (% white):
| 123 | | NR
| Intervention: | | Baseline (HAM-A):
| D1: Bupropion: 225–450 mg/d (382) | | NR
| D2: Fluoxetine: 20–80 mg/d (38) | | Mean HAM-D score at baseline:
| | | D1: 25.3
| | | D2: 26.1
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | More SER treated patients had reemergence of sexual dysfunction than nefazadone-treated (76% vs. 26%; P < 0.001); similar response rate for both treatments (numerical data NR) | Overall adverse events: | Overall attrition rate:
Ferguson et al., 2001 | To compare effects of NEF and SER on reemergence rates of sexual dysfunction in depressed patients who'd had sexual dysfunction with previous SER treatment | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV; - Receiving SER and experiencing attributable sexual dysfunction | D1: 43.2 | | D1: 100 | 32%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 44.8 | | D2: 97 | ITT Analysis
United States | 8 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Investigational drug use within last 30 days | Sex (% female): | | Sexual dysfunctional (male ejaculation): | Yes
Multicenter (9 sites) | Study design: | | D1: 46 | | D1: 76 | Quality rating:
Funding: | RCT | | D2: 48 | | D2: 26 | Fair
Bristol Myers Squibb | Overall study N: | | Race (% white):
| 75 | | D1: 95
| Intervention: | | D2: 97
| D1: Nefazodone: 200–400 mg/d | | Baseline (HAM-A):
| D2: Sertraline: 50–100 mg/d | | NR
| | | Baseline HAM-D:
| | | D1: 11.5
| | | D2: 10.5
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Mean change (SD) in body weight: | Cardiovascular adverse events: | Overall attrition rate:
Goldstein et al., 1997 | To assess effect of FLUO 20 mg/d on weight loss in older patients | - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 16; - Adults 60+ | D1: 68 | Low/normal BMI: | D1: 2.7 | NR
Country and setting: | Duration of study: | Exclusion criteria: | D2: 68 | FLUO -0.88 (2.11) | D2: 3.3 | ITT Analysis
United States | 6 wks (after a 1-wk placebo lead-in) | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder not related to depression; - Clinically sig medical disease; - Suicidal tendencies; - Score less than 25 on MMSE; - History of allergic reaction to FLUO; - History of nonresponse to at least 2 antidepressants at usual doses | Sex (% female): | Placebo 0.11 (1.96) (P < 0.001) | Changes in weight (decrease): | No another type of analysis was used (define): included patients with complete data only
multicenter, outpatient trial | Study design: | | D1: 55 | High BMI: | D1: 3.3 | Quality rating:
Funding: | RCT | | D2: 55 | FLUO -1.14 (1.99) | D2: 1.2 | Fair for AE reporting
Lilly | Overall study N: | | Race (% white): | Placebo 0.04 (1.72) (P < 0.001)
| 671 | | D1: 94 | Pooled:
| Intervention: | | D2: 94 | FLUO -1.01 (2.05)
| D1: Fluoxetine: 20 mg/d | | Baseline (HAM-A): | Placebo 0.08 (1.85) (P < 0.001)
| D2: Placebo | | NR | % with weight loss of at least 5%
| | | Baseline HAM-D: | low/normal BMI:
| | | NR | FLUO 2.4
| | | | Placebo 1.1 (P = 0.225)
| | | | High BMI:
| | | | FLUO 3.7
| | | | Placebo 0 (P = 0.021)
| | | | Pooled:
| | | | FLUO 3.1
| | | | Placebo 0.6 (P = 0.017)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | On 21-item HAM-D, diffs between MIR and placebo were statistically sig at 2, 3, 4, and 6 wks. Using MADRS, statistically sig diffs were found between both active compounds and placebo at wks 2 and 3. MIR and TRA were associated with sig higher frequencies of dizziness and blurred vision as compared to placebo | Cardiovascular adverse events: | Overall attrition rate:
Halikas, 1995 | To assess clinical efficacy and safety of “ldquo;Org 3770”rdquo; (MIR) and TRA in treatment of elderly outpatients with moderate to severe depression | - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18; - Age 55+; - Able to complete Zung Self Rating Depression Scale; - Chloral hydrate (500 mg) at bedtime was permitted | D1: 63 | At wk 6, 51% of MIR and 41% of TRA treated patients were HAM-D responders (not statistically sig) | D1: 2% Tachycardia; 4% Palpitations | 27%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 61 | Mean weight gain in MIR group = 1.3 kg | D2: 12% Tachycardia; 12% Palpitations | ITT analysis:
United States University | 6 wks | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - ECT within last 3 mos of baseline; - Suicidal tendencies; - Rapid placebo responders (reduction of 20%+ in total HAM-D score) | D3: 62 | | D3: 2% Tachycardia; 2% Palpitations | Yes
Funding: | Study design: | | Sex (% female): | | Constipation: | Quality rating:
Organon, Inc | RCT | | D1: 42.9 | | D1: 18 | Fair
| Overall study N: | | D2: 60.4 | | D2: 24
| 150 | | D3: 59.2 | | D3: 16
| Intervention: | | Race (% white): | | Dizziness:
| D1: Mirtazapine: 5–35 mg | | NR | | D1: 22
| D2: Trazodone: 40–280 mg | | Baseline (HAM-A): | | D2: 27
| D3: placebo | | NR | | D3: 8
| | | Mean HAM-D score at baseline: | | Headache:
| | | D1: 24.6 | | D1: 14
| | | D2: 24.6 | | D2: 20
| | | D3: 23.5 | | D3: 20
| | | | | Nausea:
| | | | | D1: 10
| | | | | D2: 14
| | | | | D3: 14
| | | | | Somnolence (fatigue):
| | | | | D1: 54
| | | | | D2: 55
| | | | | D3: 22
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | FLUO reduces sig reduction of body mass in depressed patients | NR | Overall attrition rate:
Harto et al., 1988 | To determine if FLUO produces weight loss and to examine predictive factors | - Adults 18 to 65; - MDD diagnosis according to DSM-III or -IV; - Minimum HAM-D score of 20 | D1: 39 | BMI change score- at wk 6 a statistically sig diff was evident between placebo and FLUO (F 3.23) = 6.81 (P < 0.002) | | NR
Country and setting: | Duration of study: | Exclusion criteria: | D2: 38.4 | | | ITT analysis:
United States | 6 wks | - Investigational drug is within last 28 days; - Additional mental illnesses or organic mental disorder; - Concomitant psychotheraputic or psychtropic medications; - History of seizure | D3: 43.8 | | | No
NR | Study design: | | D4: 36.4 | | | Quality rating:
Funding: | Cannot determine | | Sex (% female): | | | Fair
Not Reported | Overall study N: | | D1: 75
| 35 | | D2: 50
| Intervention: | | D3: 70
| D1: Placebo | | D4: 56
| D2: Fluoxetine 5mg | | Race (% white):
| D3: Fluoxetine 20 | | NR
| D4: Fluoxetine 40 | | Baseline (HAM-A):
| | | NR
| | | Mean HAM-D score at baseline:
| | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Suicidal behavior risk: | NR | Overall attrition rate:
Jick et al., 2004 | To estimate risk ratios of nonfatal suicidal behavior in patients starting treatment with 1 of 3 antidepressant drugs vs. patients starting treatment with dothiepin | - Using antidepressants | NR | D1: RR 1.16 (95% CI 0.90–1.50) | | N/A
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | D2 vs D3: RR 1.29 (95% CI 0.97–1.70) | | ITT Analysis
UK | 1993-1999 | NR | D1: 65.4 | Suicide risk increased in first mo after starting antidepressants, especially during first 9 days (RR 4.07; 95% CI 2.89–5.74) | | NR
General practices using GPRD | Study design: | | D2: 66.8 | | | Quality rating:
Funding: | Matched case-control | | Race (% white): | | | N/A
Boston Collaborative Drug Surveillance Program | Overall study N: | | NR
| 159,810 | | Baseline HAM-A:
| Intervention: | | NR
| D1: Case | | Baseline HAM-D:
| D2: Controls | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | 143 sucides within 6 mos of using antidepressants | N/A | Overall attrition rate:
Jick et al., 1995 | To estimate rate and means of suicide among people taking 10 commonly prescribed antidepressants | - Received a prescription for 1 or more antidepressant in VAMP database (General Practice Research Database); - All patients who committed suicide identified in cohort evaluation were included as cases | NR | Rates of suicide higher in men than women (RR 2.8, 95% CI: 1.9 – 4.0), people with history of feeling suicidal (RR 19.2, 95% CI: 9.5 – 38.7), and people who had taken several different antidepressants (RR 2.8, 95% CI: 1.8 – 4.3) | | N/A
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | From cohort analysis: overall rate of suicide for all antidepressant users: 8.5/10,000 person yrs (95% CI 7.2 – 10.0); FLUO: 19.0/10,000, adjusted RR: 2.1 (95% CI 1.1–4.1); TRA: 14.8/10,000, adjusted RR: 1.7 (95% CI 0.6 – 4.6), both relative to dothiepin | | ITT Analysis
UK | Patient records from Jan 1988 to Feb 1993 | - Not reported | NR | Compared with dothiepin, only FLUO and mianserin yielded RRs that were sig raised | | Not applicable-observational study
General practices in UK using VAMP database | Study design: | | Race (% white): | | | Quality rating:
Funding: | Cohort study with nested case-control analysis | | NR | | | Fair
Various pharmaceutical companies (Berlex, Boots, Burroughs Wellcome, Ciba-Geigy, Hoeschst, Hoffman-LaRoche, RW Johnson, Pfizer, Proctor and Gamble, Sanofi Winthrop) | Overall study N: | | Baseline (HAM-A):
| 172,598 | | NR
| Intervention: | | Baseline HAM-D:
| Fluoxetine | | NR
| Trazodone
| Dothiepin
| Amitriptyline
| Clomipramine
| Imipramine
| Flupenthixol
| Lofepramine
| Mianserin
| Doxepin
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | FLUO does not directly cause suicidal behavior at a substantially higher frequency than do lofepramine, mianserin, and TRA | N/A | Overall attrition rate:
Jick et al., 1992 | Evaluate whether FLUO causes important increased risk of suicidal behavior by reiviewing previously gathered data from practitioners | - Age 15 to 74; - Patients who received a px for FLUO, lofepramine, mianserin, or TRA. From this list, all who had diagnosis of aggressive, abusive, suicidal behavior | NR | | | N/A
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | | | ITT Analysis
United Kingdom | Jan 1988 to April 1990 | NR | NR | | | Not applicable-observational study
General practice | Study design: | | Race (% white): | | | Quality rating:
Funding: | Database review | | NR | | | Fair
Burroughs Wellcome | Overall study N: | | Baseline (HAM-A):
| 8730 | | NR
| Intervention: | | Baseline HAM-D:
| Mianserin and Lofepramine | | NR
| D1: Fluoxetine
| D2: Trazodone
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Observed seizure rate was 0.24% for treatment phase and 0.40% for entire study. 8-wk survival analysis performed on patients with a dosing regimen of 300 to 450 mg/d yielded a cumulative rate of 0.36% | NR | Overall attrition rate:
Johnston et al., 1991 | To determine incidence of seizures associated with use of BUP | - Adults 18 and over; - Diagnosis of depression for which antidepressant treatment was clinically appropiate | Overall: 43.5 | Rate of seizure for BUP within range of other antidepressants | | 39%
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | | | ITT Analysis
United States | 8 wk treatment stage with unlimited humanitarian continuation phase | - Pregnant; - Lactating; - Investigational drug use within last 30 days; - Previous diagnosis of bulimia or anorexia nervosa; - Known predisposition of seizures | Overall: 59.4 | | | N/A
Multicenter (102 sites) | Study design: | | Race (% white): | | | Quality rating:
Funding: | Uncontrolled, open-label trail | | Overall: 96 | | | Fair
Burroughs Wellcome | Overall study N: | | Baseline (HAM-A):
| 3341 | | NR
| Intervention: | | Baseline HAM-D:
| D1: Bupropion: 300–450 mg/d | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | FLUO group experienced fewer interruption-emergent symptoms (DESS mean diff in change = -2.4 with 95% CI = -3.9 to -1.0; P = 0.001) than PAR group | Diarrhea: | Overall attrition rate:
Judge et al., 2002 | To compare mean number of interruption-emergent events during 3 to 5 day placebo interruption period in remitted, depressed patients on maintenance therapy with FLUO or PAR | - Adults 18 and older; - Unipolar depression on effective maintenance with FLUO or PAR; - Current maintenance lasting between 4 and 24 mos; - MADRS ≤ 12 | D1: 41.5 | Symptoms occuring sig more in PAR patients were: panic, depersonalization, shaking, muscle aches, dyspnoe, stomach cramps, agitation, sleeping problems, dizziness, chills, vomiting, nausea or diarrhea, parasthesia | D2: 10+ | 6%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 44.7 | | Dizziness: | ITT Analysis
Multinational; outpatient | Placebo interruption period = 3–5 days, but unclear total duration of observation | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder not related to depression; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies; - Seizure within last yr | Sex (% female): | | D2: 33+ | N/A: Cannot tell if ITT was used; however, attrition was so low that ITT would have made little diff in results
Funding: | Study design: | | D1: 80 | | Headache: | Quality rating:
Eli Lillly | Open-label, parallel-group study with double-blind, crossover, placebo interruption phase | | D2: 73.3 | | D1: 14 | Fair
| Overall study N: | | Race (% white): | | D2: 10+
| 150 | | NR | | Insomnia:
| Intervention: | | Baseline (HAM-A): | | D2: 20+
| D1: Fluoxetine: 20–60 mg/d | | NR | | Nausea:
| D2: Paroxetine: 20–50 mg/d | | Baseline HAM-D: | | D2: 20+
| | | NR | | Somnolence (fatigue):
| | | | | D1: 17
| | | | | D2: 20+
| | | | | Suicidality:
| | | | | Sweating (increase):
| | | | | D2: 20+
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | After controlling for baseline covariates (age, gender, insurance type, titration rates, mental health specialty care, diagnoses, and comorbidity) patients initiating IR SSRIs were 13.6% less likely to be compliant than patients initiating par CR (P = 0.0001) | NR | Overall attrition rate:
Keene et al., 2005 | To evaluate differential compliance rates between IR SSRIs and CR SSRIs in patients initiating SSRI therapy | - Adults 18 and older; - Anxiety or depression according to ICD9CM; - Patients with an SSRI script but no diagnosis also included | D1: 42.9 | Patients on PAR IR least likely to be compliant when compared to PAR CR (21.2% less likely, P = 0.0001), followed by ESC (15.0% less likely, P = 0.0179), SER (12.3% less likely,P = 0.0005), CIT (9.1% less likely,P = 0.0114), and FLUO (8.4% less likely,P = 0.0250) | | N/A
Country and setting: | Duration of study: | Exclusion criteria: | D2: 41.8 | | | ITT Analysis
United States | 6 mos of follow-up | - Antidepressant in 6 mos prior to index date, continuously eligible for 6 mos prior to index date and during follow-up period; - Patients with a psychosis-related diagnosis of schizophrenia or bipolar disorders; - Antipsychotic within 6 mos previous to or within 1 yr of index date | Sex (% female): | | | N/A- observational study
IHCIS National Managed Care Benchmark Database | Study design: | | D1: 69.3 | | | Quality rating:
Funding: | Observational | | D2: 62.6 | | | Fair
GlaxoSmithKline | Overall study N: | | Race (% white):
| 116,090 | | NR
| Intervention: | | Baseline (HAM-A):
| Citalopram | | NR
| Escitalopram | | Baseline HAM-D:
| Fluoxetine | | NR
| Paroxetine(IR and CR formulations)
| Sertraline
| D1: SSRI IR
| D2: Paroxetine CR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Men reported sig greater drug-induced impairment of drive/desire [mean (SD) = 2.26 (2.02) vs. 1.43(2.12), t = 6.23, df = 107, (P < 0.05) | NR | Overall attrition rate:
Kennedy et al., 2000 | To evaluate disturbances in sexual drive/desire and arousal/orgasm in depressed patients who completed 8 wks of study | - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 16; - Sexual activity within past mo; - Major depression with or without other secondary non-psychotic axis I disorders; - No antidepressants within 2 wks (or 5 wks for FLUO) | NR | No signficant diffs between antidepressants among men reporting antidepressant-induced sexual dysfunction | | 38.5%
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | Women showed lower rates of dysfunction on VEN compared to PAR and SER, however, only one item (“difficulty achieving orgasm”rdquo;) reached statistical significance (chi-sq = 8.51, df = 1, P < 0.004). for VEN vs. PAR, VEN introduced sig less difficulty with having an orgasm than PAR (chi-sq = 2.98, df = 1, P < 0.08) | | ITT Analysis
Canada | 14 wks (primary endpoint is 8 wks) | - Clinically sig medical disease | D1: 84.6 | | | N/A
Depression clinic | Study design: | | D2: 33.3 | | | completer analysis only
Funding: | Prospective cohort study | | D3: 61.1 | | | Quality rating:
Centre for Addiction and Mental Health Foundation | Overall study N: | | Race (% white): | | | Fair for AE reporting
| 174 | | NR
| Intervention: | | Baseline (HAM-A):
| D1: Sertraline: 50–200 mg/d | | NR
| D2: Paroxetine: 10–80 mg/d | | Baseline HAM-D:
| D3: Venlafaxine: 37.5–375 mg/d | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | By objective | NR | Overall attrition rate:
Landen et al., 2005 | To determine: | - No response to CP or px for a minimum of 4 wks prior to start of study | 46 | 1 Side effect elicitation method: sig more patients (49 versus 6) reported sexual side effects in response to direct questioning than open questioning (P < 0.001); 2 Incidence of side effects by drug: no statistically sig diffs between paroxetine and paroxetine groups in sexual side effects reported or sexual dysfunction score; open-ended questioning: CIT 5%, PAR 7% (P = 0.98); direct questioning: CIT 44%, PAR 36% (P = 0.37); 3 Correlations with illness severity and treatment parameters: only weak correlation with duration of current depression episode (P = 0.043) | | N/A
Country and setting: | 1) concordance of sexual dysfunction AE rates between open-ended questioning and directed questioning; 2) incidence of sexual side effects of CIT and PAR; 3) correlation between sexual side effects and illness severity, treatment duration and drug/dose combination | Exclusion criteria: | Sex (% female): | | | ITT Analysis
Sweden and Norway | Duration of study: | - Epilepsy | 69 | | | NR
Multicenter (13 sites) | 4 wks | | Race (% white): | | | Quality rating:
Funding: | Study design: | | NR | | | Fair
NR | Non-randomized trial of AE elicitation methods embedded in RCT | | Baseline HAM-A:
| Overall study N: | | NR
| 119 | | Baseline HAM-D:
| | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | PAR and active control were sig better than palcebo in reducing suicidal thoughts and behavior from wk 1 onwards | N/A | Overall attrition rate:
Lopez-Ibor, 1993 | Effect of PAR on suicidality in depressed patients | - Depressed patients in a clinical trial | NR | | | N/A
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | | | ITT Analysis
Spain | Up to 6 wks | - NR | NR | | | N/A- observational study
Database analysis | Study design: | | Race (% white): | | | Quality rating:
Funding: | Database analysis | | NR | | | Fair
Not reported | Overall study N: | | Baseline (HAM-A):
| 4668 | | NR
| Intervention: | | Baseline HAM-D:
| D1: Paroxetine | | NR
| D2: Placebo
Author: | Research objective: | Inclusion criteria: | Survey Response rate: | FLUV had a considerably higher incidence of side-effects associated with its use than other 3 SSRIs and 36% of GPs expressing an opinion reported FLUV as effective, compared with approximately 60% for FLUO, SER, and PAR | Dizziness: | Overall attrition rate:
Mackay et al., 1997, 1999 | To compare safety and side-effect profiles of four selective serotonin reuptake inhibitor antidepressants (SSRIs), FLUV, FLUO, SER and PAR in a cohort study | - Patients prescribed SSRIs | 60% | The most common reason for stopping treatment was nausea/vomitting for all 4 SSRIs | D1: 9.6 | N/A
Country and setting: | Duration of study: | Exclusion criteria: | Mean age (yrs): | | D2: 2.7 | ITT Analysis
UK | NA | None | D1: 51 | | D3: 2.8 | N/A- observational study
General practice | Study design: | | D2: 50 | | D4: 4.0 | Quality rating:
Funding: | Cross sectional - prescription event monitoring | | D3: 49 | | Headache: | Fair
Reported as “many pharmacetical companies”rdquo; | Overall study N: | | D4: 49 | | D1: 10.1
| 50,150 | | Sex (% female): | | D2: 5.7
| Intervention: | | D1: 70.1 | | D3: 5.4
| D1: Fluvoxamine | | D2: 69.8 | | D4: 4.8
| D2: Fluoxetine | | D3: 68.6 | | Nausea:
| D3: Sertraline | | D4: 67.5 | | D1: 42.8
| D4: Paroxetine | | Race (% white): | | D2: 9.0
| | | NR | | D3: 8.6
| | | Baseline (HAM-A): | | D4: 13.0
| | | NR
| | | Baseline HAM-D:
| | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No diff in risk of non-fatal self harm among different SSRIs (P = 0.35) | N/A | Overall attrition rate:
Martinez et al., 2005 | To compare risk of non-fatal self harm and suicide in patients taking SSRIs with that of patients taking tricyclic antidepressants, as well as between different SSRIs and different tricyclic | - Age < 90; - First prescription for antidepressants between 1/1/1995 and 12/31/2001 | 31 of patients in age cohort 31 to 45 yrs old | No diff in risk of self-harm between SSRIs and tricyclic antidepressants (OR: 0.99 CI: 0.86 to 1.14) | | N/A
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | No diff in risk of suicide between SSRIs and tricyclic antidepressants (OR: 0.57 CI: 0.26 to 1.25) | | ITT Analysis
UK | 1995 to 2001 | - None | Overall: 65 | | | Not applicable-observational study
General practice research database (clinical primary care records in UK) | Study design: | | Race (% white): | | | Quality rating:
Funding: | Nested case-control study | | NR | | | Good
Medicines and Healthcare Products Regulatory Agency | Overall study N: | | Baseline (HAM-A):
| 146,095 | | NR
| Intervention: | | Baseline HAM-D:
| D1: Citalopram | | NR
| D2: Fluoxetine
| D3: Fluvoxamine
| D4: Paroxetine
| D5: Sertraline
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | 2.2 AEs per SER patient vs. 2.1 AEs per other SSRIs patient | Overall adverse events: | Overall attrition rate:
Meijer et al., 2002 | To evaluate safety profile of SER versus other SSRIs directly following introduction of SER to Dutch market | - All patients with a new SER prescription; consecutive patients taking FLUO, FLUV, or PAR used as controls | 41 (median) | 73.4% of SER patients and 75.0% of other SSRI patients reported an AE | D1: 73.4 | N/A
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | Diarrhea was reported more frequently by SER patients than patients taking other SSRIs (P < 0.05) | D2: 75 | ITT Analysis
The Netherlands | 12 mo observation period | - No additional exclusion criteria were applied | 64.1% | Abdominal pain was reported more frequently by other SSRI users (P < 0.05) | Cardiovascular adverse events: | N/A- observational study
Multicenter (109 psychiatrists in general hospitals, regional institutes of mental health, or private practices) | Study design: | | Race (% white): | No sig diffs in serious adverse event (SAE) reporting found between SER patients (5.0%) and patients using other SSRIs (4.6%) | D1: 3.2 | Quality rating:
Funding: | Cohort study | | NR | Suicide attempt: SER: 0.9% vs. other SSRIs: 1.2% | D2: 2.2 | Fair
Pfizer, Inc | Overall study N: | | Baseline (HAM-A): | | Diarrhea:
| 1,251 | | NR | | D1: 14
| Intervention: | | Baseline HAM-D: | | D2: 6.8
| D1: Sertraline | | NR | | Dizziness:
| D2: Other SSRIs (Fluoxetine Fluvoxamine Paroxetine) | | | | D1: 11.4
| | | | | D2: 11.8
| | | | | Headache:
| | | | | D1: 19.3
| | | | | D2: 17.1
| | | | | Insomnia:
| | | | | D1: 8
| | | | | D2: 5.9
| | | | | Nausea:
| | | | | D1: 24.3
| | | | | D2: 27
| | | | | Sexual dysfunctional (male ejaculation):
| | | | | D1: 2.1
| | | | | D2: 3.7
| | | | | Sweating (increase):
| | | | | D1: 13.4
| | | | | D2: 11.7
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No diff in weight change between FLUO and placebo groups after 50 wks (1.6 kg vs. 1.6 kg) | Changes in weight (increase): | Overall attrition rate:
Michelson et al., 1999 (goes with Reimherr et al., 1998) | To assess changes in weight during long-term treatment with FLUO or placebo | - Adults 18+; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 16 | D1: 40.8 | | D1: 1.6kg | NR
Country and setting: | Duration of study: | Exclusion criteria: | D2: 42.2 | | D2: 1.6kg | ITT Analysis
United States | 50 wks | - None reported | Sex (% female): | | | Yes
Academic centers (5 sites) | Study design: | | D1: 68.3 | | | Quality rating:
Funding: | RCT | | D2: 73.3 | | | Fair
Eli Lilly | Overall study N: | | Race (% white):
| 839 acute phase | | NR
| 395 remission phase | | Baseline (HAM-A):
| Intervention: | | NR
| D1: Fluoxetine: 20 mg/d | | Baseline HAM-D:
| D2: Placebo | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Overall incidence of sexual dysfunction was 59.1% | N/A | Overall attrition rate:
Montejo et al., 2001 | Incidence of sexual dysfunction associated with anti-depressant agents | - Normal sexual functioning prior to taking antidepressants; - Treatment with antidepressant alone or combine with benzodiazepine; - Previous regular and satisfactory sexual practices; - Occurrence of sexual dysfunction within 2 mos after introduction of antidepressant | Overall: 39.8 | Incidence of overall sexual dysfunction: | | N/A
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | FLUO, 57.7% | | ITT Analysis
Spain | Carried out between April 1995 and February 2000 | - Prior sexual dysfunction; - Combination of antidepressant and neuroleptic treatment; - Treatment with hormones or any other drug capable of interfering with sexual intercourse; - Sig intercurrent diseases affecting sexual function; - Substance abuse | Overall: 60 | SER, 62.9% | | Not applicable-observational study
Multicenter | Study design: | | Race (% white): | FLUV, 62.3% | | Quality rating:
Funding: | Prospective cohort study | | NR | PAR, 70.7% | | Fair
Bristol-Myers Squibb | Overall study N: | | Baseline (HAM-A): | CIT, 72.7%
| 1,022 | | NR | VEN, 67.3%
| Intervention: | | Baseline HAM-D: | MIR, 24.4%
| Citalopram | | NR | NEF, 8%
| Fluoxetine | | | Men had a higher frequency of sexual dysfunction (62.4%) than women (56.9%), although women had higher severity
| Fluvoxamine
| Mirtazapine
| Nefazodone
| Paroxetine
| Sertraline
| Venlafaxine
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Both treatment groups resulted in sig improvements of depression scores compared to baseline | Overall adverse events: | Overall attrition rate:
Nemeroff et al., 1995 | Comparison of efficacy and safety of FLUV and SER in treatment of depression | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20; - HAM-D depressed mood item of at least 2; - Covi anxiety score less than Raskin score; - Minimum score of 8 on Raskin Depression Scale | D1: 41.2 | No sig diff in efficacy between treatment groups | D1: 93.5 | 28%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 38.5 | | D2: 85.7 | ITT analysis:
United States | 7 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Patients itolerant of SSRI side effects | Sex (% female): | | Diarrhea: | Yes
Multicenter | Study design: | | D1: 60.9 | | D1: 23.9 | Quality rating:
Funding: | RCT | | D2: 61.2 | | D2: 14.3 | Fair
Solvay Pharmaceuticals | Overall study N: | | Race (% white): | | Dizziness:
| 95 | | D1: 84.8 | | D1: 15.2
| Intervention: | | D2: 98.0 | | D2: 12.2
| D1: Sertraline: 50–200 mg/d (137.1) | | Baseline (HAM-A): | | Headache:
| D2: Fluvoxamine: 50–150 mg/d (123.8) | | NR | | D1: 32.6
| | | Mean HAM-D score at baseline: | | D2: 26.5
| | | D1: 23.15 (2.77) | | Insomnia:
| | | D2: 24.57 (3.66) | | D1: 34.8
| | | | | D2: 26.5
| | | | | Nausea:
| | | | | D1: 21.7
| | | | | D2: 30.6
| | | | | Sexual dysfunction:
| | | | | D1: 28
| | | | | D2: 10
| | | | | Somnolence (fatigue):
| | | | | D1: 17.4 asthenia-13
| | | | | D2: 24.5 asthenia-6.1
| | | | | Sweating (increase):
| | | | | D1: 10.9
| | | | | D2: 6.1
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Incidence of sexual function impairment was 61.5% (Phys-SFR) with SSRIs. Male erection and ejacualation impaired in 44.3% and 39.3% of SSRI group, respectively. No statistical diff between each SSRI | NR | Overall attrition rate:
Philip et al., 2000 | To compare emergent sexual effects of moclobemide and SSRIs during acute and maintenance therapy in routine practice | - Diagnosed with MDD according to DSM-III or -IV; - Depressive disorder of at least mild severity; - On either moclobemide or SSRI (FLUO, FLUV, PAR, SER); - Interested in sexual activity | Overall: 42 | Higher rates in SSRI's vs. moclobemide | | 27.2%
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | | | ITT Analysis
Autralia, Germany; outpatient private practice | 6 mo | - No combination therapy | Overall: 49.8 | | | N/A- observational study
Funding: | Study design: | | Race (% white): | | | Quality rating:
Not reported | Prospective cohort study | | NR | | | Fair
| Overall study N: | | Baseline (HAM-A):
| 268 | | NR
| Intervention: | | Baseline HAM-D:
| D1: Fluoxetine: 20–60 mg/d | | NR
| D2: Fluvoxamine: 50–300 mg/d
| D3: Paroxetine: 10–50 mg/d
| D4: Sertraline: 50–150 mg/d
| D5: Other: moclobemide 300–1200 mg/d
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No statistically sig diffs observed between 2 groups on any efficacy parameter | Headache: | Overall attrition rate:
Rapaport et al., 1996 | To compare efficacy, safety, and tolerance of FLUV and FLUO in a depressed outpatient population | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20; - Minimum score of 2 on depressed mood item at screening and baseline visits (HAM-D) | D1: 40.0 | Medications were well tolerated, with only 2 patients in each group terminated because of side effects. FLUV was associated with less nausea than FLUO | D1: 50 | 16%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 38.6 | | D2: 53 | ITT Analysis
United States, multicenter | 7 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder not related to depression; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies; - Previous treatment with FLUO or FLUV; - History of seizure disorder | Sex (% female): | | Insomnia: | Yes
Funding: | Study design: | | D1: 62 | | D1: 36 | Quality rating:
Solvay Pharmaceuticals, Inc.; The Upjohn Company | RCT | | D2: 63.2 | | D2: 28 | Fair
| Overall study N: | | Race (% white): | | Nausea:
| 100 | | D1: 92.2 | | D2: 42.5
| Intervention: | | D2: 98 | | P = 0.030
| D1: Fluvoxamine: 100–150 mg; endpoint mean = 101.85 (25.22) | | Baseline (HAM-A): | | Suicidality:
| D2: Fluoxetine: 20–80 mg; endpoint mean = 34.17 (18.84) | | D1: 16.0 | | D1: 2
| | | D2: 16.2 | | D2: 2
| | | Baseline HAM-D: | | Vomiting
| | | D1: 25.2 | | D1: 4
| | | D2: 25.6 | | D2: 13
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | CGI-I responders (CGI-I of much or very much improved) | Overall adverse events: | Overall attrition rate:
Schatzberg et al., 2002 | To compare efficacy and tolerability of MIR with PAR in elderly patients with MDD | - Adults 65 or older; - MDD diagnosis according to DSM-III or -IV; - Minimum HAM-D score of 18; - MMSE above 25% for age and educational level | D1: 71.7 | At endpoint | D1: 79.7 | 26.8%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 72.0 | MIR (80) 64.0% | D2: 82.5 | ITT analysis:
United States | 8 wk acute phase, optional 16 wk continuation phase | - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - ECT within last 6 mos; - Suicide attempts; - MAOIs within 14 days, other psychotropic drugs or herbals within 7 days; - PAR or MIR for current depressive episode; - Patients requiring drugs for memory deficit; - Patients who did not respond to or tolerate MIR or PAR during a previous depressive episode | Sex (% female): | PAR (68) 56.7% | Changes in weight (increase): | Yes
Mutli-center (recruited from advertising, private practice, routine intake at clinics and other healthcare facilities) | Study design: | | D1: 50% | chi square 1.23 (P = 0.267) | D1: 10.9 | Quality rating:
Funding: | RCT | | D2: 53% | | D2: 0 | Fair
Organon Pharmacueticals | Overall study N: | | Race (% white): | | Constipation:
| 255 | | NR | | D1: 11.7
| Intervention: | | Baseline (HAM-A): | | D2: 11.1
| D1: Mirtazapine: 15 mg/d up to 45 mg/d | | NR | | Diarrhea:
| D2: Paroxetine: 20 mg/d up to 40 mg/d | | Mean HAM-D score at baseline: | | D1: 14.8
| | | D1: 22.2 (3.5) | | D2: 17.5
| | | D2: 22.4 (3.5) | | Dizziness:
| | | | | D1: 15.6
| | | | | D2: 14.3
| | | | | Headache:
| | | | | D1: 15.6
| | | | | D2: 24.6
| | | | | Insomnia:
| | | | | D1: 11.7
| | | | | D2: 11.1
| | | | | Nausea:
| | | | | D1: 6.3
| | | | | D2: 19.0
| | | | | Somnolence (fatigue):
| | | | | D1: 30.5
| | | | | D2: 29.4
| | | | | Sweating (increase):
| | | | | D1: 6.3
| | | | | D2: 13.5
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Rate of falls per 100 person-yr | NR | Overall attrition rate:
Thapa et al., 1998 | To compare rate of falls between nursing home residents using SSRIs and TCAs | - Adults 65 or older; - Nursing home residents who were new users of antidepressants, in facility more than 30 days | D1: 83 | PAR- 301 RR 95% CI 2.3 (2.1–2.6) Adjusted RR 1.7 (1.5–1.9) | | N/A
Country and setting: | Duration of study: | Exclusion criteria: | D2: 82.1 | FLUO- 314 RR 95% CI 2.4 (2.1–2.8) Adjusted RR 1.8 (1.6–2.1) | | ITT Analysis
United States | N/A | NR | D3: 82.1 | SER- 342 RR 95% CI 2.6 (2.3–3.0) Adjusted RR 1.8 (1.5–2.1) | | N/A
53 rest homes | Study design: | | D4: 82.2 | TRA- 244 RR 95% CI 1.9 (1.7–2.1) Adjusted RR 1.2 (1.0–1.4) | | Retrospective Cohort
Funding: | Observational | | Sex (% female): | | | Quality rating:
CDC and FDA | Overall study N: | | D1: 75.9 | | | Fair
| Cohort- 2,428 | | D2: 75.2
| Intervention: | | D3: 74
| D1: Non-users (847) | | D4: 73
| D2: TCAs (665) | | Race (% black):
| D3: SSRIs (612) | | D1: 13.2
| D4: Trazodone (304) | | D2: 5.1
| | | D3: 5.9
| | | D4: 6.6
| | | Baseline HAM-A:
| | | NR
| | | Baseline HAM-D:
| | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig diff in percent of responders at day 56, (MIR: 40.1% vs. FLUO: 41.4 %) | Overall adverse events: | Overall attrition rate:
Versiani et al., 2005 | To compare effectiveness and tolerability of MIR and FLUO in severe MDD and compare effects on anxiety, sleep and QOL | - Adults 18 to 65; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 25 | D1: 43 | Both treatment groups showed 18 point improvement on QLSQ | D1: 50 | 14%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 47 | | D2: 45 | ITT analysis:
Multinational, Multicenter (30 sites) | 8 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Investigational drug use within last 30 days; - ECT within last 3 mos; - Suicidal tendencies | Sex (% female): | | Changes in weight (increase): | Yes
Funding: | Study design: | | D1: 74 | | D1: 6.9 | Quality rating:
Organon, NV | RCT | | D2: 69 | | D2: 1.3 | Fair
| Overall study N: | | Race (% white): | | Dizziness:
| 299 | | NR | | D1: 9
| Intervention: | | Baseline (HAM-A): | | D2: 12.8
| D1: Mirtazapine: 30–60 mg | | NR | | Headache:
| D2: Fluoxetine: 20–40 mg | | Mean HAM-D score at baseline: | | D1: 19.3
| | | D1: 29 (3) | | D2: 18.8
| | | D2: 28(3) | | Insomnia:
| | | | | D1: 4.8
| | | | | D2: 8.7
| | | | | Nausea:
| | | | | D1: 15.9
| | | | | D2: 24.1
| | | | | Somnolence (fatigue):
| | | | | D1: 13.8
| | | | | D2: 9.4
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig diffs in any outcome measures between treatment groups (LOCF and observed) | Constipation: | Overall Attrition Rate:
Weihs et al., 2000 | Comparison of efficacy and safety of BUP and PAR with PAR in treatment of MDD in elderly | - Adults 60+; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18 | D1: 69.2 | Response rates ≥ 50% reduction in HAM-D) were similar in both groups: | D1: 4 | 16%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 71.0 | BUP sr: 71% | D2: 15 | ITT Analysis:
United States | 6 wks | - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies | Sex (% female): | PAR: 77% | Diarrhea: | Yes
Multicenter | Study design: | | D1: 54 | No sig diffs in QOL scales (QLDS, SF-36) between treatment groups at endpoint; overall sig improvement in QLDS and QOL at day 42 (P < 0.0001) | D1: 6 | Quality rating:
Funding: | RCT | | D2: 60 | Compliance: | D2: 21 | Fair
Glaxo Wellcome | Overall study N: | | Race (% white): | BUP 95% | Dizziness:
| 100 | | D1: 98 | PAR 98% | D1: >10
| Intervention: | | D2: 90 | | D2: >10
| D1: Bupropion: 100–300 mg/d (197) | | Baseline (HAM-A): | | Headache:
| D2: Paroxetine: 10–40 mg/d (22) | | NR | | D1: 35
| | | Mean HAM-D score at baseline: | | D2: 19
| | | NR | | Insomnia:
| | | | | D1: >10
| | | | | D2: >10
| | | | | Nausea:
| | | | | D1: >10
| | | | | D2: >10
| | | | | Somnolence (fatigue):
| | | | | D1: 6
| | | | | D2: 27
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | HAM-D (LOCF) | Constipation: | Overall attrition rate:
Weisler et al., 1994 | To compare safety and efficacy of BUP and TRA | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20; - Episode of 4 wks to 2 yrs; - Clinically approrpiate for therapy | D1: 40.2 | Center 1 | D1: 9.68 | 40.3%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 40.8 | BUP: | D2: 11.67 | ITT Analysis:
Country NR, appears to be United States | 6 wks (after a 1 wk single-blind placebo lead-in to eliminate placebo responders and placebo nontolerators) | - Pregnant/Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies; - Male with a history of priapism or being treated with medications associated with priapism; - Prior treatment with BUP or TRA, currently taking digoxin or phenytoin | Sex (% female): | at day 42, BUP stat sig better than TRA (P < 0.01) | Diarrhea: | Yes
2 private psychopharmacology clinics | Study design: | | D1: 52.4 | When centers were combined, no statistically sig diffs between TRA and BUP were observed | D1: 4.84 | Quality rating:
Funding: | RCT | | D2: 65.6 | Responder analysis (responder ≥ 50% reduction in HAM-D score between baseline and discontinuation) | D2: 11.67 | Fair
Burroughs Wellcome Co | Overall study N: | | Race (% white): | BUP = 33 (55.9%) | Dizziness:
| 124 | | D1: 90.5 | TRA = 21 (40.4%) | D1: 20.97
| Intervention: | | D2: 90.2 | Remitters (>50% reduction and a HAM-D score<10) | D2: 30.00
| D1: Bupropion: 225–450 mg/d | | Baseline (HAM-A): | BUP = 27 (46%) | Headache:
| D2: Trazodone: 150–400 mg/d | | NR | TRA = 16 (31%) | D1: 33.87
| | | Mean HAM-D score at baseline: | CGI-I responders | D2: 23.33
| | | D1: 25.8 (NR) | BUP = 34 (57.6%) | Insomnia:
| | | D2: 25.0 (NR) | TRA = 24 (46.2%) | D1: 14.52
| | | | Compliance | D2: 5.00
| | | | BUP 94.7% | Nausea:
| | | | TRA 90.1% | D1: 11.29
| | | | | D2: 6.67
| | | | | Somnolence (fatigue):
| | | | | D1: 8.06
| | | | | D2: 45.00
| | | | | Sweating (increase):
| | | | | D1: 9.68
| | | | | D2: 5.00
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | HAM-D responders at endpoint (≥ 50% improvment) | Dizziness: | Overall attrition rate:
Wheatley et al., 1998 | To compare efficacy and tolerability of MIR and FLUO in depressed inpatients and outpatients | - Adults 18 to 75; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 21; - HAM-D item 1 (depressed mood) score ≥ 2; - Depressive episode duration 2 wks to 12 mos | D1: 47.2 | MIR ~65% (n = 39) | D1: 7.6% | 28.6%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 47.5 | FLOU ~45% (n = 28) (P = NS) | D2: 9.0% | ITT analysis:
Multinational | 6 wks (after a 3–7 day single-blind, placebo washout period) | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Nonresponders to antidepressant treatment | Sex (% female): | Remission from depression (HAM-D < 7 at endpoint): | Headache: | Yes
Multicenter | Study design: | | D1: 55 | MIR 23.3% | D1: 9.1% | Quality rating:
Funding: | RCT | | D2: 58.7 | FLUO 25.4% (P = 0.39) | D2: 17.9% | Fair
NV Organon | Overall study N: | | Race (% white): | CGI responders (much or very much approved): | Nausea:
| 133 | | NR | MIR 63.3% | D1: 3.0%
| Intervention: | | Baseline (HAM-A): | FLUO 54.0% (P = 0.677) | D2: 10.4%
| D1: Mirtazapine: 15–60 mg/d | | NR | Q-LES-Q estimated treatment diff (MIR minus FLUO): 2.14 95% CI (-2.30, 6.58) (P = 0.348) | Somnolence (fatigue):
| D2: Fluoxetine: 20–40 mg/d | | Mean HAM-D score at baseline: | | D1: 18.2%
| | | D1: 26.0 (4.4) | | D2: 13.4%
| | | D2: 26.1 (4.3)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Overdosing and seizure experience on venlafaxine: | NR | Overall attrition rate:
Whyte et al., 2003 | To assess toxicity in overdose of venlafaxine and SSRIs compared to TCAs | - First time admissions for overdose with an SSRI or TCA | D1: 36 | D1: 13.7% | | N/A
Country and setting: | Duration of study: | Exclusion criteria: | D2: 29 | D2: 1.3% | | ITT Analysis
Australia | Taken from database records between November 1994 and April 2000 | - Patients who took a MAOI; - Patients ingesting more than one drug of interest; - Second and subsequent admissions for deliberate DSPs | Sex (% female): | (P < 0.001) | | NR
Hospital (Hunter Area Toxicology Service Database) | Study design: | | D1: 68.6 | Overdosing required ICU admission: | | Quality rating:
Funding: | Cohort study of prospectively collected data | | D2: 67 | D1: 29.4% | | Good
NR | Overall study N: | | Race (% white): | D2: 7.3%
| 538 (284 venlafaxine and other SSRI records) | | NR | (P < 0.01)
| Intervention: | | Baseline HAM-A: | No other sig diffs between venlafaxine and SSRI overdoses
| D1: Venlafaxine | | NR
| D2: Other SSRIs | | Baseline HAM-D:
| | | NR

Evidence Table 5. KQ4: Systematic reviews and meta-analyses on safety, adverse events, or adherence

Study Characteristics | Study Information | Study Characteristics | Results | Adverse Events | Assessments | Study Appraisals and Quality Rating
Author: | Study design: | Included Studies: | Study Results: | NR | Publication Bias: | Standard Method of Study Appraisals:
Aursnes et al., 2005 | Pooled analysis | Clinical data on paroxetine as presented to world's drug regulatory agencies in 1989 | 7 suicide attempts in patients on drug and 1 in a patient on placebo. Probability of increased intensity of suicide attempts per yr in adults taking paroxetine was 0.90 with a “pessimistic” prior, and somewhat less with 2 more neutral priors | | No | NR
Country and setting: | Number of Patients: | Included Populations | | | Heterogeneity: | Quality Rating:
NR | 1,466 | NR | | | No | Fair
Funding: | Studies Included: | Interventions:
None | 16 studies with unpublished data | Paroxetine versus placebo, no other info provided
Author: | Study design: | Included Studies: | Study Results: | NR | Publication Bias: | Standard Method of Study Appraisals:
Brambilla et al., 2005 | Meta-analysis | - All studies with random assigned patients that received FLUO or any other antidepressant; - Cross-over studies and those with patients with concomitant medical illness were excluded | - 59.4% of patients treated with FLUO and 59.3% of patients treated with other SSRIs experienced AEs.RR 1.00 95% CI 0.95, 1.04; - FLUO less withdrawals due to side effects than TCAs and other related Ads RR 0.61 95% CI 0.52, 0.71 but not in comparison to other SSRIs RR 1.04 95% CI 0.84, 1.29; - FLUO had less side effects (50.9%) than TCAs (60.3%) RR = 0.84 95% CI 0.76 to 0.94(P = 0.03); - FLUO patients had more activating and GI adverse effects and less cholinergic side effects than other ADs | | Yes | Yes
Country and setting: | Number of Patients: | Included Populations | | | Heterogeneity: | Comprehensive Search Strategy:
NR | 15,920 | Patients with MDD | | | Yes | Yes
Funding: | Studies Included: | Interventions: | | | | Quality Rating:
Multinational | 131 studies | - Fluoxetine vs. tricyclic antidepressant (65 studies); - Fluoxetine vs. SSRI (22 studies); - Fluoxetine vs. another AD (44 studies) | | | | Good
Research objective:
To assess frequency of side-effects in FLUO compared to other SSRIs, TCAs and other anti-depressants
Author: | Study design: | Included Studies: | Study Results: | NR | Publication Bias: | Standard Method of Study Appraisals:
Fergusson et al., 2005 | Systematic review | RCTs comparing an SSRI with either placebo or an active non-SSRI | A sig increase in odds of suicide attempts was found in patients receiving SSRIs compared to patients receiving placebo (OR: 2.28; CI: 1.144 –4.55, P = 0.02) | | NR | Yes—independent review of all citations by 3 authors
Country and setting: | Number of Patients: | Included Populations | No diffs in actual suicides between SSRIs and placebo were found (OR: 0.95; CI: 0.24–3.78) | | Heterogeneity: | Comprehensive Search Strategy:
Canada | 36,445 | - All patients included in trials comparing SSRIs to either placebo or non-SSRI control; - No age, gender, or diagnosis restrictions | No sig diff found in odds of suicide attempts between patients receiving SSRIs and patients receiving tricyclic antidepressants (OR: 0.88; CI: 0.54 –1.42) | | Yes | Yes
Funding: | Studies Included: | Interventions: | | | | Systematic literature search to identify all RCTs of SSRIs indexed on Medline between 1967 and 2003; search of Cochrane Collaboration's register of controlled trials for trials produced by Cochrane depression, anxiety, and neurosis group; reviewed biliographies of 3 systematic reviews to identify relevant trials and reports
Canadian Institutes of Health Research | 345 RCTs | Patients randomized to either an SSRI, placebo, or non-SSRI control for any clinical condition | | | | Quality Rating:
Research objective: | | | | | | Good
To establish if an association exists between SSRI use and suicide attempts
Author: | Study design: | Included Studies: | Study Results: | NR | Publication Bias: | Standard Method of Study Appraisals:
Greist et al., 2004 | Pooled analysis | Double-blind, randomized, placebo or active-controlled trials of DUL | No sig diffs in nausea between DUL (40–120 mg/d), PAR (20 mg/d) (14.4% vs. 12%, P -NR), and FLUO (20mg) (17.1% vs. 15.7%, P -NR) | | No | NR
Country and setting: | Number of Patients: | Included Populations | No sig diffs between DUL (120 mg/d) and FLUO (20 mg/d) (17.1% vs. 15.7%, P -NR) | | Heterogeneity: | Comprehensive Search Strategy:
US (6 studies); Europse (2 studies) | 2,345 | Adult outpatients with MDD | Sig more DUL- than placebo-treated patients reported nausea (19% vs. 6.9%, P < 0.001) | | No | No; analysis of all published and unpublished trials
Funding: | Studies Included: | Interventions: | Incidence of treatment-emergent nausea dudring 6-mo continuation of DUL (80 mg/d or 120 mg/d) was similar to placebo (2.1% vs. 1.3% vs. 1.6%) | | | Quality Rating:
Eli Lilly | - Detke et al., 2002; - Detke et al., 2002; - Goldstein et al., 2002; - Goldstein et al., 2004; - 4 unpublished studies submitted for FDA approval of DUL | - Duloxetine vs. Placebo (8 studies); - Duloxetine vs. Paroxetine (4 studies); - Duloxetine vs. Fluoxetine (2 studies) | Following abrupt discontinuation after 8 mos of treatment, nausea was reported by 1.6% of DUL (120 mg/d) patients vs. 0% for those receiving DUL (80 mg/d) and 0% for placebo | | | N/A
Research objective:
To assess incidence, severity and onset of nausea among MDD patients treated with DUL
Author: | Study design: | Included Studies: | Study Results: | NR | Publication Bias: | Standard Method of Study Appraisals:
Gunnell et al., 2005 | Meta-analysis | Randomized, placebo controlled trials of SSRIs (CIT, ESC, FLUO, FLUV, PAR, and SER) submitted by pharmaceutical companies | No sig diff was found between SSRI treatment and placebo treatment in odds ratios for suicide (OR: 0.85 CI: 0.2 to 3.4), or suicidal thought (OR: 0.77 CI: 0.37 to 1.55) | | Yes | Yes
Country and setting: | Number of Patients: | Included Populations | Non-fatal self harm (OR: 1.57 CI: 0.99 to 2.55) was more common in SSRI-treated than in placebo treated patients but did not reach statistical significance. For non-fatal self-harm NNH is 759 | | Heterogeneity: | Comprehensive Search Strategy:
Multinational | 40,826 | Adult patients with various indications included in trials comparing SSRIs to placebo | | | Yes, vaguely | No (published and unpublished data submitted by pharmaceutical companies; review does not include studies from sources other than pharmaceutical companies)
Funding: | Studies Included: | Interventions: | | | | Quality Rating:
NR | - Published and unpublished data submitted by pharmaceutical companies to Medicine and Healthcare Products Regulatory Agency (MHRA) (2004); - 342 placebo controlled trials included in report - citations not given in bibliography | Patients randomized to either SSRI or placebo | | | | Good
Research objective:
To investigate whether SSRIs are associated with an increased risk of suicide related outcomes in adults
Author: | Study design: | Included Studies: | Study Results: | NR | Publication Bias: | Standard Method of Study Appraisals:
Khan et al., 2003 | Meta-analysis | FDA clinical trial data | No statistically sig diff in suicide rates between SSRIs, other antidepressants, and placebo (P > 0.05) | | NR | NR
Country and setting: | Number of Patients: | Included Populations | Absolute Suicide Rate | | Heterogeneity: | Comprehensive Search Strategy:
US | 48,277 | - Major depression according to DSM-III-R criteria; - Minimum score of 18 or 20 on HAM-D-17 or HAM-D-21 | - SSRI: 0.15% (0.10–0.20% 95% CI); - “Other”: 0.20% (0.09–0.27% 95% CI); - Placebo: 0.10% (0.01–0.19% 95% CI); - P > 0.05 for diff | | No | No
Funding: | Studies Included: | Interventions: | Suicide Rate by Patient Exposure Yrs (PEY) | | | Quality Rating:
NR | - Pooled analysis of FDA clinical trial data from 1985-2000 for 9 SSRIs; - 2000 publication reports on 1987 to 1997 (same data) | Fluoxetine | - SSRI: 0.59%/PEY (0.31–0.87 95% CI); - “Other”: 0.76%/PEY (0.49–1.03 95% CI); - Placebo: 0.45%/PEY (0.01–0.89 95% CI); - P > 0.05 for diff | | | Fair
Research objective: | | Sertraline
Compare suicide rates among depressed patients | | Paroxetine
| | Citalopram
| | Fluvoxamine
| | Nefazodone
| | Mirtazapine
| | Bupropion
| | Venlafaxine
| | Imipramine
| | Amitrptyline
| | Maprotiline
| | Trazodone
| | Mianserin
| | Dothiepin
Author: | Study design: | Included Studies: | Study Results: | Adverse Events: | Publication Bias: | Standard Method of Study Appraisals:
Nieuwstraten and Dolovich, 2001 | Meta-analysis | - RCTs; - Study durations: 6 to 16 wks; - Median 7 wks | Results of HAM-D scores and CGI-I scores could not be pooled due to unavailability of data; weighted mean diffs of CGI-S and HAM-A scores not sig different between bupropion and SSRIs | Nausea, diarrhea, and somnolence occurred sig less frequently in BUP group compared to SSRI group RR: nausea: 0.6 (95%CI: 0.41–0.89), diarrhea: 0.31 (95%CI: 0.16–0.57), somnolence: 0.27 (95% CI: 0.15–0.48). Satisfaction with sexual function was sig less in SSRI group RR: 1.28 (95% CI: 1.16–1.41) | No | Yes
Country and setting: | Number of Patients: | Included Populations | | | Heterogeneity: | Quality Rating:
Canada | 1,332 | - Age: 36 to 70 yrs; - Proportion of females: 48.0% to 61.8% | | | Yes- indirectly | Good
Funding: | Studies Included: | Interventions: | | | | Comprehensive Search Strategy:
NR | - Kavoussi RJ et al. 1997; - Segraves RT, et al. 2000; - Weihs KL, et al. 2000; - Croft H, et al. 1999; - ColemanCC, et al. 1999; - Feighner JP, et al. 1991 | Bupropion vs. sertraline (3 trials) | | | | Yes
| | Bupropion vs. paroxetine (1 trial)
| | Bupropion vs. fluoxetine (1 trial)
Author: | Study design: | Included Studies: | Study Results: | NR | Publication Bias: | Standard Method of Study Appraisals:
Pedersen, 2005 | Retrospective cohort study | Studies are from adult clinical database at H. Lund | MADRS item 10 (suicidal thoughts): ESC patients had fewer suicidal thoughts than placebo from wks 1 (P < 0.05) to 8 (P < 0.001) | | No | Yes
Country and setting: | Number of Patients: | Included Populations | Suicides in placebo-controlled studies: | | Heterogeneity: | Quality Rating:
Denmark | 4091 | Adult outpatients with MDD (2,277) or anxiety (371) | ESC n = 0 | | No | Fair
Funding: | Studies Included: | Interventions: | Rate = 0 | | | Comprehensive Search Strategy:
Drug Development, H. Lundbeck A/S | 12 placebo-controlled studies and 2 relapse prevention studies | Escitalopram and placebo | Incidence = 0 | | | No
| | | Placebo n = 1
| | | Rate = 0.003
| | | Incidence = 0.1
| | | Non-fatal self harm in placebo controlled studies:
| | | ESC n = 5
| | | Rate = 0.011
| | | Incidence = 0.2
| | | Placebo n = 1
| | | Rate = 0.003
| | | Incidence = 0.1
Author: | Study design: | Characteristics of Included Studies: | Study Results: | Adverse Events: | Publication Bias: | Standard Method of Study Appraisals:
Perahia et al., 2005 | Pooled analysis (9 trials: 6 short-term treatment trials, 2 extension trials and 1 open trial) | - Conducted in US, Europe, and Latin America; - 8 studies randomized, double blind, placebo controlled trials, examining 8–9 wks of acute treatment (2 had 26-wk placebo-controlled extension phase and grouped as long-term treatment); - 1 study was a 52-wk open-label trial | In 6-study pooled analysis, significanlty more DUL patients (44.3%) had > 1 DEAE than placebo (22.9%) (P = NR). Dizziness most common symptom in all groups analyzed. Mild, moderate, and severe DEAEs were 39.8%, 50.6%, and 9.6% for DUL vs. 46%, 48.9%, and 5.0% for placebo. Withdrawal due to DEAEs occured in 3.1% of DUL patients and 0% of placebo. A higher, but nonlinear, incidence of DEAEs was seen with 120 mg/d compared to lower doses | Events registered as DEAEs if they occured for first time or worsened following discontinuation of treatment. Observation period for DEAEs was 2 wks | No | Not described
Country and setting: | Number of Patients: | Characteristics of Included Populations | In 2 long-term studies, significanlty more DUL patients (9.1%) had > = 1 DEAE than placebo-treated (2.0%) (P = NR). Mild, moderate, and severe DEAEs were 70.6%, 26.5%, and 2.9% for DUL group. No difference in DEAEs between 80 and 120 mg/d groups. 47.5% of DEAEs resolved prior to final contact with study patients. | | Heterogeneity: | Comprehensive Search Strategy:
NR | 3,624 | - Depression defined by DSM-IV; - Baseline total HAMD-17≥15; - Baseline CGI-S >+4 | In open label study 50.8% reported ≥1 DEAE | | No | Not described
Funding: | Studies Included: | Characteristics of Interventions: | | | | Quality Rating:
Eli Lilly and Company | 9 multicenter clinical trials assessing efficacy and safety of DUL in treatment of major depressive disorder | - DUL (40–120 mg/d); - DUL discontinued, followed by lead-out phase of 1 or 2 wks; - Placebo-controlled trials, placebo given during lead-out phase | | | | Fair
Research objective:
To characterize DEAEs of DUL hydrochloride
Author: | Study design: | Included Studies: | Study Results: | N/A | Publication Bias: | Standard Method of Study Appraisals:
Thase et al., 2005 | Pooled analysis | - Placebo-controlled studies | Greater change in heart rate for DUL vs. FLUO and PAR: mean change of 2.8 bpm for DUL vs. -1.0 bpm for FLUO (P < 0.01); mean change of 1.0 bpm for DUL vs. -1.4 bpm for PAR (P < 0.001) | | No | Yes
Country and setting: | Number of Patients: | Included Populations | DUL had slightly lower mean change in systolic BP than FLUO (2.3 mm Hg vs. 3.2 mm Hg) | | Heterogeneity: | Comprehensive Search Strategy:
Multinational | 2,345 | - 18 yrs of age or older; - Current primary MDD diagnosis as defined in DSM-IV; - HAM-D score >15; - CGI-S score >4 | No statistically sig diffs in systolic and diastolic BP for DUL vs. FLUO or PAR | | No | No
Funding: | Studies Included: | Interventions: | Mean changes in QTcF and QRS intervals not sig different for DUL vs. PAR | | | Quality Rating:
Eli Lilly and Mental Health Intervention Center | 8 placebo-controlled studies | Duloxetine | | | | Fair
| | Fluoxetine
| | Paroxetine
Author: | Study design: | Included Studies: | Study Results: | NR | Publication Bias: | Standard Method of Study Appraisals:
Thase et al., 1998 | Meta-analysis | Acute and continuation phase data from randomized controlled trials comparing VEN with placebo and IMI (21 outpatient and 6 inpatient trials at 180 different sites) | Acute phase at 6 wks: | | Yes | Yes
Country and setting: | Number of Patients: | Included Populations | - Mean increase in supine DBP: VEN 1.02 mmHG; - Sustained elevation in supine DBP: VEN: 4.8%, placebo 2.1% (P = 0.015 for crude group comparison and P = 0.086 after adjustment for age/sex); - Incidence of supine DBP > 90 mmHg: VEN: 11.5%, placebo 5.7% (P < 0.001 VEN vs placebo) | | Heterogeneity: | Comprehensive Search Strategy:
United States | 3,744 | - Meet DSM-III-R criteria for a current principal diagnosis of major depression; - Score at least 20 on 21-item HAM-D; - Have no poorly controlled or serious medical illness | Continuation Phase Results: | | Yes | No
Funding: | Studies Included: | Interventions: | - Mean supine DBP: no drug effect P = 0.58; - 4.5% (21 of 467) with normal supine DBPs developed elevated readings during this phase and it was sig higher in VEN group P = 0.058; - A sig dose response effect on BP was seen in VEN group (P < 0.001) | | | Quality Rating:
NR | Original data for statistical analysis were provided by Wyeth-Ayerst Laboratories | D1: Venlafaxine | | | | Fair
Research objective: | | D2: Imipramine
To assess effects of VEN on BP | | D3: Placebo

Evidence Table 6. KQ5: Efficacy, effectiveness, or harms of antidepressants in subpopulations

Study Characteristics | Research Objective | Inclusion/Exclusion | Baseline Characteristics | Health Outcome Results | Adverse Events (%) | Analysis and Quality Rating
| Duration
| Study Design
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No statistically sig diffs between treatments in any outcome measures (MADRS, CGI-S, CGI-I) | Overall adverse events: | Overall attrition rate:
Allard et al., 2004 | Compare efficacy and tolerability of VEN ER 75–150 mg/d with CIT 10–20 mg/d in elderly patients with major depression according to DSM-IV criteria | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV | D1: 73.6 | Response rates were 93% in both groups at wk 22 | D1: 62 | 22.2
Country and setting: | Duration of study: | Exclusion criteria: | D2: 72.5 | MADRS remission rate was 19% for VEN and 23% for CIT (P = NR) | D2: 43 | ITT Analysis
Sweden and Denmark | 6 mos | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Uncontrolled hypertension, sig cardiovascular or cerebrovascular disorders | Sex (% female): | Side effects were common during both treatments but differed in tremor being more common during CIT and nausea/vomiting during VEN treatment. | Constipation: | Yes
Multicenter (12) | Study design: | | D1: 73.6 | | D1: 6.6 | Quality rating:
Funding: | RCT | | D2: 72.7 | | D2: 2.7 | Fair
Wyeth | Overall study N: | | Race (% white): | | Dizziness:
| 151 | | NR | | D1: 34
| Intervention: | | Baseline (HAM-A): | | D2: 30
| D1: Venlafaxine: 37.5–150 mg/d | | NR | | Headache:
| D2: Citalopram: 10–30 mg/d | | Baseline HAM-D: | | D1: 26
| | | NR | | D2: 31
| | | | | Nausea:
| | | | | D1: 30
| | | | | D2: 16
| | | | | Sweating (increase):
| | | | | D1: 2.6
| | | | | D2: 2.7
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Sig improvement was seen in patients treated with CIT compared to placebo (P < 0.05) | NR | Overall attrition rate:
Andersen et al., 1994 | To investigate efficacy and safety of CIT in treatment of post-stroke depression in post-stroke patients | - Adults 25 to 80; - Minimum HAM-D score of 13; - Concomitant condition: post-stroke; - Diagnosed with PSD according to DSM-III | D1: 68.2 | | | 13.6%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 65.8 | | | ITT Analysis
Denmark | 6 wks | - Additional mental illnesses or organic mental disorder; - Subarachnoid or Binswanger's disease or other degenerative diseases; - Patients with decreased consciousness, dementia, or aphasia to such a degree that they could not explain themselves or gave conflicting verbal and nonverbal signals | Sex (% female): | | | Yes
2 hospitals and an outpatient clinic | Study design: | | D1: 64 | | | Quality rating:
Funding: | RCT | | D2: 58 | | | Fair
Lundbeck Foundation | Overall study N: | | Race (% white):
| 66 | | NR
| Intervention: | | Baseline (HAM-A):
| D1: Citalopram: 10–40 mg/d | | NR
| D2: Placebo | | Baseline HAM-D:
| | | D1: 19.4 (3.1)
| | | D2: 18.9 (2.8)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | ITT analysis: mean decrease in HSCL-D-20; PAR: 0.88 (0.08), placebo: 0.85 (0.09); behavior therapy: 0.79 (0.09), no sig diffs between arms | NR | Overall attrition rate:
Barrett et al., 2001 | To compare PAR vs. placebo vs. behavioral treatment for dysthymia and minor depression in primary care patients | - Adults 18 to 59; - Minimum HAM-D score of 10; - Dysthymia | D1: 45.2 | Remission by HAM-D-17 score < 6: PAR: 80%, placebo: 44.4%; behavior therapy: 56.8% (P = 0.008 for diff among all 3 arms) | | 20.7%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 42.6 | Minor depression: PAR 60.7%, placebo 65.6%; behavior therapy 65.5% (P = 0.906 for diff among all 3 arms) | | ITT analysis:
United States | 11 wks | - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Suicidal tendencies; - Current depression treatment | Sex (% female): | | | Yes
Multicenter, primary care clinics | Study design: | | D1: 57.5 | | | Quality rating:
Funding: | RCT | | D2: 66.7 | | | Fair
Hartford and MacArthur Foundation | Overall study N: | | Race (% white):
| 241 | | D1: 90
| Intervention: | | D2: 89
| D1: Paroxetine 10–40 mg/d, individually titrated | | Baseline (HAM-A):
| D2: placebo | | NR
| | | Mean HAM-D score at baseline:
| | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | At wk 4 sig improvements in depression were seen in BDI and BSI (P < 0.05) | Cardiovascular adverse events: | Overall attrition rate:
Blumenfield et al., 1997 | To test safety and efficacy of FLUO in patients with renal failure on dialysis | - Adults 18 to 70; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 16; - Concomitant condition: renal failure | NR | At endpoint, wk 8, there were no longer any diffs between fluo and placebo in depression scores | D1: 67 | 7.1%
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | No withdrawals due to AEs | D2: 14 | ITT Analysis
United States (New York) | 8 wks | - Pregnant; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Clinically sig medical disease; - Investigational drug use within last 4 wks; - Suicidal tendencies | NR | | Constipation: | Yes
2 inpatient centers | Study design: | | Race (% white): | | D1: 0 | Quality rating:
Funding: | RCT | | NR | | D2: 14 | Fair
Lilly Research Laboratories | Overall study N: | | Baseline (HAM-A): | | Diarrhea:
| 14 | | NR | | D1: 17
| Intervention: | | Baseline HAM-D: | | D2: 14
| D1: Fluoxetine: 20mg/d | | NR | | Dizziness:
| D2: Placebo | | | | D1: 17
| | | | | D2: 0
| | | | | Headache:
| | | | | D1: 50
| | | | | D2: 0
| | | | | Insomnia:
| | | | | D1: 33
| | | | | D2: 14
| | | | | Nausea:
| | | | | D1: 83
| | | | | D2: 29
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Using LOCF, response rates were 58.2% in DUL vs. 32.2% in placebo group (P = 0.003, cell = 1, 1, P = 0.008). Remission rates were 34.6% in DUL and 18.6% in placebo group (P = 0.027, cell = 1, 1, P = 0.006). Magnitude of treatment effect was similar in women aged 40–55 compared to older and younger women | NR | Overall attrition rate:
Burt et al., 2005 | To assess efficacy of DUL in depressed women ages 40 to 55 yrs | - Adults 18 to no max given; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 15; - CGI-S ≥ 4 at 2 consecutive screening visits | D1: 47.7 | | | N/A
Country and setting: | Duration of study: | Exclusion criteria: | D2: 46.4 | | | ITT Analysis
US; multicenter | 9 wks | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Treatment-resistant depression; lack of response of current depression episode to 2+ adequate treatment courses | Sex (% female): | | | N/A Post-hoc analysis
Funding: | Study design: | | D1: 100 | | | Quality rating:
Eli Lilly and Co | Post-hoc analysis of pooled data from 2 identical, but independent, randomized, double-blind studies | | D2: 100 | | | Fair Post-hoc analysis
| Overall study N: | | Race (% white):
| 114 | | D1: 80.0
| Intervention: | | D2: 72.6
| D1: Duloxetine: 60 mg/d | | Baseline (HAM-A):
| D2: Placebo | | NR
| | | Baseline HAM-D:
| | | D1: 21.3 (4.4)
| | | D2: 21.5 (3.5)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Both treatment groups showed sig improvements in cognitive performance on all test scales | Overall adverse events: | Overall attrition rate:
Cassano et al., 2002 | To assess efffects of PAR and FLUO on mood and cognitive function in depressed non-demented geriatric patients | - Adults 18 or older; - Minimum HAM-D score of 18; - ICD-10, mini mental state, Raskin, Covi Anxiety | D1: 75.6 | No sig diffs between treatment groups and cognitive performance except for Buschke test at wk 3 and 6 where PAR showed a sig greater improvement on a number of tests | D1: 27.6 | 39.3%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 74.9 | Both treatment groups sig improved HAM-D total scores but overall no diffs in HAM-D improvement between treatment groups | D2: 32.8 | ITT Analysis
Italy | 1 yr | - Additional mental illnesses or organic mental disorder not related to depression; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies | Sex (% female): | Kaplan Meier analysis evaluating percentage of responders (HAM-D < 10) over time showed a sig diff in favor of PAR (P < 0.03) | Cardiovascular adverse events: | No another type of analysis was used (define): Observed case
Multicenter (38 centers) | Study design: | | D1: 61 | No sig diffs on CGI scores | D1: 6.5 | Quality rating:
Funding: | RCT | | D2: 50 | | D2: 7.5 | Fair
SmithKline, Beecham | Overall study N: | | Race (% white):
| 242 | | NR
| Intervention: | | Baseline (HAM-A):
| D1: Paroxetine: 20–40 mg/d | | NR
| D2: Fluoxetine: 20–60 mg/d | | Baseline HAM-D:
| | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig differences in response rates between treatment groups | NR | Overall attrition rate:
Devanand, 2005 | FLUO vs. placebo for treatment of dysthymia in patients over 60 | - Minimum HAM-D score of 8, max score 25; - Dysthymia; - Adults at least 60 yrs old; - CGI-s score ≥ 3 | D1: 69.0 | Responders: FLUO: 27.3%, placebo: 19.6% (P = 0.4) | | 21%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 70.8 | No sig differences in QOL measures on Q-LES-Q | | ITT analysis:
United States | 12 wks | - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Active suicidal ideation or plan; - MDD during current dysthymia episode; - Lack of response of current episode to prior trial of any SSRI; - Major neurologic disorder; - MMSE <24 | Sex (% female): | | | Yes
Outpatient clinic | Study design: | | D1: 32.6 | | | Quality rating:
Funding: | RCT | | D2: 40.9 | | | Good
NIMH | Overall study N: | | Race (% white):
| 90 | | D1: 86.4
| Intervention: | | D2: 89.1
| D1: Fluoxetine: 20–60 mg (individually titrated by protocol according to response) | | Baseline (HAM-A):
| D2: placebo | | NR
| | | Mean HAM-D score at baseline:
| | | D1: 15.3 (5.1)
| | | D2: 14.4 (3)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Clinical response (response = CGI of much or very much improved) | Diarrhea: | Overall attrition rate:
Ferrando et al., 1997 | To assess effectiveness and tolerability of SER, PAR, and FLUO in treatment of depressed patients with medically symptomatic HIV or AIDS | - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 17; - Symptomatic HIV infection (CDC stage B2, or B3) or AIDS (CDC stage C2 or C3) as determined by CD4 count, physical exam by physician, and medical records review; - BDI ≥ 20 | Overall: 38 | Overall = 83% | Overall: 9 | 27.3%
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | SER = 71% | Headache: | ITT Analysis
US appears to be a university outpatient clinic (outpatients referred from Northwestern Memorial Hospital) | 6 wks | - Pregnant; - Concomitant psychotheraputic or psychotropic medications; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Actively suicidal; - Had been treated with other psychotropics in past mo; - Unable to sign informed consent | Overall: 18 | PAR = 86% | Overall: 21 | No- completer analysis
Funding: | Study design: | | Race (% white): | FLUO = 90% | Insomnia: | Quality rating:
Chicago Consortium for Psychiatric Research | Other: open-label medication trial | | Overall: 73 | Subjects who completed 6 wks of SSRI treatment experienced sig reductions in both affective and somatic symptoms (as measured by HAM-D, BDI, HAM-D affective, BDI cognitive subscale, HAM-D vegetative, and BDI somatic subscale scores among completers), many of the latter having been attributed to HIV rather than depression | Overall: 21 | Poor: open-label, no ITT
| Overall study N: | | Baseline (HAM-A): | Nine subjects dropped out early due to AEs | Nausea:
| 33 | | NR | | Overall: 15
| Intervention: | | Baseline HAM-D:
| D1: Sertraline: 50 mg/d to a maximum of 150 mg/d as tolerated | | Overall: 23.3 (4.8)
| D2: Paroxetine: 20 mg/d to a maximum of 40 mg/d
| D3: Fluoxetine: 20 mg/d to a maximum of 40 mg/d
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | HAM-D mean score (SD) and mean score change: | Cardiovascular adverse events: | Overall attrition rate:
Glassman et al., 2002 | To evaluate safety and efficacy of SER treatment of MDD in patients hospitalized for acute MI or unstable angina free of other life-threatening medical conditions | - Adults; - Diagnosed with MDD according to DSM-III or -IV; - Acute MI or hospitalization for unstable angina in past 30 days | D1: 56.8 | All randomized patients: | D1: 52.7 | 26.8%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 57.6 | SER = 19.6 (5.3) and-8.4 (0.41) | D2: 59.0 | ITT Analysis
multinational, conduceted in 40 outpatient cardiology centers and psychiatry clinics | 24 wks | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Sig suicide risk; - Women of childbearing potential not on adequate contraception; - Current use of antiarrythmic medications | Sex (% female): | Placebo = 19.6 (5.4) and -7.6 (0.41) | Diarrhea: | Yes
Funding: | Study design: | | D1: 37 | Any recurrent depression: | D1: 18.8 | Quality rating:
Pfizer | RCT | | D2: 36 | SER = 20.6 (5.1) and -9.8 (0.59) | D2: 7.7 | Fair
| Overall study N: | | Race (% white): | placebo = 20.8 (5.6) and -7.6 (0.61) | Dizziness:
| 369 | | D1: 74 | Patients with 2 prior episodes, plus HAM-D score ≥ 18: | D1: 15.6
| Intervention: | | D2: 79 | SER = 22.9 (3.6) and -12.3 (0.88) | D2: 12.0
| D1: Sertraline: 50–200 mg/d | | Baseline (HAM-A): | Placebo = 24.5 (4.4) and -8.9 (0.98) | Headache:
| D2: Placebo | | NR | # CGI responders | D1: 20.4
| | | Baseline HAM-D: | total sample: | D2: 16.4
| | | D1: 19.6 (5.3) | SER = 125 (67%) | Insomnia:
| | | D2: 19.6 (5.4) | Placebo = 97 (53%) (P = 0.01) | D1: 18.8
| | | | Any recurrent MDD: | D2: 18.8
| | | | SER = 69 (72%) | Nausea:
| | | | Placebo = 46 (51%) (P = 0.003) | D1: 19.9
| | | | Patients with more severe (2 prior episodes plus HAM-D score ≥ 18): | D2: 10.9
| | | | SER = 39 (78%) | Somnolence (fatigue):
| | | | Placebo = 18 (45%) (P = 0.001) | D1: 14.5
| | | | | D2: 13.7
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Mean change (SD) in body weight: | Cardiovascular adverse events: | Overall attrition rate:
Goldstein et al., 1997 | To assess effect of FLUO 20 mg/d on weight loss in older patients | - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 16; - Adults 60+ | D1: 68 | Low/normal BMI: | D1: 2.7 | NR
Country and setting: | Duration of study: | Exclusion criteria: | D2: 68 | FLUO -0.88 (2.11) | D2: 3.3 | ITT Analysis
United States | 6 wks | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder not related to depression; - Clinically sig medical disease; - Suicidal tendencies; - Score less than 25 on MMSE; - History of allergic reaction to FLUO; - History of nonresponse to at least 2 antidepressants at usual doses | Sex (% female): | Placebo 0.11 (1.96) (P < 0.001) | Changes in weight (decrease): | No another type of analysis was used (define): included patients with complete data only
multicenter, outpatient trial | (after a 1-wk placebo lead-in) | | D1: 55 | High BMI: | D1: 3.3 | Quality rating:
Funding: | Study design: | | D2: 55 | FLUO -1.14 (1.99) | D2: 1.2 | Fair for AE reporting
Lilly | RCT | | Race (% white): | Placebo 0.04 (1.72) (P < 0.001)
| Overall study N: | | D1: 94 | Pooled:
| 671 | | D2: 94 | FLUO -1.01 (2.05)
| Intervention: | | Baseline (HAM-A): | Placebo 0.08 (1.85) (P < 0.001)
| D1: Fluoxetine: 20 mg/d | | NR | % with weight loss of at least 5%
| D2: Placebo | | Baseline HAM-D: | low/normal BMI:
| | | NR | FLUO 2.4
| | | | Placebo 1.1 (P = 0.225)
| | | | High BMI:
| | | | FLUO 3.7
| | | | Placebo 0 (P = 0.021)
| | | | Pooled:
| | | | FLUO 3.1
| | | | Placebo 0.6 (P = 0.017)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Treatment response (≥ 50% improvement in MADRS score), % | Diarrhea: | Overall attrition rate:
Gual et al, 2003 | To evaluate efficacy and safety of SER at achieving stable maintenance, at amerliorating depressive symptoms, and at improving QOL in patients with alcohol dependence and current depressive symptoms | - Adults 18 to no upper limit; - Diagnosed with MDD according to DSM-III or -IV; - Alcohol dependence (according to DSM-IV and ICD10); - Dysthymia; - MDD according to DSM-IV and ICD-10; - Abstinent from alcohol for at least 2 wks following detoxification | D1: 47.3 | SER = 44% | D1: 7.7 | 61%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 46.1 | placebo = 39% | D2: 9.1 | ITT Analysis
Spain, single-center, hospital | 24 wks | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Investigational drug use within last 6 mos; - Suicidal tendencies; - ECT within 3 mos | Sex (% female): | No sig diff in SF-36 physical component score, mean (SD) | Dizziness: | Yes
Funding: | Study design: | | D1: 46.1 | SER = 48.6 (9.6); change from baseline ~ 2.5 points | D1: 12.8 | Quality rating:
Pfizer | RCT | | D2: 47.7 | Placebo = 47.0 (11.0); change from baseline ~ 4 points | D2: 11.4 | Fair:
| Overall study N: | | Race (% white): | | Headache:
| 83 | | NR | | D1: 28.2
| Intervention: | | Baseline (HAM-A): | | D2: 27.3
| D1: Placebo | | NR | | Nausea:
| D2: Sertraline: 50–150 mg/d | | Baseline HAM-D: | | D1: 7.7
| | | D1: 12.8 (4.0) | | D2: 9.1
| | | D2: 13.9 (5.6)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | On 21-item HAM-D, diffs between MIR and placebo were statistically sig at 2, 3, 4, and 6 wks. Using MADRS, statistically sig diffs were found between both active compounds and placebo at wks 2 and 3. MIR and TRA were associated with sig higher frequencies of dizziness and blurred vision as compared to placebo | Cardiovascular adverse events: | Overall attrition rate:
Halikas, 1995 | To assess clinical efficacy and safety of “Org 3770” (MIR) and TRA in treatment of elderly outpatients with moderate to severe depression | - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18; - Age 55+; - Able to complete Zung Self Rating Depression Scale (SDS); - Chloral hydrate (500 mg) at bedtime was permitted | D1: 63 | At wk 6, 51% of MIR and 41% of TRA treated patients were HAM-D responders (not statistically sig) | D1: 2% Tachycardia; 4% Palpitations | 27%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 61 | | D2: 12% Tachycardia; 12% Palpitations | ITT analysis:
United States | 6 wks | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - ECT within last 3 mos of baseline; - Suicidal tendencies; - Rapid placebo responders (reduction of 20%+ in total HAM-D score) | D3: 62 | | D3: 2% Tachycardia; 2% Palpitations | Yes
University | Study design: | | Sex (% female): | | Constipation: | Quality rating:
Funding: | RCT | | D1: 42.9 | | D1: 18 | Fair
Organon, Inc | Overall study N: | | D2: 60.4 | | D2: 24
| 150 | | D3: 59.2 | | D3: 16
| Intervention: | | Race (% white): | | Dizziness:
| D1: Mirtazapine: 5–35 mg | | NR | | D1: 22
| D2: Trazodone: 40–280 mg | | Baseline (HAM-A): | | D2: 27
| D3: placebo | | NR | | D3: 8
| | | Mean HAM-D score at baseline: | | Headache:
| | | D1: 24.6 | | D1: 14
| | | D2: 24.6 | | D2: 20
| | | D3: 23.5 | | D3: 20
| | | | | Nausea:
| | | | | D1: 10
| | | | | D2: 14
| | | | | D3: 14
| | | | | Somnolence (fatigue):
| | | | | D1: 54
| | | | | D2: 55
| | | | | D3: 22
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | NEF group showed greater reductions in depression, effects did not reach statistical significance | NR | Overall attrition rate:
Hernandez-Avila et al., 2003 | To compare NEF or placebo in a sample of alcohol dependant subjects with current major depression | - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 17; - Alcoholism; - Age 21 to 65; - Spoke English | D1: 43.1 | (P = 0.82); however, NEF subjects showed sig greater reduction in heavy drinking days (P = 0.01) | | 31.7
Country and setting: | Duration of study: | Exclusion criteria: | D2: 42.7 | | | ITT Analysis
United States | 12 wks | - Pregnant; - Concomitant psychotheraputic or psychotropic medications; - Suicidal tendencies; - Drug dependance other than alcohol; - Major mental illness other than depression or anxiety | Sex (% female): | | | Yes
Outpatient | Study design: | | D1: 52.4 | | | Quality rating:
Funding: | RCT | | D2: 50.0 | | | Fair
Bristol-Meyers Squibb | Overall study N: | | Race (% white):
NIH Grants | 41 | | NR
| Intervention: | | Baseline (HAM-A):
| D1: Nefazodone: 200–600 mg/d (412.9) | | NR
| D2: Placebo | | Baseline HAM-D:
| | | D1: 16.33 (2.31)
| | | D2: 17.35 (1.98)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | “Responders” (≥ 50% decrease from baseline in MADRS total score) = 46% ESC group, 47% placebo group, 37% FLUO group (all NS) | Overall adverse events: | Overall attrition rate:
Kasper et al., 2005 | To compare efficacy and tolerability of ESC in a fixed dose of 10 mg with placebo in elderly patients with major depressive disorder, using FLUO at fixed dose of 20 mg as a reference drug | - Diagnosed with MDD according to DSM-III or -IV; - Age 65+; - MADRS total score of 22–40 at screening and baseline; - MMSE 22+ at screening | D1: 75 | “Remitters” (MADRS total score < = 12): 40% ESC group, 42% placebo group, 30% FLUO group. Diff between placebo and ESC groups NS, but fewer remitters in FLUO vs. placebo groups (P < 0.05) | D1: 2.8 D2: 9.8 | 17.6%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 75 | ESC-treated patients experienced greater improvement than FLUO-treated patients in MADRS score at wk 8 (last observation carried forward) (P < 0.01); however, there was no sig diff between ESC- and placebo-treated patients | D3: 12.2 | ITT Analysis
Multinational (11 countries) | 8 wks | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Investigational drug use within last 30 days; - Current ECT; - MADRS score ≥ 5 on Item 10 (suicidal thoughts); - History of severe drug allergy or hypersensitivity; - Lack of response to more than one antidepressant treatment (including CIT) during present depressive episode | D3: 75 | | Changes in weight (decrease): | Yes
Multicenter (76 general practice and specialist settings) | Study design: | | Sex (% female): | | D1: 1.1 D2: 1.2 | Quality rating:
Funding: | RCT | | D1: 76 | | D3: 2.4 | Good
Eli Lilly, Lundbeck, Bristol-Myers Squibb, GlaxoSmith-Kline, Organon, Servier | Overall study N: | | D2: 75 | | Constipation:
| 517 | | D3: 77 | | D1: 4.4 D2: 1.2
| Intervention: | | Race (% white): | | D3: 4.3
| D1: Placebo | | D1: 100 | | Diarrhea:
| D2: Escitalopram: 10 mg | | D2: 99 | | D1: 5.0 D2: 1.7
| D3: Fluoxetine: 20 mg | | D3: 100 | | D3: 4.9
| | | Baseline (HAM-A): | | Dizziness:
| | | NR | | D1: 0.6 D2: 2.9
| | | Baseline HAM-D: | | D3: 3.7
| | | NR | | Headache:
| | | | | D1: 8.3 D2: 5.2
| | | | | D3: 4.3
| | | | | Insomnia:
| | | | | D1: 2.2 D2: 2.3
| | | | | D3: 1.8
| | | | | Nausea:
| | | | | D1: 1.7 D2: 6.9
| | | | | D3: 7.3
| | | | | Somnolence (fatigue):
| | | | | D1: 0.6 D2: 2.3
| | | | | D3: 0
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Men reported sig greater drug-induced impairment of drive/desire compared with women (mean [SD] = 2.26 (2.02) vs. 1.43(2.12), t = 6.23, df = 107, P < 0.05) | NR | Overall attrition rate:
Kennedy et al., 2000 | To evaluate disturbances in sexual drive/desire and arousal/orgasm in depressed patients who completed 8 wks of study | - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 16; - Sexual activity within past mo; - Major depression with or without other secondary non-psychotic axis I disorders; - No antidepressants within 2 wks (or 5 wks for FLUO) | NR | No signficant diffs between antidepressants among men reporting antidepressant-induced sexual dysfunction | | 38.5%
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | On arousal/orgasm scale women showed lower rates of dysfunction on VEN compared to PAR and ser, however, only one item of 3 arousal/orgasm items (“difficulty achieving orgasm”) reached statistical significance (chi-sq = 8.51, df = 1, P < 0.004). for VEN vs. PAR, VEN introduced sig less difficulty with having an orgasm than PAR (chi-sq = 2.98, df = 1, P < 0.08) | | ITT Analysis
Canada | 14 wks (primary endpoint is 8 wks) | - Clinically sig medical disease | D1: 84.6 | | | N/A
Depression clinic | Study design: | | D2: 33.3 | | | Quality rating:
Funding: | Prospective cohort study | | D3: 61.1 | | | Fair
Centre for Addiction and Mental Health Foundation | Overall study N: | | Race (% white):
| 174 | | NR
| Intervention: | | Baseline (HAM-A):
| D1: Sertraline: 50–200 mg/d | | NR
| D2: Paroxetine: 10–80 mg/d | | Baseline HAM-D:
| D3: Venlafaxine: 37.5–375 mg/d | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | SSRIs/VEN were sig associated with hyponatremia after controlling for confounding factors (OR 3.5, 95% CI 1.4–8.9) | NR | Overall attrition rate:
Kirby et al.; 2002 | To determine prevalence of hyponatremia associated with SSRI use vs. VEN in elderly compared to elderly not on these drugs | - Inpatient in North-West Hospital psychogeriatric unit between 1997 and 1998 | Overall: 74.2 | OR adjusted for thiazide use: 2.5 (95% CI 1.1 – 5.4) | | N/A
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | VEN had a higher rate of hyponatremia than other drugs (71.4%; PAR: 32.0%; FLUO: 60.0%; SER: 28.6%) | | ITT Analysis
Australia; inpatient | 1 yr. (inpatients treated between 1997 to 1998) | - Patients with no sodium test during admission | Overall: 65 | | | Not applicable-observational study
Funding: | Study design: | | Race (% white): | | | Quality rating:
Not reported | Observational | | Overall: NR | | | Fair
| Overall study N: | | Baseline (HAM-A):
| 199 | | NR
| Intervention: | | Baseline HAM-D:
| Fluoxetine
| Fluvoxamine
| Paroxetine
| Sertraline
| Venlafaxine
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | SER found to be safe, well-tolerated, and effective as an antidepressant in elderly patients suffering from hypertension and other forms of vascular comorbidity | Constipation: | Overall attrition rate:
Krishnan et al., 2001 | To evaluate safety and efficacy of SER in treatment of moderate-to-severe major depression in elderly outpatients with comorbid vascular disease | - Adults 60 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18; - Minimal improvement at most on CGI-I | D1: 68.6 | Both completer analysis and more conservative endpoint (LOCF) analysis found similar numbers of patients achieving “responder” status by end of study treatment (responder status defined as 50% or greater reduction from baseline in HAM-D total score); SER treatment yielded comparable levels of response in all 3 groups at treatment endpoint on both completer analysis (HTN, 86%, VASC, 89%, NoVASC, 58%; P < 0.05) | D1: 18 | NR
Newhouse et al. 2000 | Duration of study: | Exclusion criteria: | D2: 68.9 | | D2: 13 | ITT Analysis
Country and setting: | 12 wks | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - ECT within last 3 mos; - Suicidal tendencies; - MMSE < 23; - Current diagnosis of dysthmia; - Previous history of non-response to 6-wks adequate doses of 2 or more antidepressants | D3: 67.3 | | D3: 6 | Yes
US | Study design: | | Sex (% female): | | Diarrhea: | Quality rating:
Funding: | RCT | | D1: 69 | | D1: 21 | Fair
Pfizer, Inc | Overall study N: | | D2: 44 | | D2: 19
| 220 | | D3: 62 | | D3: 22
| Intervention: | | Race (% white): | | Headache:
| Fluoxetine: 50–100 mg/d | | NR | | D1: 44
| Sertraline: 50–150 mg/d | | Baseline (HAM-A): | | D2: 28
| Other: nortriptyline | | D1: 14.4 | | D3: 25
| D1: HTN | | D2: 14.4 | | Insomnia:
| D2: VASC | | D3: 15.2 | | D1: 18
| D3: NoVasc | | Baseline HAM-D: | | D2: 19
| | | NR | | D3: 20
| | | | | Nausea:
| | | | | D1: 19
| | | | | D2: 9
| | | | | D3: 20
| | | | | Somnolence (fatigue):
| | | | | D1: 12
| | | | | D2: 16
| | | | | D3: 7
| | | | | Sweating (increase):
| | | | | D1: 17
| | | | | D2: 6
| | | | | D3: 8
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | All 3 treatment groups showed sig improvements in depression and other health related QOL domains (social function, work function, physical function) | NR | Overall attrition rate:
Kroenke et al., 2001 | To compare efficacy of PAR, FLUO, and SER in depressed primary care patients | - Adults 18 and up; - Depressive disorder as determined by PCP; - Home telephone | D1: 47.2 | No sig diffs between treatment groups in any of 3 and 9 mos outcome measures | | 24.3%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 47.1 | Subgroup analysis showed no diffs in treatment effects for patients with MDD and for patients older than 60 yrs | | ITT Analysis
US | 9 mos | - Pregnant; - Lactating; - Concomitant psychotheraputic or psychotropic medications; - Clinically sig medical disease; - Suicidal tendencies | D3: 44.1 | Switch rate to other medication: | | Yes
Primary care (76 physicians) | Study design: | | Sex (% female): | PAR: 22% | | Quality rating:
Funding: | Open-label, randomized trial | | D1: 76 | FLUO: 14% | | Fair
Eli Lilly | Overall study N: | | D2: 86 | SER: 17%
| 573 | | D3: 75
| Intervention: | | Race (% white):
| D1: Paroxetine: 20 mg/d | | D1: 85
| D2: Fluoxetine: 20 mg/d | | D2: 88
| D3: Sertraline: 50 mg/d | | D3: 79
| | | Baseline (HAM-A):
| | | NR
| | | Baseline HAM-D:
| | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | 9 SER patients (38%) were full responders and 11 (46%) were partial responders compared with 3 (20%) and 4 (15%) placebo patients (P = 0.007) | NR | Overall attrition rate:
Lyketsos et al, 2003 | To assess efficacy and safety of SER for treatment of major depression in Alzheimer disease and to evaluate effect of depression reduction on activities of daily living, cognition, and nonmood behavioral disturbance | - Diagnosed with MDD according to DSM-III or -IV; - Probable alzheimer disease by National Institute of Neurological and Communicative Disorders and Stroke-Alzheimer's disease and Related Disorders Association; - MMSE of 10; - Current residence in a community setting (home or assisted living) | D1: 79.9 | SER was statistically sig superior to placebo as measured by both Cornell Scale for Depression in Dementia (P = 0.002) and Hamilton Depression Rating Scale (P = 0.01) | | 18.2%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 75.5 | | | ITT Analysis
US, 3 psychiatric outpatient clinics | 12 wks (after a one-wk single-blind placebo phase) | - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies; - Use of SER contraindicated in opinion of study psychiatrist | Sex (% female): | | | Yes
Funding: | Study design: | | D1: 50 | | | Quality rating:
Depression in Alzheimer's disease study from NIMH | RCT | | D2: 83 | | | Fair
| Overall study N: | | Race (% white):
| 44 | | NR
| Intervention: | | Baseline (HAM-A):
| D1: Placebo | | NR
| D2: Sertraline: up to 150 mg/d | | Baseline HAM-D:
| | | D1: 21.8 (5.4)
| | | D2: 23.7 (6.4)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | On all measures, both treatment and placebo groups improved over time, with 3 of 6 measures showing a sig time effect. “Knit-brow” facial feature approached significance for a treatment by time effect. In sum, SER had no sig benefits over placebo | Overall adverse events: | Overall attrition rate:
Magai et al., 2000 | To evaluate efficacy of SER in treatment of depressive symptoms and signs in late-stage dementia patients | - Diagnosed with MDD according to DSM-III or -IV; - Concomitant condition: dementia; - Minor depression | D1: 88.4 | | D1: 11.8 | 12.9%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 90.1 | | D2: 14.3 | ITT Analysis
US, nursing homes | 8 wks | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Clinically sig medical disease | Sex (% female): | | | Yes
Funding: | Study design: | | D1: 100 | | | Quality rating:
Pfizer Pharmaceuticals New York State Dept. of Health Dementia Grants Program; Minority Biomedical Research Support Program and National Institute on Aging | RCT | | D2: 100 | | | Fair
| Overall study N: | | Race (% white):
| 31 | | D1: 94
| Intervention: | | D2: 71
| D1: Sertraline: 25–100mg | | Baseline (HAM-A):
| D2: Placebo | | NR
| | | Baseline HAM-D:
| | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Subjects who received SER had fewer drinks per drinking day than subjects who received placebo, but other drinking outcomes were not different between 2 treatment groups. In female subjects, treatment with SER was associated with less depression at end of treatment compared with placebo. Less drinking during study was associated with improved depression outcomes | NR | Overall attrition rate:
Moak et al., 2003 | Comparison of SER and placebo in conjunction with CBT in treatment of depressed alcoholics | - Adults; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 17; - Alcoholism (alcohol dependence or abuse); - Dysthymia; - Primary major depression episode of dysthymic disorder or a clear family hisory of affective disorder without comorbid substance abuse in a first degree relative | D1: 41 | | | 28%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 42 | | | ITT Analysis
USA | 12 wks | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Current suicidal ideation or plan; - Treatment resistant depression | Sex (% female): | | | Yes
Single center | Study design: | | D1: 39 | | | Quality rating:
Funding: | RCT | | D2: 39 | | | Fair
National Institute on Alcohol Abuse and Alcoholism | Overall study N: | | Race (% white):
| 82 | | NR
| Intervention: | | Baseline (HAM-A):
| D1: Sertraline: 50–200 mg/d | | NR
| D2: Placebo | | Baseline HAM-D:
| | | D1: 19.4 (2.6)
| | | D2: 18.8 (2.4)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | HAM-D responders (percent of those who completed 26 wks of treatment) | Changes in weight (decrease): | Overall attrition rate:
Murray et al., 2005 | To evaluate efficacy and safety of SER in post-stroke depression | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Stroke (according to WHO criteria), hospitalized during acute phase of index stroke; - Minor depression according to DSM-IV and MADRS ≥ 10 and time criteria (symptoms should have been present during same 2 wk period) | D1: 70.7 | SER = 76% | D1: 17.4 | 44%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 70.7 | placebo = 78% | D2: 13.3 | ITT Analysis
Sweden, outpatients (4 stroke centers) | 26 wks | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Sig risk of suicide; - Severe impairment of ability to communicate; - Current use of opiate analgesics | Sex (% female): | % remission (defined as a MADRS score < 10) (percent of those who completed 26 wks of treatment) | Changes in weight (increase): | Yes
Funding: | Study design: | | D1: 48.4% | SER = 81% | D1: 15.2 | Quality rating:
Pfizer AB Sweden | RCT | | D2: 55.7% | placebo = 87% | D2: 15.6 | Fair
| Overall study N: | | Race (% white): | Improvement in QOL at wk 26 was sig better in SER treated patients (P < 0.05) | Constipation:
| 123 | | NR | | D1: 14.5
| Intervention: | | Baseline (HAM-A): | | D2: 9.3
| D1: Sertraline: 50–100 mg/d | | NR | | Diarrhea:
| D2: Placebo | | Baseline HAM-D: | | D1: 23.6
| | | NR | | D2: 9.3
| | | | | Dizziness:
| | | | | D1: 14.5
| | | | | D2: 13.0
| | | | | Headache:
| | | | | D1: 14.5
| | | | | D2: 16.7
| | | | | Nausea:
| | | | | D1: 21.8
| | | | | D2: 14.8
| | | | | Sweating (increase):
| | | | | D1: 16.4
| | | | | D2: 17.0
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | HAM-D Responders: | Diarrhea: | Overall attrition rate:
Newhouse et al., 2000 and Finkel et al., 1999 | Examined efficacy and safety of FLUO and SER in depressed elderly outpatients | - Adults 60 yrs or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18 | D1: 68 | SER: 73% | D1: 22.4 | 32.2%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 67 | FLUO: 71% | D2: 16.1 | ITT Analysis
USA | 12 wks | - Additional mental illnesses or organic mental; - Clinically sig medical disease; - Failure to respond to ECT | Sex (% female): | P = NS | Dizziness: | Yes
Multicenter | Study design: | | D1: 63.2 | HAM-D remitters: | D1: 7.8 | Quality rating:
Funding: | RCT | | D2: 51.3 | SER: 45% | D2: 10.2 | Fair
Pfizer, Inc | Overall study N: | | Race (% white): | FLUO: 46% | Headache:
| 236 | | D1: 95.7 | P = NS | D1: 33.6
| Intervention: | | D2: 100 | Q-LES-Q and other patient-rated secondary efficacy measures were similar for both treatment groups at endpoint | D2: 31.4
| D1: Sertraline: 50–100 mg/d | | Baseline (HAM-A): | SER-treated patients showed a greater cognitive improvement than patients on FLUO on Digit Symbol Substitution Test at endpoint (P = 0.037) | Insomnia:
| D2: Fluoxetine: 20–40 mg/d | | NR | Patients 70 yrs of age and older, HAM-D responders at endpoint in SER group (P = 0.027): | D1: 13.7
| | | Baseline HAM-D: | 58.5% (SER) vs. 42.4% (FLUO) | D2: 14.4
| | | D1: 25.1 (4.2) | | Nausea:
| | | D2: 25.0 (4.7) | | D1: 14.7
| | | Subgroup analysis: | | D2: 18.6
| | | Mean age (yrs): | | Subgroup analysis:
| | | D1: 74 | | Overall adverse events:
| | | D2: 75 | | D1: 93
| | | Sex (% female): | | D2: 94
| | | D1: 57 | | Headache:
| | | D2: 49 | | D1: 23.8
| | | Race (% white): | | D2: 33.3
| | | D1: 95 | | Nausea:
| | | D2: 100 | | D1: 16.7
| | | Baseline (HAM-A): | | D2: 15.2
| | | NR
| | | Baseline HAM-D:
| | | D1: 24.2
| | | D2: 25.4
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Rate of response as measured by HAM-D was similar in CIT and placebo groups (no data given) | Overall adverse events: | Overall attrition rate:
Nyth et al., 1992 | To assess efficacy and safety of CIT vs. placebo in depressed elderly patients who might also suffer from somatic disorders and/or senile dementia | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 14; - Mild to moderate dementia and somatic disorders acceptable but not required for inclusion | D1: F: 77.0, M: 74.4 | GBS dementia rating scale indicated that intellectual function-time orientation, recent memory, and ability to increase tempo and symptoms common to dementia-anxiety, fear-panic, depressed mood all improved sig more in CIT-treated subgroup of patients with dementia than in placebo-treated subgroup (P < 0.05) | D1: 37 | 36.9%
Country and setting: | Duration of study: | Exclusion criteria: | D2: F: 77.7; M: 77.8 | | D2: 25 | ITT Analysis
Denmark, Norway, Sweden | 6 wks | - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies; - Receipt of anti-cancer treatment; recent treatment with monoamine oxidase inhibitors; GBS geriatric rating scale with score >4 | Sex (% female): | | Changes in weight (decrease): | Efficacy analysis; ITT done and ITT
Multicenter (7) | Study design: | | D1: 67 | | D1: 9.2 | Quality rating:
Funding: | RCT | | D2: 73 | | D2: 3.9 | Poor
NR | Overall study N: | | Race (% white): | | Constipation: | Completer analysis only
| 149 | | NR | | D1: 3.1
| Intervention: | | Baseline (HAM-A): | | D2: 5.9
| D1: Citalopram: 10–30 mg | | NR | | Dizziness:
| D2: Placebo | | Baseline HAM-D: | | D1: 7.1
| | | D1: 22.1 (6.2) | | D2: 0
| | | D2: 21.1 (5.8) | | Nausea:
| | | | | D1: 5.1
| | | | | D2: 7.8
| | | | | Somnolence (fatigue):
| | | | | D1: 18.4
| | | | | D2: 5.9
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Mean change from baseline to endpoint: HAM-D (F 3.45, P 0.069) = 8.0 (SER) vs. 4.6 (VEN); GDS (F 2.13, P 0.151) = 3.5 (ser) vs. 0.8 (ven); Cornell (F 7.65, P 0.008) = 8.5 (ser) vs. 4.0 (ven). Endpoint CGI = 2.3 (ser) vs. 3.0 (ven) with F = 2.83 and P = 0.98. | NR | Overall attrition rate:
Oslin et al., 2003 | To examine efficacy and tolerability of VEN and SER among nursing home residents | - Age 60 or more; - Diagnosed with MDD according to DSM-III or -IV; - HAM-D ≤ 12; - Sig dysphoria with score ≥ 10 on GDS and/or rating >2 on depressed mood item of HAM-D; - Minor depression, dementia with depression, or dysthymia; - Blessed Memory Information Concentration test score < 21 | D1: 83.8 | Tolerability lower for VEN | | 38.5%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 81.2 | | | ITT Analysis
US | 10 wks | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Investigational drug use within last 2 wks; - Suicidal tendencies | Overall: 82.5 | | | Yes
VA nursing facilities (13) | Study design: | | Sex (% female): | | | Quality rating:
Funding: | RCT | | D1: 56 | | | Poor
National Institute of Mental Health; Department of Veterans Affairs | Overall study N: | | D2: 33
| 52 | | Overall: 44.2
| Intervention: | | Race (% white):
| D1: Sertraline: 25–100 mg/d | | D1: 92
| D2: Venlafaxine: 18.75–150 mg/d | | D2: 63
| | | Overall: 76.9
| | | Baseline (HAM-A):
| | | NR
| | | Baseline HAM-D:
| | | D1: 20.2 (3.4)
| | | D2: 20.3 (3.7)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | In entire sample, BDI and HAM-D scores decreased sig in both groups (z = 2.37; P = 0.01; z = 5.85, P < 0.01); no sig diffs between placebo and FLUO treated patients. Among subjects with major depression (n = 31), there were no sig diffs in rate of change of depressive symptoms by treatment group over time | NR | Overall attrition rate:
Petrakis et al., 1998 | To evaluate efficacy of FLUO in treating depression in methadone-maintained opioid addicts | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 14; - Methadone-maintained opioid addiction; - > 8 on BDI; medically healthy | D1: 35.4 | Concomitant heroin use and ASI scores decreased sig for both groups (z = 2.92, P < 0.01; z = 2.66, P < 0.01); no sig diff between groups | | 15.9%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 33.3 | | | ITT Analysis
US | 3 mos | - Additional mental illnesses or organic mental disorder | Sex (% female): | | | No
Teaching hospital | Study design: | | D1: 39.1 | | | Quality rating:
Funding: | RCT | | D2: 33.3 | | | Fair
National Institute on Drug Abuse | Overall study N: | | Race (% white):
| 44 | | D1: 91.3
| Intervention: | | D2: 85.7
| D1: Fluoxetine: 20–60 mg/d | | Baseline (HAM-A):
| D2: Placebo | | NR
| | | Baseline HAM-D:
| | | D1: 14 (4.9)
| | | D2: 14.9 (5.8)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No statistically different outcomes between treatment groups. HAM-D response (52% [fluox] vs. 51% [placebo] [P = 0.66]) and remission (50% [fluox] vs. 51% [placebo] [P = 0.59]) rates | Changes in weight (decrease): | Overall attrition rate:
Rabkin et al., 2004 | To determine whether testosterone and FLUO is superior to placebo for depression, fatigue, or both | - Adults 18 or older; - Diagnosed with MDD according to DSM-III or -IV; - HIV seropositive; - Dysthymia; - Male; - Negative PSA; - Agreement of primary healthcare provider | D1: 40 | | D1: 9 | 26.8%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 41 | | Diarrhea: | ITT Analysis
US | 8 wks | - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Investigational drug use within last 5 wks; - ECT; - Suicidal tendencies; - Psychotherapy started in last mo; - Use of anabolic steroids; - Current/anticipated change in ARV regimen within 4 wks; - Unprotected intercourse with partners of unknown or negative HIV status | Sex (% female): | | D1: 4 | Yes
Outpatient | Study design: | | D1: 0 | | Headache: | Quality rating:
Funding: | RCT | | D2: 0 | | D1: 9 | Fair
Lilly (provided tablets); Pharmacia and Upjohn (provided coded vials) | Overall study N: | | Race (% white): | | Insomnia:
National Institute of Mental Health | 123 | | D1: 21.7 | | D1: 4
| Intervention: | | D2: 23.1 | | Nausea:
| D1: Fluoxetine: 20–60 mg/d | | Baseline (HAM-A): | | D1: 7
| D2: Placebo Testosterone 200–400 mg biwkly | | NR | | Sexual dysfunctional (male ejaculation):
| | | Baseline HAM-D: | | D1: 6
| | | D1: 18.2 (4.5) | | Somnolence (fatigue):
| | | D2: 16.8 (3.3) | | D1: 7
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | PAR CR and IR were more effective than placebo, with mean +/- SD endpoint HAM-D total scores of 10.0 +/- 7.41 (P = 0.007) and 10.0 +/- 7.10 (P= 0.003), respectively, compared with 12.6 +/- 7.34 for placebo. Response (a score of 1 or 2 on CGI-I scale) was achieved by 72% of PAR CR patients (P < 0.002 vs. placebo), 65% of PAR IR patients (P = 0.06 vs. placebo), and 52% of placebo patients. Remission, defined as HAM-D total score ≤ 7, was achieved by 43% of PAR CR patients (P = 0.009 vs. placebo), 44% of PAR IR patients (P= 0.01 vs. placebo), and 26% of placebo patients | Insomnia: | Overall attrition rate:
Rapaport et al., 2003 | Efficacy and safety of PAR CR and IR versus placebo in late life depression | - Adults > 59 yrs; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18 | D1: 70.4 | | D1: 9.6 | 24.4%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 70.1 | | D2: 14.2 | ITT Analysis
US and Canada | 12 wks | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - ECT within last 3 mos; - Suicidal tendencies; - History of brief depressive episodes with spontaneous remission; - Neuological disorders contributing to secondary depression; - Dementia; - MMSE ≤ 24 | D3: 69.4 | | D3: 8.3 | Yes
Multicenter (31) | Study design: | | Sex (% female): | | | Quality rating:
Funding: | RCT | | D1: 48.1 | | | Fair
GlaxoSmithKline | Overall study N: | | D2: 56.6
| 310 | | D3: 63.3
| Intervention: | | Race (% white):
| D1: Paroxetine CR 12.5–50 | | D1: 96.2
| D2: Paroxetine IR 10–40 mg/d | | D2: 95.3
| D3: Placebo | | D3: 94.5
| | | Baseline (HAM-A):
| | | NR
| | | Baseline HAM-D:
| | | D1: 22.1 (3.45)
| | | D2: 22.3 (3.15)
| | | D3: 22.1 (3.0)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Both treatments induced a sig, sustained, comparable improvement in depressive symptoms and in social functioning | Dizziness: | Overall attrition rate:
Rocca et al., 2005 | To compare effect of SER and CIT on depression symptoms and cognitive functions in nondemented elderly patients with minor depressive disorder or sybsyndromal depressive symptomatology | - Minimum HAM-D score of 10; - Nondemented elderly (65 or older); - Minor depressive disorder or subsyndromal depressive disorder according to SCID | D1: 72.4 | Change from baseline to endpoint on HAM-D CIT and SER groups decrease 55% vs. 52.7%; (P = NR) or GDS | D1: 15.2 | 27.5
Country and setting: | Duration of study: | Exclusion criteria: | D2: 71.9 | Remission observed at any timepoint between treatment groups | D2: 9.7 | ITT Analysis:
Italy | 12 mos | - Concomitant psychotheraputic or psychotropic medications; - Clinically sig medical disease; - Any other current Axis I or II psychiatric disorder; - Impairment and decline of global cognitive functions on MMSE; - Score of at least 12 on Alzheimer's Disease Assessment Scale-Cognitive Subscale | Sex (% female): | 12 mos: 53% vs. 42%; P = 0.25 | Headache: | Yes
University clinic | Study design: | | D1: 24.2 | Sig within-group improvements seen in all cognitive measures for both SER and CIT WMS, TMT-A, TMT-B, VF, and MMSE) | D1: 10.1 | Quality rating:
Funding: | Nonrandomized controlled trial | | D2: 31.9 | | D2: 9.7 | N/A
University of Turin, Italy | Overall study N: | | Race (% white): | | Nausea:
| 138 | | NR | | D1: 24.2
| Intervention: | | Baseline (HAM-A): | | D2: 18.1
| D1: Citalopram: 20 mg/d | | NR
| D2: Sertraline: 50 mg/d | | Mean HAM-D score at baseline:
| | | D1: 12.9
| | | D2: 12.9
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Number of responders (reduction of ≥ 50% in HAM-D score) | Constipation: | Overall attrition rate:
Roose et al., 2004 | To evaluate efficacy of CIT for treatment of depression in “old-old” | - Age 75 or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 20 (HAM-D 24) | D1: 79.8 | CIT = 34 | D1: 11.5 | 16.7%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 79.3 | placebo = 34 | D2: 4.4 | ITT Analysis
US, multicenter | 8 wks (after a single-blind placebo lead-in) | - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Current suicide intent or serious suicide attempt within past yr; - Probable Alzheimer's disease or probable vascular dementia; - MMSE score ≤ 18; - Parkinson's disease; - Failure to respond to either a trial of an SSRI for at least 4 wks, or trials of 2 or more different classes of antidepressants other than SSRIs | Sex (% female): | f = 0.97 (P = 0.32) | Diarrhea: | Yes
Funding: | Study design: | | D1: 53.6 | Number of remitters (HAM-D ≤ 10) | D1: 14.9 | Quality rating:
Forest Laboratories | RCT | | D2: 62.2 | CIT = 29 | D2: 6.7 | Fair
| Overall study N: | | Race (% white): | placebo = 30 | Dizziness:
| 184 | | NR | f = 0.29 (P = 0.59) | D1: 9.2
| Intervention: | | Baseline (HAM-A): | CGI improvement of 1 or 2 | D2: 7.8
| D1: Citalopram: 10–40 mg/d | | NR | CIT = 37 | Headache:
| D2: Placebo | | Baseline HAM-D: | placebo = 39 | D1: 11.5
| | | D1: 24.4 (4.3) | f = 1.53 (P = 0.22) | D2: 4.4
| | | D2: 24.2 (3.9) | Higher rate of response, CIT vs. placebo, in high severity group: chi-square = 4.03, df = 1 (P = 0.04) | Insomnia:
| | | | Patients with onset of major depression before 60 yrs of age had poorer outcome when treated with placebo than any other 3 subgroups (P < 0.05) | D1: 3.4
| | | | | D2: 5.6
| | | | | Nausea:
| | | | | D1: 6.9
| | | | | D2: 6.7
| | | | | Somnolence (fatigue):
| | | | | D1: 5.7
| | | | | D2: 4.4
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Controlling for cycle 1, PAR was more effective in reducing depression during chemotherapy as measured by CESD (P = 0.006) [mean (SD) at cycle 4 for PAR and placebo: 8.8 (1.11) vs. 12.6 (1.24)] | NR | Overall attrition rate:
Roscoe et al., 2005 | To evaluate effect of PAR on fatigue and depression in breast cancer patients receiving chemotherapy | - Breast cancer; - Beginning or currently receiving treatment for breast cancer; - Females | D1: 52.2 | No sig diff between PAR and placebo on all 4 fatigue scales MAF question 1, Fatigue/Inertia Scale, Fatigue Symptom Checklist, and Interference with Daily Activities Sub-Scale from MAF (Interference)]; mean at cycle 4: MAF 4.6 vs. 5.0; Fatigue/Inertia Scale 6.0 vs. 7.1, Fatigue Symptom Checklist 44.6 vs. 48.0, Interference 3.1 vs. 3.8) (all Ps >0.27) | | 23%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 52.2 | | | ITT Analysis
US | Undefined (visits conducted 7 days after each of 4 on-study treatments) | - Concurrent radiation, interferon, history of seizures or mania, treatment cycles less than 2 wks apart, radiation okay if occurs between chemo cycles (it was regarded as a treatment cycle); - Concomitant psychotherapeutic or psychotropic medications | Sex (% female): | | | No
University medical center | PAR: 20 mg/d | | D1: 100 | | | Quality rating:
Funding: | placebo | | D2: 100 | | | Poor: Appears to be completer analysis only, study length is not defined
SmithKline Beecham (supplied medication), Department of Defense | Study design: | | Race (% white):
| RCT | | D1: 93
| Overall study N: | | D2: 86
| 122 | | Baseline (HAM-A):
| Intervention: | | NR
| D1: Paroxetine | | Baseline HAM-D:
| D2: Placebo | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig diff in final response rates was found between 2 treatment groups, 55.6% (25/45) and 71.8% (28/39) for SER and FLUV, respectively (P = 0.12). A repeated-measures analysis of variance on Hamilton Rating Scale for Depression scores revealed a sig different decrease of depressive symptoms between 2 treatment groups, favoring FLUV (P = 0.007) | NR | Overall attrition rate:
Rossini et al., 2005 | To compare efficacy and tolerability of FLUV and SER in elderly patients | - Age 59 or more; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 21; - MDD diagnosed by MD using unstructured interviews and medical records according to DSM-IV, and after best estimate procedure | D1: 67.80 | | | 4.5%
Study has 13–20% bipolars | Duration of study: | Exclusion criteria: | D2: 68.24 | | | ITT Analysis
Country and setting: | 7 wks (after a 7-day single-blind placebo washout) | - Additional mental illnesses or organic mental disorder; - MMSE score <23; - Nonreversible MAOI or slow release neuroleptics within 1 mo of study; - Bipolar patients had to be on mood stabilizers; - Depression or bipolar disorder due to a medical condition or induced by a substance; - No psychotic features | Sex (% female): | | | Yes
Italy | Study design: | | D1: 61.5 | | | Quality rating:
One inpatient center | RCT | | D2: 82.2 | | | Fair
Funding: | Overall study N: | | Race (% white):
Not reported | 93 | | NR
| Intervention: | | Baseline (HAM-A):
| D1: Fluvoxamine: 200 mg/d (100mg twice daily) | | NR
| D2: Sertraline: 150 mg/d (75mg twice daily) | | Baseline HAM-D:
| | | D1: 31.23 (5.12)
| | | D2: 29.23 (3.45)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | CGI-I responders (CGI-I of much or very much improved) | Overall adverse events: | Attrition:
Schatzberg et al, 2002 | To compare efficacy and tolerability of MIR with PAR in elderly patients with MDD | - Adults 65 or older; - MDD diagnosis according to DSM-III or -IV; - HAM-D ≥ 18; - MMSE above 25% for age and educational level | D1: 71.7 | At endpoint | D1: 79.7 | 26.8%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 72.0 | MIR = (80) 64.0% | D2: 82.5 | ITT Analysis:
US | 8 wk acute phase, optional 16 wk continuation phase | - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - ECT within last 6 mos; - Suicide attempts; - MAOIs within 14 days, other psychotropic drugs or herbals within 7 days; - PAR or MIR for current depressive episode; - Patients requiring drugs for memory deficit; - Patients who did not respond to or tolerate MIR or PAR during a previous depressive episode | Sex (% female): | PAR = (68) 56.7% | Changes in weight (increase): | Yes
Mutli-center (recruited from advertising, private practice, routine intake at clinics and other healthcare facilities) | Study design: | | D1: 50 | chi square = 1.23 P = 0.267 | D1: 10.9 | Quality rating:
Funding: | RCT | | D2: 53 | Greater early efficacy for mirtazapine, similar number of CGI responders at end of continuation phase | D2: 0 | Fair
Organon Pharmacueticals | Overall study N: | | Race (% white): | | Constipation:
| 255 | | NR | | D1: 11.7
| Intervention: | | Baseline (HAM-A): | | D2: 11.1
| D1: MIR: 15 mg/d up to 45 mg/d | | NR | | Diarrhea:
| D2: Paroxetine: 20 mg/d up to 40 mg/d | | Mean HAM-D score at baseline: | | D1: 14.8
| | | D1: 22.2 (3.5) | | D2: 17.5
| | | D2: 22.4 (3.5) | | Dizziness:
| | | | | D1: 15.6
| | | | | D2: 14.3
| | | | | Headache:
| | | | | D1: 15.6
| | | | | D2: 24.6
| | | | | Insomnia:
| | | | | D1: 11.7
| | | | | D2: 11.1
| | | | | Nausea:
| | | | | D1: 6.3
| | | | | D2: 19.0
| | | | | Somnolence (fatigue):
| | | | | D1: 30.5
| | | | | D2: 29.4
| | | | | Sweating (increase):
| | | | | D1: 6.3
| | | | | D2: 13.5
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig diff in response among depressed cocaine abusers | NR | Overall attrition rate:
Schmitz et al., 2001 | To test hypothesis that FLUO would produce favorable effects onoutcome measures of retention, depression, and cocaine use compared with placebo for treatment of comorbid cocaine dependence and depression | - Adults 18 to 50; - Diagnosed with MDD according to DSM-III or -IV; - Diagnosed dually with MDD and cocaine dependence; - BDI score > 10; - English speaking; - Free of serious legal and medical problems | NR | | | 52.9%
Country and setting: | Duration of study: | Exclusion criteria: | Sex (% female): | | | ITT Analysis:
US | 12 wks | - Current dependence on alcohol or any other psychoactive substance (except nicotine or cannabis); - Met criteria for current primary Axis I disorders other than depression | NR | | | NR
Funding: | Study design: | | Race (% white): | | | Quality rating:
National Institute on Drug Abuse and Department of Pscyhiatry and Behavioral Sciences, University of Texas-Houston | RCT | | NR | | | Poor
| Overall study N: | | Baseline (HAM-A): | | | High LTF
| 68 | | NR
| Intervention: | | Baseline HAM-D:
| D1: Fluoxetine: 40 mg/d | | NR
| D2: Placebo
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Mean changes in HAM-D = -7.4 (SD 6.3) for SER and -6.6 (SD 6.4) for placebo with P = 0.01 | Diarrhea: | Overall attrition rate:
Schneider et al., 2003 and Sheikh et al., 2004 | To confirm results of non-placebo controlled efficacy trials of SER for treating late-life derpession and to report on efficacy, safety, and tolerability of SER in treatment of elderly depres-sed patients with and without comorbid medical illness | - Age 60 or more; - Diagnosed with MDD according to DSM-III or -IV; - HAM-D > 17; - Community-dwelling; - Episode ≥ 4 wks; - HAM-D depressed mood score ≥ 2 | D1: 70 | HAM-D responders = 35% for SER vs. 26% for placebo (P = 0.007) | D1: 19 | 20.9%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 69.6 | CGI responders = 45% for SER vs. 35% for placebo (chi sq = 7.8, df = 1, P = 0.005) | Dizziness: | ITT Analysis
US; psychiatric and primary care | 8 wks | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses; - Illicit drug and alcohol abuse; - Investigational drug in last 2 wks; - Any need for ECT; - Suicidal tendencies; - Psychotic features, dementia, seizure disorder; - Previous nonresponse/ hypersensitivity; - Clinically sig unstable medical disease; - Psychotherapy within 3 mos | Overall: 69.8 | SER was superior to placebo on all three primary outcome measures, HAM-D, and overall clinical severity and change (CGI-S/CGI-I). Furthermore, therapeutic response to SER was comparable in those with or without medical comorbidity, and there were no treatment by comorbidity group interactions | D1: 8 | Yes
Funding: | Study design: | | Sex (% female): | | Headache: | Quality rating:
Pfizer | RCT | | D1: 54 | | D1: 17 | Fair
| Overall study N: | | D2: 58 | | Insomnia:
| 752 | | Race (% white): | | D1: 9
| Intervention: | | NR | | Nausea:
| D1: Sertraline: 50–100 mg/d | | Baseline (HAM-A): | | D1: 16
| D2: Placebo | | NR | | Somnolence (fatigue):
| | | Baseline HAM-D: | | D1: 10
| | | D1: 21.4 (2.7)
| | | D2: 21.4 (2.6)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Wk 6 (endpoint) mean changes from baseline, PAR vs. FLUO, respectively: | Overall adverse events: | Overall attrition rate:
Schone et al., 1993 and Geretsegger et al., 1994 | To compare efficacy of PAR vs. FLUO in treatment of depression among elderly clients, and to assess drugs' effects on clients' cognitive and behavioral function | - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18 | D1: 74.3 | (1) SCAG total score = -14.5 vs. -8.9. (2)SCAG Cognitive dysfunction factor scores = -2.9 vs. -0.6. (3) HAM-D cognitive factor scores = -1.5 vs. -1.0. (4)MMS total scores = 2.3 vs. 1.1 | D1: 61 | 17%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 73.7 | Sig higher proportion of responders (reduction of 50% or more in HAM-D [37.5% vs. 17.5%, P = 0.03] or MADRS [P = 0.04] total scores) at end of treatment in PAR group. No sig diff between treatment groups in proportion of responders on CGI-S | D2: 77 | ITT Analysis
NR (but assume Germany, based on authors' affiliations), inpatient and outpatient clinics | 6 wks | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - ECT within last 3 mos; - Serious risk of suicide; - Improvement of more than 20% on HAM-D during placebo run-in period (3–7 days) | Sex (% female): | | Constipation: | Yes
Funding: | Study design: | | D1: 83.3 | | D1: 10 | Quality rating:
Not reported | RCT | | D2: 90.4 | | D2: 0 | Fair
| Overall study N: | | Race (% white): | | Dizziness:
| 106 | | NR | | D1: 0
| Intervention: | | Baseline (HAM-A): | | D2: 7
| D1: Paroxetine: 20–40 mg | | NR
| D2: Fluoxetine: 20–60 mg | | Baseline HAM-D:
| | | D1: 24.2
| | | D2: 26.0
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | At 9 wks mean HAM-D-17 score FLUO - 8.34 (5.87) vs. placebo 5.84 (5.92) (P = 0.06) but mildly depressed patients in FLUO group had endpoint HAM-D scores sig different (by 5.4 points) than placebo (P = 0.01). At wk 25- responder rates 48% (fluox) vs. 26% (placebo) (P = 0.05) and remission rates 26% (fluox) vs. 14.8% (placebo)(P = 0.60) | Cardiovascular adverse events: | Overall attrition rate:
Strik et al., 2000 | To investigate efficacy and safety of FLUO in patients with depression after their first MI | - Adults 18 to 75; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 17; - 3 to 12 mos post-MI | D1: 54.1 | | D1: 18.5 | 25.9%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 58.7 | | D2: NR | ITT Analysis
Netherlands | Maximum of 25 wks (acute phase 9 wks; continuation phase 16 wks) | - Concomitant psychotheraputic or psychotropic medications; - Additional mental illnesses or organic mental disorder; - Clinically sig medical disease; - Right ventricular filling pressure > 30 mmHG; ATVI < 20 cm | Sex (% female): | | | Yes
Hospitals (2) | Study design: | | D1: 22.2 | | | Quality rating:
Funding: | RCT | | D2: 37.0 | | | Good
Eli Lilly | Overall study N: | | Race (% white):
Dutch Prevention Fund; Maastricht University Hospital Research Fund | 54 | | NR
| Intervention: | | Baseline (HAM-A):
| D1: Fluoxetine: 20–60 mg/d | | NR
| D2: Placebo | | Baseline HAM-D:
| | | D1: 22.0 (3.5)
| | | D2: 21.2 (3.7)
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | FLUO had sig better rates of response and remission than placebo. Response of FLUO group was 36% versus 27% placebo (P = 0.014) and remission of FLUO group was 21% versus 13% for placebo (P = 0.008) | Overall adverse events: | Overall attrition rate:
Tollefson et al., 1993 | To compare HAM-D scores of FLUO-treated vs. placebo-treated elderly depressed patients (not explicitly stated) | - Adults 60 yrs or older; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 16; - MMSE < 25 | NR | FLUO was statistically sig more efficacious than placebo in overall response (43.9% vs. 31.6%, P = 0.002) and remission (31.6% vs. 18.6%, P < 0.001) | D1: 11.6% discontinuation rate | 20.4%
Tollefson et al., 1995 | Duration of study: | Exclusion criteria: | Sex (% female): | Number of physical illnesses did not affect treatment response, though historic illness was associated with greater fluoxetine repsone and poorer placebo repsonse | Dizziness: | ITT Analysis
Small et al., 1996 and | 6 wks | - Concomitant psychotheraputic or psychotropic medications; - Clinically sig medical disease; - Suicidal tendencies | NR | | D1: 0.3% discontinuation rate | Yes
Heiligenstein et al., 1995 | Study design: | | Race (% white): | | Insomnia: | Quality rating:
Country and setting: | RCT | | NR | | D1: 0.9% discontinuation rate | Fair
US | Overall study N: | | Baseline (HAM-A): | | Suicidality:
Mulitcenter | 671 | | NR | | D1: n = 4
Funding: | Intervention: | | Baseline HAM-D:
Not reported | D1: Fluoxetine: 20 mg/d | | NR
| D2: Placebo
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | No sig diffs in any outcome measures between treatment groups (LOCF and observed ) | Constipation: | Attrition:
Weihs et al., 2000 | Comparison of efficacy and safety of BUP and PAR with PAR in treatment of MDD in elderly | - Adults 60+; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18 | D1: 69.2 | Response rates ≥ 50% reduction in HAM-D) were similar in both groups: | D1: 4 | 16%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 71.0 | BUP sr: 71% | D2: 15 | ITT Analysis:
US | 6 wks | - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidal tendencies | Sex (% female): | PAR: 77% | Diarrhea: | Yes
Multicenter | Study design: | | D1: 54 | No sig diffs in QOL scales (QLDS, SF-36) between treatment groups at endpoint; overall sig improvement in QLDS and QOL at day 42 (P < 0.0001) | D1: 6 | Quality rating:
Funding: | RCT | | D2: 60 | | D2: 21 | Fair
Glaxo Wellcome | Overall study N: | | Race (% white): | | Dizziness:
| 100 | | D1: 98 | | D1: >10
| Intervention: | | D2: 90 | | D2: >10
| D1: Bupropion: 100–300 mg/d (197) | | Baseline (HAM-A): | | Headache:
| D2: Paroxetine: 10–40 mg/d (22) | | NR | | D1: 35
| | | Mean HAM-D score at baseline: | | D2: 19
| | | NR | | Insomnia:
| | | | | D1: >10
| | | | | D2: >10
| | | | | Nausea:
| | | | | D1: >10
| | | | | D2: >10
| | | | | Somnolence (fatigue):
| | | | | D1: 6
| | | | | D2: 27
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Mean decrease in HSCL-D-20: | NR | Overall attrition rate:
Williams et al., 2000 | To compare effectiveness of PAR vs. placebo vs. behavioral treatment for dysthymia or minor depression in primary care patients older than 60 yrs | - Minimum HAM-D score of 10; - Dysthymia; - Age 60+ | D1: 71 | PAR: 0.61 (P = 0.05) | | 25.1%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 71 | placebo: 0.40 (P = 0.05) | | TT Analysis:
United States | 11 wk | - Additional mental illnesses or organic mental disorder; - Illicit drug and alcohol abuse; - Severe Suicidal tendencies; - MMSE <24; - Current depression treatment | Sex (% female): | Behavior Therapy 0.52 (P = 0.05) | | Yes
Multicenter, primary care clinics | Study design: | | D1: 39 | P = 0.004 for PAR vs. placebo | | Quality rating:
Funding: | RCT | | D2: 45 | PAR only statistically and clinically sig better than placebo for subjects with dysthymia and high baseline mental health function | | Fair
Hartford and MacArthur Foundations | Overall study N: | | Race (% white): | HAM-D results NR for ITT population
| 415 | | D1: 82.5
| Intervention: | | D2: 75.7
| D1: Paroxetine: 10–40, individually titrated | | Baseline (HAM-A):
| D2: placebo | | NR
| | | Mean HAM-D score at baseline:
| | | NR
Author: | Research objective: | Inclusion criteria: | Mean age (yrs): | Analysis of recurrence | NR | Overall attrition rate:
Wilson et al, 2003 | To examine efficacy of SER in preventing recurrence of depression in older people living in community | - Adults 65+; - Diagnosed with MDD according to DSM-III or -IV; - Minimum HAM-D score of 18; - Geriatric Mental State AGECAT depression level 3 or greater | D1: 76.6 | Kaplan Meier analysis, SER vs placebo, log rank test = 1.55, df = 1 (P = 0.21) | | 72.6%
Country and setting: | Duration of study: | Exclusion criteria: | D2: 76.8 | Cumulative survival function | | ITT Analysis
UK, outpatient clinic(s) | 8 wk treatment phase and a 16–20 wk continuation phase (open-label SER) | - Concomitant psychotheraputic or psychotropic medications; - Illicit drug and alcohol abuse; - Clinically sig medical disease; - Suicidial tendencies: sig suicidal or delusional experiences; - MMSE ≤ 11; - Concomitant drugs excluded include psychotropic drugs, warfarin, and anticonvulsants | Sex (% female): | SER = 39%, median survival 92 wks; placebo = 31%, median survival 48 wks | | Not applicable:
Funding: | 100 wk randomized, double-blind phase (SER and placebo) (article focuses on results of this maintenance phase) | | D1: 66.1 | Reduction in risk of recurrence: 8.4% over 100 wks (SER vs. placebo) | | recurrence trial
Not reported | Study design: | | D2: 75.4 | % with recurrence in first 26 wks and wks 27–52, respectively: | | Quality rating:
| RCT | | Race (% white): | SER = 57%, 16% | | Fair
| Overall study N: | | NR | placebo = 60%, 32%
| 113 (randomised to double-blind phase) | | Baseline (HAM-A): | Cox regression model predicting recurrence:
| Intervention: | | NR | hazard ratio (95% CI)
| D1: Sertraline: 50–100 mg/d | | Baseline HAM-D: | included variables:
| D2: Placebo | | D1: 20.7 (3.7) | SER vs. placebo = 1.21 (0.704, 2.082)
| | | D2: 20.3 (3.3)

Evidence Table 7. KQ5: Systematic reviews and meta-analyses on antidepressants in subpopulations

Study Characteristics | Study Information | Study Characteristics | Results | Adverse Events (%) | Assessments | Study Appraisals and Quality Rating
Author: | Study design: | Included Studies: | Study Results: | Adverse Events: | Publication Bias: | Standard Method of Study Appraisals:
Bush et al., 2005 | Systematic review | See above | In post-MI patients with depression, selective serotonin reuptake inhibitors improve depression and some surrogate markers of cardiac risk, but no studies of sufficient power address question of whether treatment improves survival | NR | Yes | Yes
Country and setting: | Number of Patients: | Included Populations | | | Heterogeneity: | Comprehensive Search Strategy:
Multinational | NR | Patients suffering from myocardial infarction and depression | | | Yes | MEDLINE®, Cochrane CENTRAL Register of Controlled Trials (Issue 1, 2003), Cochrane Database of Methodology Reviews (CDMR®), Cumulative Index of Nursing and Allied Health Literature (CINAHL®), Psychological Abstracts (PsycINFO®), and EMBASE
Funding: | Studies Included: | Interventions: | | | | Quality Rating:
AHRQ | Studies (86) have examined depression or depressive symptoms in patients after MI and focuses on prevalence, clinical significance, treatment, and methods of evaluating condition | SSRIs and therapy | | | | Fair
Research objective:
To examine role of depression post-MI
Author: | Study design: | Included Studies: | Study Results: | Adverse Events: | Publication Bias: | Standard Method of Study Appraisals:
Entsuah et al., 2001 | Pooled analysis | Studies that compared VEN to FLUO or PAR | No sig age by treatment; gender by treatment; or age-by-gender by treatment interactions (all P -values >0.1) | Women on VEN had more nausea than other groups | No | NR
Thase et al., 2005 | Number of Patients: | Included Populations | Among women, but not men, there was a sig interaction reflecting poorer SSRI response in older age group (P = 0.04). HRT appeared to eliminate this diff. Diff among older women taking and not taking HRT was 23% | | Heterogeneity: | Comprehensive Search Strategy:
Country and setting: | 2,045 | - 18 yrs of age or more; - HAM-D of 20 or more or MADRS of 25 or more | Remission (HAMD at endpoint ≤ 7): | | No | No
Multinational | Studies Included: | Interventions: | VEN = 45% | | | Quality Rating:
Funding: | 8 double-blind, active controlled | - D1: Venlafaxine 75–225 mg/d; - D2: Fluoxetine 20–50 mg/d; - D3: Paroxetine 20–40 mg d | SSRI = 35% | | | Fair
NR | | | placebo = 25%
Research objective: | | | (VEN vs SSRI, P < 0.0001; SSRI vs placebo, P = 0.0003)
To compare response and remission rates in different sub-populations

MMA Abbreviations for Evidence Tables

A/S | Aktieselskap (Company type in Denmark)
AD | antidepressant
AE | adverse event
AIDS | acquired immune deficiency syndrome
AMT | awake and moving time
ARV | antiretroviral
ATVI | aortic time velocity interval
BDI | Beck Depression Inventory
BMI | body mass index
BP | blood pressure
BQOL | Battelle Quality of Life Measure
BSI | Brief Symptom Inventory of Depression
BUP SR | bupropion sustained release
BUP | bupropion
CBT | cognitive-behavioral therapy
CDC | Centers for Disease Control and Prevention
CESD | Center for Epidemiologic Studies-Depression
CGI | Clinical Global Impressions
CGI-I | Clinical Global Impressions Improvement Scale
CGI-S | Clinical Global Impressions Severity Scale
CI | confidence interval
CIT | citalopram
cm | centimeter
CR | controlled release
D | drug
DBP | diastolic blood pressure
DESS | Discontinuation-Emergent Signs and Symptoms checklist
df | degrees of freedom
diff | difference(s)
DSM | Diagnostic and Statistical Manual of Mental Disorders
DSM-III | Diagnostic and Statistical Manual of Mental Disorders, version III
DSM-III-R | Diagnostic and Statistical Manual of Mental Disorders, version III revised
DSM-IV | Diagnostic and Statistical Manual of Mental Disorders, version IV
DSP | deliberate self-poisoning
DUL | duloxetine
ECG | electrocardiogram
ECT | Electroconvulsive therapy
EEG | electroencephalogram
ESC | escitalopram
FDA | Food and Drug Administration
FLUO | fluoxetine
FLUV | fluvoxamine
FSQ | Functional Status Questionnaire
GBS | Gottfrey-Brane-Steen
GDS | Geriatric Depression Scale
GP | general physician
GPRD | General Practice Research Database
HAM-A | Hamilton Rating Scale for Anxiety
HAM-D | Hamilton Rating Scale for Depression
HIV | Human immunodeficiency virus
HSCL-D | Hopkins Depression Scale
HTN | hypertension
ICD10 | International Classification of Diseases- 10^th^ revision
IDS | Inventory for Depressive Symptomatology
IDS-C | Inventory for Depressive Symptomatology - Clinician Rated
IDS-SR | Inventory for Depressive Symptomatology - Self Rated
IMI | imipramine
IR | immediate release
ITT | intent to treat
KQ | key question
LOCF | last-observation-carried-forward
LTF | loss to follow-up
MADRS | Montgomery Asberg Depression Rating Scale
MAF | Multidimensional
MAOI | monoamine oxidase inhibitor
m-CPP | meta-chlorophenylpiperazine
MD | medical doctor
MDD | major depressive disorder
MI | myocardial infarction
mil | milnacipran
MINI | Mini International Neuropsychiatric Interview
MIR | mirtazapine
mmHG | millimeters of mercury
MMSE | Mini Mental State Examination
mo | month(s)
N | number
N/A | not applicable
NEF | nefazodone
NIH | National Institute of Health
NIHM | Health Diagnostic Interview Schedule
NIMH | National Institute of Mental Health
NNT | number needed to treat
NoVASC | no other comorbid vascular illness
NR | not reported
NS | not sig
NV | Naamloze Vennootschap (Dutch company type)
OR | odds ratio
P | P-value
PAR | paroxetine
PCP | primary care physician
PGI | Patient Global Impression
PGIS | Patient Global Improvement Scale
Phys-SFR | physicians rating of sexual functioning
PSD | poststroke depression
px | prescription
QLDS | Quality of Life in Depression Scale
Q-LES-Q | Quality of Life Enjoyment and Satisfaction Questionnaire
QLSQ | Q-LES-Q
QOL | quality of life
QRS | time of ventricular contraction
QTcF | Fridericia-corrected time of ventricular contraction
RCT | randomized controlled trial
RD | Risk difference
RNZCGP | Royal New Zealand College of General Practitioners
RR | relative risk
RRR | relative risk ratio
SCID | Structured Clinical Interview for DSM-III Revised
SD | sexual dysfunction
SDS | Self rating Depression Scale
SDS | Sheehan Disability Scale
SER | sertraline
SF-36 | Medical Outcomes Study Health Survey - Short Form 36
Sig | significant/significantly
SIP | Sickness Impact Profile
SSRI | selective serotonin reuptake inhibitor
TCA | tricyclic antidepressant
TMT-A | Trail Making Test - Part A
TMT-B | Trail Making Test - Part B
TRA | Trazodone
UK | United Kingdom
UKU | Utvalg for Kliniske Undersogelse (Side Effect Scale)
US | United States
USA | United States of America
UT | Utah
VAS | visual analog scale
VASC | patients with a history of cardiovascular illness (excluding hypertension)
VEN ER | venlafaxine extended release
VEN XR | venlafaxine extended release
VEN | venlafaxine
VF | verbal fluency test
vs. | versus
WHO | World Health Organization
wk | week(s)
WMS | Wechsler Memory Scale
yr | year(s)