# Excluded Studies

## Background

This appendix documents that 525 publications that we identified but did not ultimately include in this report. The citations are numbered consecutively throughout the appendix, but within groupings of the major reasons for exclusion, they are listed alphabetical order by author. The groupings include publication in a language other than English, the wrong outcome, relevant drug(s) not included in the study or publication, population not included, wrong publication type, and wrong study design

## Articles by Reason for Exclusion

### Not Published in English

1 Berlanga C, Arechavaleta B, Heinze G, Campillo C, Torres M, Caballero A, et al. A double-blind comparison of nefazodone and fluoxetine in the treatment of depressed outpatients. Salud Mental. 1997;20(3):1-8.
2 Bremner JD. Double-blind comparison of mirtazapine, amitriptyline and placebo in major depression. <ORIGINAL> DOPPELBLINDVERGLEICH VON MIRTAZAPIN, AMITRIPTYLIN UND PLAZEBO BEI “MAJOR DEPRESSION”. Nervenheilkunde. 1996;15(8):533-540.
3 Peters UH, Lenhard P, Metzm M. Therapy of depression in the psychiatrist's office - A double-blind multicenter study. Nervenheilkunde. 1990;9(1):28-31.
4 Schone W, Ludwig M. Paratoxetine in the treatment of geriatric depressed patients - A double-blind comparison with fluoxetine. <ORIGINAL> PAROXETIN IN DER DEPRESSIONSBEHANDLUNG GERIATRISCHER PATIENTEN - EINE DOPPELBLINDE VERGLEICHSSTUDIE MIT FLUOXETIN. Fortschr Neurol Psychiatr. 1994;62(Suppl 1):16-18. [pmid: 7959520].
5 Skarstein J. A ‘trouble-blind’ placebo controlled comparative study between two new antidepressant agents (Seroxat (R) (paroxetine) and Tolvon (R) (mianserin)): <ORIGINAL> EN ‘TROUBLE-BLIND’ PLACEBOKONTROLLERT SAMMENLIKNENDE UNDERSOKELSE MELLOM TO NYE ANTIDEPRESSIVER. Tidsskrift For Den Norske Laegeforening. 1998;118(2):265-266. [pmid: 9485626].
6 Tsutsui S, Okuse S, Sasaki D, Hongo M, Katsura T, Suematsu H, et al. Clinical evaluation of sertraline hydrochloride, a selective serotonin reuptake inhibitor in the treatment of depression and depressive state: A double blind, group comparison study of sertraline hydrochloride vs. trazodone hydrochloride. Japanese Journal of Neuropsychopharmacology. 1997;19(6):549-568.

### Wrong Outcome

7 Ackerman DL, Greenland S, Bystritsky A, Small GW. Characteristics of fluoxetine versus placebo responders in a randomized trial of geriatric depression. Psychopharmacol Bull. 1997;33(4):707-14. [pmid: 9493483].
8 Amsterdam JD, Brunswick DJ. Site variability in treatment outcome in antidepressant trials. Prog Neuropsychopharmacol Biol Psychiatry. 2002;26(5):989-93. [pmid: 12369275].
9 Argyropoulos SV, Hicks JA, Nash JR, Bell CJ, Rich AS, Nutt DJ, et al. Correlation of subjective and objective sleep measurements at different stages of the treatment of depression. Psychiatry Res. 2003;120(2):179-90. [pmid: 14527649].
10 Armitage R, Yonkers K, Cole D, Rush AJ. A multicenter, double-blind comparison of the effects of nefazodone and fluoxetine on sleep architecture and quality of sleep in depressed outpatients. J Clin Psychopharmacol. 1997;17(3):161-8. [pmid: 9169959].
11 Arroll B, Macgillivray S, Ogston S, Reid I, Sullivan F, Williams B, et al. Efficacy and tolerability of tricyclic antidepressants and SSRIs compared with placebo for treatment of depression in primary care: a meta-analysis. Ann Fam Med. 2005;3(5):449-56. [pmid: 16189062]. [pmcid: 1466912].
12 Bair MJ, Robinson RL, Eckert GJ, Stang PE, Croghan TW, Kroenke K. Impact of pain on depression treatment response in primary care. Psychosom Med. 2004;66(1):17-22. [pmid: 14747633].
13 Barak Y, Kimhi R, Weizman R. Is selectivity for serotonin uptake associated with a reduced emergence of manic episodes in depressed patients?. Int Clin Psychopharmacol. 2000;15(1):53-6. [pmid: 10836288].
14 Beasley CM Jr, Koke SC, Nilsson ME, Gonzales JS. Adverse events and treatment discontinuations in clinical trials of fluoxetine in major depressive disorder: an updated meta-analysis. Clin Ther. 2000;22(11):1319-30. [pmid: 11117656].
15 Bech P. Meta-analysis of placebo-controlled trials with mirtazapine using the core items of the Hamilton Depression Scale as evidence of a pure antidepressive effect in the short-term treatment of major depression. Int J Neuropsychopharmacol. 2001;4(4):337-45. [pmid: 11806859].
16 Bent-Hansen J, Lunde M, Klysner R, Andersen M, Tanghoj P, Solstad K, et al. The validity of the depression rating scales in discriminating between citalopram and placebo in depression recurrence in the maintenance therapy of elderly unipolar patients with major depression. Pharmacopsychiatry. 2003;36(6):313-6. [pmid: 14663657].
17 Berman RM, Anand A, Cappiello A, Miller HL, Hu XS, Oren DA, et al. The use of pindolol with fluoxetine in the treatment of major depression: final results from a double-blind, placebo-controlled trial. Biol Psychiatry. 1999;45(9):1170-7. [pmid: 10331109].
18 Brown WA, Dornseif BE, Wernicke JF. Placebo response in depression: a search for predictors. Psychiatry Res. 1988;26(3):259-64. [pmid: 3065807].
19 Brunswick DJ, Amsterdam JD, Fawcett J, Quitkin FM, Reimherr FW, Rosenbaum JF, et al. Fluoxetine and norfluoxetine plasma concentrations during relapse-prevention treatment. J Affect Disord. 2002;68(23):243-9. [pmid: 12063152].
20 Burke WJ, Hendricks SE, McArthur-Campbell D, Jacques D, Stull T. Fluoxetine and norfluoxetine serum concentrations and clinical response in weekly versus daily dosing. Psychopharmacol Bull. 1996;32(1):27-32. [pmid: 8927671].
21 Burke WJ, Dewan V, Wengel SP, Roccaforte WH, Nadolny GC, Folks DG. The use of selective serotonin reuptake inhibitors for depression and psychosis complicating dementia. Int J Geriatr Psychiatry. 1997;12(5):519-25. [pmid: 9193959].
22 Burke WJ, Hendricks SE, McArthur-Miller D, Jacques D, Bessette D, McKillup T, et al. Weekly dosing of fluoxetine for the continuation phase of treatment of major depression: results of a placebo-controlled, randomized clinical trial. J Clin Psychopharmacol. 2000;20(4):423-7. [pmid: 10917403].
23 Carney RM, Blumenthal JA, Freedland KE, Youngblood M, Veith RC, Burg MM, et al. Depression and late mortality after myocardial infarction in the Enhancing Recovery in Coronary Heart Disease (ENRICHD) study. Psychosom Med. 2004;66(4):466-74. [pmid: 15272090].
24 Cook IA, Leuchter AF, Witte E, Abrams M, Uijtdehaage SH, Stubbeman W, et al. Neurophysiologic predictors of treatment response to fluoxetine in major depression. Psychiatry Res. 1999;85(3):263-73. [pmid: 10333379].
25 Cornelius JR, Salloum IM, Ehler JG, Jarrett PJ, Cornelius MD, Black A, et al. Double-blind fluoxetine in depressed alcoholic smokers. Psychopharmacol Bull. 1997;33(1):165-70. [pmid: 9133770].
26 Davidson J, Watkins L, Owens M, Krulewicz S, Connor K, Carpenter D, et al. Effects of paroxetine and venlafaxine XR on heart rate variability in depression. J Clin Psychopharmacol. 2005;25(5):480-4. [pmid: 16160626].
27 Debus JR, Rush AJ, Himmel C, Tyler D, Polatin P, Weissenburger J. Fluoxetine versus trazodone in the treatment of outpatients with major depression. J Clin Psychiatry. 1988;49(11):422-6. [pmid: 3053668].
28 Doraiswamy PM, Khan ZM, Donahue RM, Richard NE. Quality of life in geriatric depression: a comparison of remitters, partial responders, and nonresponders. Am J Geriatr Psychiatry. 2001;9(4):423-8. [pmid: 11739069].
29 Dunlop SR, Dornseif BE, Wernicke JF, Potvin JH. Pattern analysis shows beneficial effect of fluoxetine treatment in mild depression. Psychopharmacol Bull. 1990;26(2):173-80. [pmid: 2236453].
30 Dunner DL, D'Souza DN, Kajdasz DK, Detke MJ, Russell JM. Is treatment-associated hypomania rare with duloxetine: secondary analysis of controlled trials in non-bipolar depression. J Affect Disord. 2005;87(1):115-9. [pmid: 15967235].
31 Durham LK, Webb SM, Milos PM, Clary CM, Seymour AB. The serotonin transporter polymorphism, 5HTTLPR, is associated with a faster response time to sertraline in an elderly population with major depressive disorder. Psychopharmacology (Berl). 2004;174(4):525-9. [pmid: 12955294].
32 Dursun SM, Bird D, Ronson KE. Nefazodone treatment of dysthymic disorder an open, long-term, prospective pilot study. Prog Neuropsychopharmacol Biol Psychiatry. 2002;26(4):671-6. [pmid: 12188098].
33 Eick TJ, Kofoed L. An unusual indication for a single-subject clinical trial. J Nerv Ment Dis. 1994;182(10):587-90. [pmid: 7931209].
34 Ekselius L, von Knorring L. Personality disorder comorbidity with major depression and response to treatment with sertraline or citalopram. Int Clin Psychopharmacol. 1998;13(5):205-11. [pmid: 9817625].
35 Ekselius L, Bengtsson F, von Knorring L. Non-compliance with pharmacotherapy of depression is associated with a sensation seeking personality. Int Clin Psychopharmacol. 2000;15(5):273-8. [pmid: 10993129].
36 Entsuah AR, Bradley MM, Littman GS. Cumulative mean change procedure: application to a comparative trial of venlafaxine, imipramine, and placebo in the treatment of major depression. Prog Neuropsychopharmacol Biol Psychiatry. 1994;18(4):695-706. [pmid: 7938560].
37 Entsuah AR, Rudolph RL, Hackett D, Miska S. Efficacy of venlafaxine and placebo during long-term treatment of depression: a pooled analysis of relapse rates. Int Clin Psychopharmacol. 1996;11(2):137-45. [pmid: 8803651].
38 Fava M, Labbate LA, Abraham ME, Rosenbaum JF. Hypothyroidism and hyperthyroidism in major depression revisited. J Clin Psychiatry. 1995;56(5):186-92. [pmid: 7737957].
39 Fava M, Nierenberg AA, Quitkin FM, Zisook S, Pearlstein T, Stone A, et al. A preliminary study on the efficacy of sertraline and imipramine on anger attacks in atypical depression and dysthymia. Psychopharmacol Bull. 1997;33(1):101-3. [pmid: 9133758].
40 Ferguson JM, Wesnes KA, Schwartz GE. Reboxetine versus paroxetine versus placebo: effects on cognitive functioning in depressed patients. Int Clin Psychopharmacol. 2003;18(1):9-14. [pmid: 12490769].
41 Fernandez JL, Montgomery S, Francois C. Evaluation of the cost effectiveness of escitalopram versus venlafaxine XR in major depressive disorder. Pharmacoeconomics. 2005;23(2):155-67. [pmid: 15748090].
42 Fieve RR, Goodnick PJ, Peselow ED, Barouche F, Schlegel A. Pattern analysis of antidepressant response to fluoxetine. J Clin Psychiatry. 1986;47(11):560-2. [pmid: 3533909].
43 Fisch C, Knoebel SB. Electrocardiographic findings in sertraline depression trials. Drug Invest. 1992;4(4):305-312.
44 Gershon S, Georgotas A, Newton R, Bush D. Clinical evaluation of two new antidepressants. Adv Biochem Psychopharmacol. 1982;32:57-68. [pmid: 6211943].
45 Goodnick PJ, Fieve RR, Peselow ED, Barouche F, Schlegel A. Double-blind treatment of major depression with fluoxetine: use of pattern analysis and relation of HAM-D score to CGI change. Psychopharmacol Bull. 1987;23(1):162-3. [pmid: 3496624].
46 Greenberg RP, Bornstein RF, Zborowski MJ, Fisher S, Greenberg MD. A meta-analysis of fluoxetine outcome in the treatment of depression. J Nerv Ment Dis. 1994;182(10):547-51. [pmid: 7931201].
47 Grossman R, Reynolds D, Goodman M, New A, Silverman J, Schmeidler J, et al. Efficacy of open-label venlafaxine in subjects with major depressive disorder: associations with neuroendocrine response to serotonergic and noradrenergic probes. Psychiatry Res. 2004;128(2):203-6. [pmid: 15488964].
48 Hamed A, Lee A, Ren XS, Miller DR, Cunningham F, Zhang H, et al. Use of antidepressant medications: are there differences in psychiatric visits among patient treatments in the Veterans Administration?. Med Care. 2004;42(6):551-9. [pmid: 15167323].
49 Hamilton SP, Nunes EV, Janal M, Weber L. The effect of sertraline on methadone plasma levels in methadone-maintenance patients. Am J Addict. 2000;9(1):63-9. [pmid: 10914294].
50 Hayes RL, Gerner RH, Fairbanks L, Moran M, Waltuch L. ECG findings in geriatric depressives given trazodone, placebo, or imipramine. J Clin Psychiatry. 1983;44(5):180-3. [pmid: 6343360].
51 Heiligenstein JH, Tollefson GD, Faries DE. A double-blind trial of fluoxetine, 20 mg, and placebo in out-patients with DSM-III-R major depression and melancholia. Int Clin Psychopharmacol. 1993;8(4):247-51. [pmid: 8277143].
52 Heiligenstein JH, Faries DE, Rush AJ, Andersen JS, Pande AC, Roffwarg HP, et al. Latency to rapid eye movement sleep as a predictor of treatment response to fluoxetine and placebo in nonpsychotic depressed outpatients. Psychiatry Res. 1994;52(3):327-39. [pmid: 7991725].
53 Hellerstein DJ, Kocsis JH, Chapman D, Stewart JW, Harrison W. Double-blind comparison of sertraline, imipramine, and placebo in the treatment of dysthymia: effects on personality. Am J Psychiatry. 2000;157(9):1436-44. [pmid: 10964860].
54 Himmelhoch JM, Schechtman K, Auchenbach R. The role of trazodone in the treatment of depressed cardiac patients. Psychopathology. 1984;17(Suppl 2):51-63. [pmid: 6201941].
55 Hirschfeld RM, Mallinckrodt C, Lee TC, Detke MJ. Time course of depression-symptom improvement during treatment with duloxetine. Depress Anxiety. 2005;21(4):170-7. [pmid: 16035056].
56 Hochberg HM, Kanter D, Houser VP. Electrocardiographic findings during extended clinical trials of fluvoxamine in depression: one years experience. Pharmacopsychiatry. 1995;28(6):253-6. [pmid: 8773292].
57 Hoflich G, Kasper S, Danos P, Schmidt R. Thyroid hormones, body temperature, and antidepressant treatment. Biol Psychiatry. 1992;31(8):859-62. [pmid: 1643199].
58 Jamerson BD, Krishnan KR, Roberts J, Krishen A, Modell JG. Effect of bupropion SR on specific symptom clusters of depression: analysis of the 31-item Hamilton Rating Scale for depression. Psychopharmacol Bull. 2003;37(2):67-78. [pmid: 14566216].
59 Katon W, Russo J, Frank E, Barrett J, Williams JW Jr, Oxman T, et al. Predictors of nonresponse to treatment in primary care patients with dysthymia. Gen Hosp Psychiatry. 2002;24(1):20-7. [pmid: 11814530].
60 Koran LM, Hamilton SH, Hertzman M, Meyers BS, Halaris AE, Tollefson GD, et al. Predicting response to fluoxetine in geriatric patients with major depression. J Clin Psychopharmacol. 1995;15(6):421-7. [pmid: 8748431].
61 Kraus T, Haack M, Schuld A, Hinze-Selch D, Koethe D, Pollmacher T. Body weight, the tumor necrosis factor system, and leptin production during treatment with mirtazapine or venlafaxine. Pharmacopsychiatry. 2002;35(6):220-5. [pmid: 12518269].
62 Kreider MS, Bushnell WD, Oakes R, Wheadon DE. A double-blind, randomized study to provide safety information on switching fluoxetine-treated patients to paroxetine without an intervening washout period. J Clin Psychiatry. 1995;56(4):142-5. [pmid: 7713852].
63 Lam RW, Gorman CP, Michalon M, Steiner M, Levitt AJ, Corral MR, et al. Multicenter, placebo-controlled study of fluoxetine in seasonal affective disorder. Am J Psychiatry. 1995;152(12):1765-70. [pmid: 8526243].
64 Leuchter AF, Morgan M, Cook IA, Dunkin J, Abrams M, Witte E. Pretreatment neurophysiological and clinical characteristics of placebo responders in treatment trials for major depression. Psychopharmacology (Berl). 2004;177(12):15-22. [pmid: 15252704].
65 Linden RD, Wilcox CS, Heiser JF, Cavanaugh E, Wisselink PG. Are selective serotonin reuptake inhibitors well tolerated in somatizing depressives?. Psychopharmacol Bull. 1994;30(2):151-6. [pmid: 7831448].
66 Marie-Mitchell A, Leuchter AF, Chou CP, James Gauderman W, Azen SP. Predictors of improved mood over time in clinical trials for major depression. Psychiatry Res. 2004;127(12):73-84. [pmid: 15261707].
67 McFarlane A, Kamath MV, Fallen EL, Malcolm V, Cherian F, Norman G. Effect of sertraline on the recovery rate of cardiac autonomic function in depressed patients after acute myocardial infarction. Am Heart J. 2001;142(4):617-23. [pmid: 11579351].
68 Michelson D, Bancroft J, Targum S, Kim Y, Tepner R. Female sexual dysfunction associated with antidepressant administration: a randomized, placebo-controlled study of pharmacologic intervention. Am J Psychiatry. 2000;157(2):239-43. [pmid: 10671393].
69 Michelson D, Amsterdam J, Apter J, Fava M, Londborg P, Tamura R, et al. Hormonal markers of stress response following interruption of selective serotonin reuptake inhibitor treatment. Psychoneuroendocrinology. 2000;25(2):169-77. [pmid: 10674280].
70 Mitchell AJ, Subramaniam H. Prognosis of depression in old age compared to middle age: a systematic review of comparative studies. Am J Psychiatry. 2005;162(9):1588-601. [pmid: 16135616].
71 Montgomery SA, Pedersen V, Tanghoj P, Rasmussen C, Rioux P. The optimal dosing regimen for citalopram—a meta-analysis of nine placebo-controlled studies. Int Clin Psychopharmacol. 1994;9(Suppl 1):35-40. [pmid: 8021436].
72 Murphy GM Jr, Hollander SB, Rodrigues HE, Kremer C, Schatzberg AF. Effects of the serotonin transporter gene promoter polymorphism on mirtazapine and paroxetine efficacy and adverse events in geriatric major depression. Arch Gen Psychiatry. 2004;61(11):1163-9. [pmid: 15520364].
73 Nierenberg AA, Pava JA, Clancy K, Rosenbaum JF, Fava M. Are neurovegetative symptoms stable in relapsing or recurrent atypical depressive episodes?. Biol Psychiatry. 1996;40(8):691-6. [pmid: 8894060].
74 Nofzinger EA, Reynolds CF 3rd, Thase ME, Frank E, Jennings JR, Fasiczka AL, et al. REM sleep enhancement by bupropion in depressed men. Am J Psychiatry. 1995;152(2):274-6. [pmid: 7840365].
75 Oakley F, Khin NA, Parks R, Bauer L, Sunderland T. Improvement in activities of daily living in elderly following treatment for post-bereavement depression. Acta Psychiatr Scand. 2002;105(3):231-4. [pmid: 11939978].
76 Oxman TE, Hull JG. Social support and treatment response in older depressed primary care patients. J Gerontol B Psychol Sci Soc Sci. 2001;56(1):P35-45. [pmid: 11192336].
77 Papakostas GI, Petersen T, Denninger JW, Montoya HD, Nierenberg AA, Alpert JE, et al. Treatment-related adverse events and outcome in a clinical trial of fluoxetine for major depressive disorder. Ann Clin Psychiatry. 2003;15(34):187-92. [pmid: 14971864].
78 Papakostas GI, Iosifescu DV, Petersen T, Hamill SK, Alpert JE, Nierenberg AA, et al. Serum cholesterol in the continuation phase of pharmacotherapy with fluoxetine in remitted major depressive disorder. J Clin Psychopharmacol. 2004;24(4):467-9. [pmid: 15232350].
79 Papakostas GI, Petersen T, Iosifescu DV, Burns AM, Nierenberg AA, Alpert JE, et al. Obesity among outpatients with major depressive disorder. Int J Neuropsychopharmacol. 2005;8(1):59-63. [pmid: 15361263].
80 Perlis RH, Alpert J, Nierenberg AA, Mischoulon D, Yeung A, Rosenbaum JF, et al. Clinical and sociodemographic predictors of response to augmentation, or dose increase among depressed outpatients resistant to fluoxetine 20 mg/day. Acta Psychiatr Scand. 2003;108(6):432-8. [pmid: 14616224].
81 Polsky D, Onesirosan P, Bauer MS, Glick HA. Duration of therapy and health care costs of fluoxetine, paroxetine, and sertraline in 6 health plans. J Clin Psychiatry. 2002;63(2):156-64. [pmid: 11874218].
82 Quitkin FM, Petkova E, McGrath PJ, Taylor B, Beasley C, Stewart J, et al. When should a trial of fluoxetine for major depression be declared failed?. Am J Psychiatry. 2003;160(4):734-40. [pmid: 12668363].
83 Rasanen P, Hakko H, Jokelainen J, Tiihonen J. Outcome of different types of long-term antidepressant treatments: a 3-year follow-up study of 14182 patients. J Affect Disord. 1999;55(1):67-71. [pmid: 10512609].
84 Reimherr FW, Wood DR, Byerley B, Brainard J, Grosser BI. Characteristics of responders to fluoxetine. Psychopharmacol Bull. 1984;20(1):70-2. [pmid: 6371874].
85 Reis M, Aberg-Wistedt A, Agren H, Hoglund P, Akerblad AC, Bengtsson F. Serum disposition of sertraline, N-desmethylsertraline and paroxetine: a pharmacokinetic evaluation of repeated drug concentration measurements during 6 months of treatment for major depression. Hum Psychopharmacol. 2004;19(5):283-91. [pmid: 15252820].
86 Rickels K, Derivan A, Entsuah R, Miska S, Rudolph R. Rapid onset of antidepressant activity with venlafaxine treatment. Depression. 1995;3(3):146-153.
87 Romeo R, Patel A, Knapp M, Thomas C. The cost-effectiveness of mirtazapine versus paroxetine in treating people with depression in primary care. Int Clin Psychopharmacol. 2004;19(3):125-34. [pmid: 15107654].
88 Rosenberg PB, Mielke MM, Lyketsos CG. Caregiver assessment of patients' depression in Alzheimer disease: longitudinal analysis in a drug treatment study. Am J Geriatr Psychiatry. 2005;13(9):822-6. [pmid: 16166413].
89 Rush AJ, Fava M, Wisniewski SR, Lavori PW, Trivedi MH, Sackeim HA, et al. Sequenced treatment alternatives to relieve depression (STAR*D): rationale and design. Control Clin Trials. 2004;25(1):119-42. [pmid: 15061154].
90 Salloway S, Correia S, Boyle P, Malloy P, Schneider L, Lavretsky H, et al. MRI subcortical hyperintensities in old and very old depressed outpatients: the important role of age in late-life depression. J Neurol Sci 2002;203–204:227–33.
91 Salzman C, Jimerson D, Vasile R, Watsky E, Gerber J. Response to SSRI antidepressants correlates with reduction in plasma HVA: pilot study. Biol Psychiatry. 1993;34(8):569-71. [pmid: 8274586].
92 Schins A, Hamulyak K, Scharpe S, Lousberg R, Van Melle J, Crijns H, et al. Whole blood serotonin and platelet activation in depressed post-myocardial infarction patients. Life Sci. 2004;76(6):637-50. [pmid: 15567189].
93 Smajkic A, Weine S, Duric-Bijedic Z, Boskailo E, Lewis J, Pavkovic I. Sertralilne, paroxetine and venlafaxine in refugee post traumatic stress disorder with depression symptoms. Med Arh. 2001;55(1 Suppl 1):35-8. [pmid: 11795192].
94 Small GW, Hamilton SH, Bystritsky A, Meyers BS, Nemeroff CB. Clinical response predictors in a double-blind, placebo-controlled trial of fluoxetine for geriatric major depression. Fluoxetine Collaborative Study Group. Int Psychogeriatr. 1995;7(Suppl):41-53. [pmid: 8580391].
95 Small GW, Schneider LS, Hamilton SH, Bystritsky A, Meyers BS, Nemeroff CB. Site variability in a multisite geriatric depression trial. Journal of Geriatric Psychiatry. 1996;11(12):1089-1095.
96 Smeraldi E, Zanardi R, Benedetti F, Di Bella D, Perez J, Catalano M. Polymorphism within the promoter of the serotonin transporter gene and antidepressant efficacy of fluvoxamine. Mol Psychiatry. 1998;3(6):508-11. [pmid: 9857976].
97 Stain-Malmgren R, Khoury AE, Aberg-Wistedt A, Tham A. Serotonergic function in major depression and effect of sertraline and paroxetine treatment. Int Clin Psychopharmacol. 2001;16(2):93-101. [pmid: 11236074].
98 Stewart JW, Quitkin FM, McGrath PJ, Amsterdam J, Fava M, Fawcett J, et al. Use of pattern analysis to predict differential relapse of remitted patients with major depression during 1 year of treatment with fluoxetine or placebo. Arch Gen Psychiatry. 1998;55(4):334-43. [pmid: 9554429].
99 Strik JJ, Honig A, Lousberg R, Cheriex EC, Van Praag HM. Cardiac side-effects of two selective serotonin reuptake inhibitors in middle-aged and elderly depressed patients. Int Clin Psychopharmacol. 1998;13(6):263-7. [pmid: 9861576].
100 Sullivan MD, Katon WJ, Russo JE, Frank E, Barrett JE, Oxman TE, et al. Patient beliefs predict response to paroxetine among primary care patients with dysthymia and minor depression. J Am Board Fam Pract. 2003;16(1):22-31. [pmid: 12583647].
101 Trivedi MH, Rush AJ, Pan JY, Carmody TJ. Which depressed patients respond to nefazodone and when?. J Clin Psychiatry. 2001;62(3):158-63. [pmid: 11305700].
102 Varner RV, Ruiz P, Small DR. Black and white patients response to antidepressant treatment for major depression. Psychiatr Q. 1998;69(2):117-25. [pmid: 9627929].
103 Yu-Isenberg KS, Fontes CL, Wan GJ, Geissler EC, Harada AS. Acute and continuation treatment adequacy with venlafaxine extended release compared with fluoxetine. Pharmacotherapy. 2004;24(1):33-40. [pmid: 14740786].
104 Zaharia MD, Ravindran AV, Griffiths J, Merali Z, Anisman H. Lymphocyte proliferation among major depressive and dysthymic patients with typical or atypical features. J Affect Disord. 2000;58(1):1-10. [pmid: 10760553].

### Drug Not Included

105 Appelberg BG, Syvalahti EK, Koskinen TE, Mehtonen OP, Muhonen TT, Naukkarinen HH. Patients with severe depression may benefit from buspirone augmentation of selective serotonin reuptake inhibitors: results from a placebo-controlled, randomized, double-blind, placebo wash-in study. J Clin Psychiatry. 2001;62(6):448-52. [pmid: 11465522].
106 Balon R, Yeragani VK, Pohl R, Ramesh C. Sexual dysfunction during antidepressant treatment. J Clin Psychiatry. 1993;54(6):209-12. [pmid: 8331089].
107 Barbosa L, Berk M, Vorster M. A double-blind, randomized, placebo-controlled trial of augmentation with lamotrigine or placebo in patients concomitantly treated with fluoxetine for resistant major depressive episodes. J Clin Psychiatry. 2003;64(4):403-7. [pmid: 12716240].
108 Barge-Schaapveld DQ, Nicolson NA, van der Hoop RG, De Vries MW. Changes in daily life experience associated with clinical improvement in depression. J Affect Disord. 1995;34(2):139-54. [pmid: 7665806].
109 Bascara L. A double-blind study to compare the effectiveness and tolerability of paroxetine and amitriptyline in depressed patients. Acta Psychiatr Scand Suppl. 1989;350:141-2. [pmid: 2530771].
110 Baumann P, Nil R, Souche A, Montaldi S, Baettig D, Lambert S, et al. A double-blind, placebo-controlled study of citalopram with and without lithium in the treatment of therapy-resistant depressive patients: a clinical, pharmacokinetic, and pharmacogenetic investigation. J Clin Psychopharmacol. 1996;16(4):307-14. [pmid: 8835706].
111 Bech P, Allerup P, Gram LF, Kragh-Sorensen P, Rafaelsen OJ, Reisby N, et al. The Diagnostic Melancholia Scale (DMS): dimensions of endogenous and reactive depression with relationship to the Newcastle Scales. J Affect Disord. 1988;14(2):161-70. [pmid: 2966830].
112 Berman RM, Darnell AM, Miller HL, Anand A, Charney DS. Effect of pindolol in hastening response to fluoxetine in the treatment of major depression: a double-blind, placebo-controlled trial. Am J Psychiatry. 1997;154(1):37-43. [pmid: 8988956].
113 Beuzen JN, Ravily VF, Souetre EJ, Thomander L. Impact of fluoxetine on work loss in depression. Int Clin Psychopharmacol. 1993;8(4):319-21. [pmid: 8277155].
114 Bordet R, Thomas P, Dupuis B. Effect of pindolol on onset of action of paroxetine in the treatment of major depression: intermediate analysis of a double-blind, placebo-controlled trial. Reseau de Recherche et d'Experimentation Psychopharmacologique. Am J Psychiatry. 1998;155(10):1346-51. [pmid: 9766765].
115 Brady KT, Lydiard RB, Kellner CH, Joffe R, Laird LK, Morton WA, et al. A comparison of the effects of imipramine and fluvoxamine on the thyroid axis. Biol Psychiatry. 1994;36(11):778-9. [pmid: 7858077].
116 Butters MA, Becker JT, Nebes RD, Zmuda MD, Mulsant BH, Pollock BG, et al. Changes in cognitive functioning following treatment of late-life depression. Am J Psychiatry. 2000;157(12):1949-54. [pmid: 11097959].
117 Byrne MM. Meta-analysis of early phase II studies with paroxetine in hospitalized depressed patients. Acta Psychiatr Scand Suppl. 1989;350:138-9. [pmid: 2530768].
118 Carney PA, Healy D, Leonard BE. A double-blind study to compare trazodone with amitriptyline in depressed patients. Psychopathology. 1984;17(Suppl 2):37-8. [pmid: 6371877].
119 Claghorn JL, Johnstone EE, Studebaker SL, Ajeman SA. The effectiveness of 6-azamianserin (Org 3770) in depressed outpatients. Psychopharmacol Bull. 1987;23(1):160-1. [pmid: 3602313].
120 Clayton AH, Zajecka J, Ferguson JM, Filipiak-Reisner JK, Brown MT, Schwartz GE. Lack of sexual dysfunction with the selective noradrenaline reuptake inhibitor reboxetine during treatment for major depressive disorder. Int Clin Psychopharmacol. 2003;18(3):151-6. [pmid: 12702894].
121 Cohn CK, Shrivastava R, Mendels J, Cohn JB, Fabre LF, Claghorn JL, et al. Double-blind, multicenter comparison of sertraline and amitriptyline in elderly depressed patients. J Clin Psychiatry. 1990;51(Suppl B):28-33. [pmid: 2258379].
122 Coppen A, Bailey J. Enhancement of the antidepressant action of fluoxetine by folic acid: a randomised, placebo controlled trial. J Affect Disord. 2000;60(2):121-30. [pmid: 10967371].
123 Dam J, Ryde L, Svejso J, Lauge N, Lauritsen B, Bech P. Morning fluoxetine plus evening mianserin versus morning fluoxetine plus evening placebo in the acute treatment of major depression. Pharmacopsychiatry. 1998;31(2):48-54. [pmid: 9562208].
124 Dubini A, Bosc M, Polin V. Do noradrenaline and serotonin differentially affect social motivation and behaviour?. Eur Neuropsychopharmacol. 1997;7(Suppl 1):S49-55. discussion S71–3. [pmid: 9169310].
125 Farabaugh A, Mischoulon D, Fava M, Wu SL, Mascarini A, Tossani E, et al. The relationship between early changes in the HAMD-17 anxiety/somatization factor items and treatment outcome among depressed outpatients. Int Clin Psychopharmacol. 2005;20(2):87-91. [pmid: 15729083].
126 Fawcett J, Barkin RL. A meta-analysis of eight randomized, double-blind, controlled clinical trials of mirtazapine for the treatment of patients with major depression and symptoms of anxiety. J Clin Psychiatry. 1998;59(3):123-7. [pmid: 9541155].
127 Ferreri M, Lavergne F, Berlin I, Payan C, Puech AJ. Benefits from mianserin augmentation of fluoxetine in patients with major depression non-responders to fluoxetine alone. Acta Psychiatr Scand. 2001;103(1):66-72. [pmid: 11202131].
128 Flint AJ, Rifat SL. Two-year outcome of elderly patients with anxious depression. Psychiatry Res. 1997;66(1):23-31. [pmid: 9061801].
129 Flint AJ, Rifat SL. Maintenance treatment for recurrent depression in late life. A four-year outcome study. Am J Geriatr Psychiatry. 2000;8(2):112-6. [pmid: 10804071].
130 Ginestet D. Fluoxetine in endogenous depression and melancholia versus clomipramine. Int Clin Psychopharmacol. 1989;4(Suppl 1):37-40. [pmid: 2644338].
131 Green TD, Reynolds CF 3rd, Mulsant BH, Pollock BG, Miller MD, Houck PR, et al. Accelerating antidepressant response in geriatric depression: a post hoc comparison of combined sleep deprivation and paroxetine versus monotherapy with paroxetine, nortriptyline, or placebo. J Geriatr Psychiatry Neurol. 1999;12(2):67-71. [pmid: 10483927].
132 Guillibert E, Pelicier Y, Archambault JC, Chabannes JP, Clerc G, Desvilles M, et al. A double-blind, multicentre study of paroxetine versus clomipramine in depressed elderly patients. Acta Psychiatr Scand Suppl. 1989;350:132-4. [pmid: 2530766].
133 Guy W, Wilson WH, Ban TA, King DL, Manov G, Fjetland OK. A double-blind clinical trial of fluvoxamine and imipramine in patients with primary depression. Psychopharmacol Bull. 1984;20(1):73-8. [pmid: 6425916].
134 Hart S, Fonareva I, Merluzzi N, Mohr DC. Treatment for depression and its relationship to improvement in quality of life and psychological well-being in multiple sclerosis patients. Qual Life Res. 2005;14(3):695-703. [pmid: 16022063].
135 Katona CL, Abou-Saleh MT, Harrison DA, Nairac BA, Edwards DR, Lock T, et al. Placebo-controlled trial of lithium augmentation of fluoxetine and lofepramine. Br J Psychiatry. 1995;166(1):80-6. [pmid: 7894881].
136 Kerr JS, Fairweather DB, Hindmarch I. Effects of fluoxetine on psychomotor performance, cognitive function and sleep in depressed patients. Int Clin Psychopharmacol. 1993;8(4):341-3. [pmid: 8277161].
137 Kopf D, Westphal S, Luley CW, Ritter S, Gilles M, Weber-Hamann B, et al. Lipid metabolism and insulin resistance in depressed patients: significance of weight, hypercortisolism, and antidepressant treatment. J Clin Psychopharmacol. 2004;24(5):527-31. [pmid: 15349009].
138 Levitan RD, Shen JH, Jindal R, Driver HS, Kennedy SH, Shapiro CM. Preliminary randomized double-blind placebo-controlled trial of tryptophan combined with fluoxetine to treat major depressive disorder: antidepressant and hypnotic effects. J Psychiatry Neurosci. 2000;25(4):337-46. [pmid: 11022398]. [pmcid: 1407729].
139 Lewis-Hall FC, Wilson MG, Tepner RG, Koke SC. Fluoxetine vs. tricyclic antidepressants in women with major depressive disorder. J Womens Health. 1997;6(3):337-43. [pmid: 9201668].
140 Licht RW, Qvitzau S. Treatment strategies in patients with major depression not responding to first-line sertraline treatment. A randomised study of extended duration of treatment, dose increase or mianserin augmentation. Psychopharmacology (Berl). 2002;161(2):143-51. [pmid: 11981594].
141 Loonen AJ, Doorschot CH, Oostelbos MC, Sitsen JM. Lack of drug interactions between mirtazapine and risperidone in psychiatric patients: a pilot study. Eur Neuropsychopharmacol. 1999;10(1):51-7. [pmid: 10647097].
142 Mittmann N, Herrmann N, Einarson TR, Busto UE, Lanctot KL, Liu BA, et al. The efficacy, safety and tolerability of antidepressants in late life depression: a meta-analysis. J Affect Disord. 1997;46(3):191-217. [pmid: 9547117].
143 Montgomery SA, Kennedy SH, Burrows GD, Lejoyeux M, Hindmarch I. Absence of discontinuation symptoms with agomelatine and occurrence of discontinuation symptoms with paroxetine: a randomized, double-blind, placebo-controlled discontinuation study. Int Clin Psychopharmacol. 2004;19(5):271-80. [pmid: 15289700].
144 Nathan RS, Perel JM, Pollock BG, Kupfer DJ. The role of neuropharmacologic selectivity in antidepressant action: fluvoxamine versus desipramine. J Clin Psychiatry. 1990;51(9):367-72. [pmid: 2120201].
145 Nelson JC, Mazure CM, Jatlow PI, Bowers MB Jr, Price LH. Combining norepinephrine and serotonin reuptake inhibition mechanisms for treatment of depression: a double-blind, randomized study. Biol Psychiatry. 2004;55(3):296-300. [pmid: 14744472].
146 Normann C, Hummel B, Scharer LO, Horn M, Grunze H, Walden J. Lamotrigine as adjunct to paroxetine in acute depression: a placebo-controlled, double-blind study. J Clin Psychiatry. 2002;63(4):337-44. [pmid: 12000208].
147 Nowak G, Siwek M, Dudek D, Zieba A, Pilc A. Effect of zinc supplementation on antidepressant therapy in unipolar depression: a preliminary placebo-controlled study. Pol J Pharmacol. 2003;55(6):1143-7. [pmid: 14730113].
148 Onder E, Tural U. Faster response in depressive patients treated with fluoxetine alone than in combination with buspirone. J Affect Disord. 2003;76(13):223-7. [pmid: 12943952].
149 Oslin DW. Treatment of late-life depression complicated by alcohol dependence. Am J Geriatr Psychiatry. 2005;13(6):491-500. [pmid: 15956269].
150 Otero FJ, Hernandez HC, Martinez AMJ, Garrido J, Armenteros S, J V. Fluoxetine/bentazepam combination in the treatment of dysthymic disorders. Ther Res Clin Exp. 1994;55(5):519-531.
151 Perry EB, Berman RM, Sanacora G, Anand A, Lynch-Colonese K, Charney DS. Pindolol augmentation in depressed patients resistant to selective serotonin reuptake inhibitors: a double-blind, randomized, controlled trial. J Clin Psychiatry. 2004;65(2):238-43. [pmid: 15003079].
152 Poelinger W, Haber H. Fluoxetine 40 mg vs maprotiline 75 mg in the treatment of out-patients with depressive disorders. Int Clin Psychopharmacol. 1989;4(Suppl 1):47-50. [pmid: 2644340].
153 Pohl R, Balon R, Jayaraman A, Doll RG, Yeragani V. Effect of fluoxetine, pemoline and placebo on heart period and QT variability in normal humans. J Psychosom Res. 2003;55(3):247-51. [pmid: 12932798].
154 Ramaekers JG, Ansseau M, Muntjewerff ND, Sweens JP, O'Hanlon JF. Considering the P450 cytochrome system as determining combined effects of antidepressants and benzodiazepines on actual driving performance of depressed outpatients. Int Clin Psychopharmacol. 1997;12(3):159-69. [pmid: 9248873].
155 Reynolds CF 3rd, Frank E, Perel JM, Mazumdar S, Dew MA, Begley A, et al. High relapse rate after discontinuation of adjunctive medication for elderly patients with recurrent major depression. Am J Psychiatry. 1996;153(11):1418-22. [pmid: 8890674].
156 Roberts RL, Mulder RT, Joyce PR, Luty SE, Kennedy MA. No evidence of increased adverse drug reactions in cytochrome P450 CYP2D6 poor metabolizers treated with fluoxetine or nortriptyline. Hum Psychopharmacol. 2004;19(1):17-23. [pmid: 14716707].
157 Rocca P, Marchiaro L, Rasetti R, Rivoira E, Bogetto F. A comparison of paroxetine versus paroxetine plus amisulpride in the treatment of dysthymic disorder: efficacy and psychosocial outcomes. Psychiatry Res. 2002;112(2):145-52. [pmid: 12429360].
158 Roose SP, Glassman AH, Attia E, Woodring S, Giardina EG, Bigger JT Jr. Cardiovascular effects of fluoxetine in depressed patients with heart disease. Am J Psychiatry. 1998;155(5):660-5. [pmid: 9585718].
159 Sanacora G, Berman RM, Cappiello A, Oren DA, Kugaya A, Liu N, et al. Addition of the alpha2-antagonist yohimbine to fluoxetine: effects on rate of antidepressant response. Neuropsychopharmacology. 2004;29(6):1166-71. [pmid: 15010697].
160 Scardigli G, Jans G. Comparative double-blind study on efficacy and side-effects of trazodone, nomifensine, mianserin in elderly patients. Adv Biochem Psychopharmacol. 1982;32:229-36. [pmid: 7046366].
161 Scharf MB, Sachais BA. Sleep laboratory evaluation of the effects and efficacy of trazodone in depressed insomniac patients. J Clin Psychiatry. 1990;51(Suppl):13-7. [pmid: 2211559].
162 Schneider LS, Small GW, Hamilton SH, Bystritsky A, Nemeroff CB, Meyers BS. Estrogen replacement and response to fluoxetine in a multicenter geriatric depression trial. Fluoxetine Collaborative Study Group. Am J Geriatr Psychiatry. 1997;5(2):97-106. [pmid: 9106373].
163 Segraves RT. Psychiatric drugs and inhibited female orgasm. J Sex Marital Ther. 1988;14(3):202-7. [pmid: 2902230].
164 Smith WT, Londborg PD, Glaudin V, Painter JR. Short-term augmentation of fluoxetine with clonazepam in the treatment of depression: a double-blind study. Am J Psychiatry. 1998;155(10):1339-45. [pmid: 9766764].
165 Smith WT, Londborg PD, Glaudin V, Painter JR. Is extended clonazepam cotherapy of fluoxetine effective for outpatients with major depression?. J Affect Disord. 2002;70(3):251-9. [pmid: 12128237].
166 Solai LK, Mulsant BH, Pollock BG, Sweet RA, Rosen J, Yu K, et al. Effect of sertraline on plasma nortriptyline levels in depressed elderly. J Clin Psychiatry. 1997;58(10):440-3. [pmid: 9375595].
167 Stahl S, Zivkov M, Reimitz PE, Panagides J, Hoff W. Meta-analysis of randomized, double-blind, placebo-controlled, efficacy and safety studies of mirtazapine versus amitriptyline in major depression. Acta Psychiatr Scand Suppl. 1997;391:22-30. [pmid: 9265948].
168 Stein MD, Solomon DA, Anderson BJ, Herman DS, Anthony JL, Brown RA, et al. Persistence of antidepressant treatment effects in a pharmacotherapy plus psychotherapy trial for active injection drug users. Am J Addict. 2005;14(4):346-57. [pmid: 16188715].
169 Stratta P, Bolino F, Cupillari M, Casacchia M. A double-blind parallel study comparing fluoxetine with imipramine in the treatment of atypical depression. Int Clin Psychopharmacol. 1991;6(3):193-6. [pmid: 1806625].
170 Taragano FE, Bagnatti P, Allegri RF. A double-blind, randomized clinical trial to assess the augmentation with nimodipine of antidepressant therapy in the treatment of “vascular depression”. Int Psychogeriatr. 2005;17(3):487-98. [pmid: 16252380].
171 Taylor MJ, Carney SM, Goodwin GM, Geddes JR. Folate for depressive disorders: systematic review and meta-analysis of randomized controlled trials. J Psychopharmacol. 2004;18(2):251-6. [pmid: 15260915].
172 Taylor MJ, Rudkin L, Hawton K. Strategies for managing antidepressant-induced sexual dysfunction: Systematic review of randomised controlled trials. J Affect Disord 2005.
173 van de Merwe TJ, Silverstone T, Ankier SI, Warrington SJ, Turner P. A double-blind non-crossover placebo-controlled study between group comparison of trazodone and amitriptyline on cardiovascular function in major depressive disorder. Psychopathology. 1984;17(Suppl 2):64-76. [pmid: 6371879].
174 Wagner GJ, Rabkin JG, Rabkin R. A comparative analysis of standard and alternative antidepressants in the treatment of human immunodeficiency virus patients. Compr Psychiatry. 1996;37(6):402-8. [pmid: 8932964].
175 Weigmann H, Gerek S, Zeisig A, Muller M, Hartter S, Hiemke C. Fluvoxamine but not sertraline inhibits the metabolism of olanzapine: evidence from a therapeutic drug monitoring service. Ther Drug Monit. 2001;23(4):410-3. [pmid: 11477325].

### Population Not Included

176 Agosti V, McGrath PJ. Comparison of the effects of fluoxetine, imipramine and placebo on personality in atypical depression. J Affect Disord. 2002;71(13):113-20. [pmid: 12167507].
177 Amsterdam JD, Shults J. Fluoxetine monotherapy of bipolar type II and bipolar NOS major depression: a double-blind, placebo-substitution, continuation study. Int Clin Psychopharmacol. 2005;20(5):257-64. [pmid: 16096516].
178 Bakish D, Cavazzoni P, Chudzik J, Ravindran A, Hrdina PD. Effects of selective serotonin reuptake inhibitors on platelet serotonin parameters in major depressive disorder. Biol Psychiatry. 1997;41(2):184-90. [pmid: 9018388].
179 Black DW, Wesner R, Gabel J. The abrupt discontinuation of fluvoxamine in patients with panic disorder. J Clin Psychiatry. 1993;54(4):146-9. [pmid: 8486592].
180 Clayton AH, Stewart RS, Fayyad R, Clary CM. Sex differences in clinical presentation and response in panic disorder: pooled data from sertraline treatment studies. Arch Women Ment Health 2005.
181 Cohn JB, Wilcox C. A comparison of fluoxetine, imipramine, and placebo in patients with major depressive disorder. J Clin Psychiatry. 1985;46(3 Pt 2):26-31. [pmid: 3882677].
182 Cox LS, Patten CA, Niaura RS, Decker PA, Rigotti N, Sachs DP, et al. Efficacy of bupropion for relapse prevention in smokers with and without a past history of major depression. J Gen Intern Med. 2004;19(8):828-34. [pmid: 15242467]. [pmcid: 1492503].
183 Evans ME. Depression in elderly physically ill in-patients: a 12-month prospective study. Int Clin Psychopharmacol. 1993;8(4):333-6. [pmid: 8277159].
184 Fieve RR, Goodnick PJ, Peselow E, Schlegel A. Fluoxetine response: endpoint vs pattern analysis. Int Clin Psychopharmacol. 1986;1(4):320-3. [pmid: 3549877].
185 Goldberg HL, Finnerty RJ. Trazodone in the treatment of neurotic depression. J Clin Psychiatry. 1980;41(12 Pt 1):430-4. [pmid: 7440519].
186 Goodman WK, Price LH, Delgado PL, Palumbo J, Krystal JH, Nagy LM, et al. Specificity of serotonin reuptake inhibitors in the treatment of obsessive-compulsive disorder. Comparison of fluvoxamine and desipramine. Arch Gen Psychiatry. 1990;47(6):577-85. [pmid: 2112374].
187 Lenox-Smith AJ, Reynolds A. A double-blind, randomised, placebo controlled study of venlafaxine XL in patients with generalised anxiety disorder in primary care. Br J Gen Pract. 2003;53(495):772-7. [pmid: 14601352]. [pmcid: 1314709].
188 Leon AC, Keller MB, Warshaw MG, Mueller TI, Solomon DA, Coryell W, et al. Prospective study of fluoxetine treatment and suicidal behavior in affectively ill subjects. Am J Psychiatry. 1999;156(2):195-201. [pmid: 9989554].
189 Lepola UM, Wade AG, Leinonen EV, Koponen HJ, Frazer J, Sjodin I, et al. A controlled, prospective, 1-year trial of citalopram in the treatment of panic disorder. J Clin Psychiatry. 1998;59(10):528-34. [pmid: 9818634].
190 Martiny K, Lunde M, Simonsen C, Clemmensen L, Poulsen DL, Solstad K, et al. Relapse prevention by citalopram in SAD patients responding to 1 week of light therapy. A placebo-controlled study. Acta Psychiatr Scand. 2004;109(3):230-4. [pmid: 14984396].
191 Menkes DB, Taghavi E, Mason PA, Howard RC. Fluoxetine's spectrum of action in premenstrual syndrome. Int Clin Psychopharmacol. 1993;8(2):95-102. [pmid: 8345163].
192 Modell JG, Rosenthal NE, Harriett AE, Krishen A, Asgharian A, Foster VJ, et al. Seasonal affective disorder and its prevention by anticipatory treatment with bupropion XL. Biol Psychiatry. 2005;58(8):658-67. [pmid: 16271314].
193 Moscovitch A, Blashko CA, Eagles JM, Darcourt G, Thompson C, Kasper S, et al. A placebo-controlled study of sertraline in the treatment of outpatients with seasonal affective disorder. Psychopharmacology (Berl). 2004;171(4):390-7. [pmid: 14504682].
194 Narushima K, Kosier JT, Robinson RG. Preventing poststroke depression: a 12-week double-blind randomized treatment trial and 21-month follow-up. J Nerv Ment Dis. 2002;190(5):296-303. [pmid: 12011609].
195 Roy-Byrne PP, Perera P, Pitts CD, Christi JA. Paroxetine response and tolerability among ethnic minority patients with mood or anxiety disorders: a pooled analysis. J Clin Psychiatry. 2005;66(10):1228-33. [pmid: 16259535].
196 Soares CN, Poitras JR, Prouty J, Alexander AB, Shifren JL, Cohen LS. Efficacy of citalopram as a monotherapy or as an adjunctive treatment to estrogen therapy for perimenopausal and postmenopausal women with depression and vasomotor symptoms. J Clin Psychiatry. 2003;64(4):473-9. [pmid: 12716252].
197 Waters CH. Fluoxetine and selegiline—lack of significant interaction. Can J Neurol Sci. 1994;21(3):259-61. [pmid: 8000982].
198 Zanardi R, Franchini L, Serretti A, Perez J, Smeraldi E. Venlafaxine versus fluvoxamine in the treatment of delusional depression: a pilot double-blind controlled study. J Clin Psychiatry. 2000;61(1):26-9. [pmid: 10695642].

### Wrong Publication Type

199 Novel selective serotonin reuptake inhibitors, Part II. J Clin Psychiatry 1992;53(6):216–21.
200 Safety and efficacy of paroxetine in elderly patients. Geriatrics 1993;48 Suppl 2:13–5.
201 SSRIs: Prozac and company - part II. Harv Ment Health Lett 2000;17(5):1–3.
202 The brain tells: early signs of depression recovery. Harv Ment Health Lett 2002;19(5):6.
203 Abraham G. Massive weight gain and hostility force mirtazapine stoppage. Can J Psychiatry. 2002;47(6):582. [pmid: 12211888].
204 Albert R, Ebert D. Full efficacy of SSRI treatment in refractory dysthymia is achieved only after 16 weeks. J Clin Psychiatry. 1996;57(4):176. [pmid: 8601556].
205 Alevizos B, Vaidakis N, Alevizos E. Increased libido with the combined use of venlafaxine and mirtazapine. J Clin Psychopharmacol. 2005;25(2):194-6. [pmid: 15738758].
206 Alonso M, Val E, Rapaport MH. An open-label study of SSRI treatment in depressed hispanic and non-Hispanic women. J Clin Psychiatry. 1997;58(1):31. [pmid: 9055837].
207 Altshuler LL. Fluoxetine-associated panic attacks. J Clin Psychopharmacol. 1994;14(6):433-4. [pmid: 7884030].
208 Altshuler LL, Pierre JM, Wirshing WC, Ames D. Sertraline and akathisia. J Clin Psychopharmacol. 1994;14(4):278-9. [pmid: 7962686].
209 Anghelescu I, Klawe C, Dahmen N. Venlafaxine in a patient with idiopathic leukopenia and mirtazapine-induced severe neutropenia. J Clin Psychiatry. 2002;63(9):838. [pmid: 12363126].
210 Artigas F, Perez V, Alvarez E. Pindolol induces a rapid improvement of depressed patients treated with serotonin reuptake inhibitors. Arch Gen Psychiatry. 1994;51(3):248-51. [pmid: 8122960].
211 Ashleigh EA, Fesler FA. Fluoxetine and suicidal preoccupation. Am J Psychiatry. 1992;149(12):1750. [pmid: 1443254].
212 Ashton AK. Lack of desipramine toxicity with citalopram. J Clin Psychiatry. 2000;61(2):144. [pmid: 10732663].
213 Avorn J. Depression in the elderly—falls and pitfalls. N Engl J Med. 1998;339(13):918-20. [pmid: 9744979].
214 Bauer M, Hellweg R, Baumgartner A. Fluoxetine-induced akathisia does not reappear after switch to paroxetine. J Clin Psychiatry. 1996;57(12):593-4. [pmid: 9010125].
215 Benazzi F. Urinary retention with fluoxetine-haloperidol combination in a young patient. Can J Psychiatry. 1996;41(9):606-7. [pmid: 8946091].
216 Benazzi F. Severe anticholinergic side effects with venlafaxine-fluoxetine combination. Can J Psychiatry. 1997;42(9):980-1. [pmid: 9429070].
217 Benazzi F. Venlafaxine-fluoxetine-nortriptyline interaction. J Psychiatry Neurosci. 1997;22(4):278-9. [pmid: 9262050]. [pmcid: 1188872].
218 Benazzi F. Venlafaxine drug-drug interactions in clinical practice. J Psychiatry Neurosci. 1998;23(3):181-2. [pmid: 9595894]. [pmcid: 1188927].
219 Benazzi F. Venlafaxine-fluoxetine interaction. J Clin Psychopharmacol. 1999;19(1):96-8. [pmid: 9934950].
220 Benazzi F. Fluoxetine and olanzapine for resistant depression. American Journal of Psychiatry. 2002;159(1):155-6. [pmid: 11772722].
221 Benazzi F. Hemorrhages during escitalopram-venlafaxine-mirtazapine combination treatment of depression. Can J Psychiatry. 2005;50(3):184. [pmid: 15830829].
222 Bhanji NH. Serotonin syndrome following low-dose sertraline. Can J Psychiatry. 2000;45(10):936-7. [pmid: 11190366].
223 Bolukbasi O, Akyol A. Spontaneous erections and libido increase associated with venlafaxine. Eur J Neurol. 1999;6(4):527-8. [pmid: 10362913].
224 Bouman WP, Johnson H, Trescoli-Serrano C, Jones RG. Recurrent hyponatremia associated with sertraline and lofepramine. Am J Psychiatry. 1997;154(4):580. [pmid: 9090354].
225 Bourgeois JA. Reversible hyponatremia and venlafaxine. Psychosomatics. 2005;46(5):495-6. [pmid: 16145194].
226 Browne JL, Rice JL, Evans DL, Prange AJ. Triiodothyronine augmentation of the antidepressant effect of the nontricyclic antidepressant trazodone. J Nerv Ment Dis. 1990;178(9):598-9. [pmid: 2394983].
227 Buni TM. Treatment of dysthymia. J Fam Pract. 1997;44(6):528-9. [pmid: 9191617].
228 Burrai C, Bocchetta A, del Zompo M. Mania and fluvoxamine. Am J Psychiatry. 1991;148(9):1263-4. [pmid: 1909099].
229 Bushell I, Newton W. SSRI or tricyclics for depression?. J Fam Pract. 1996;43(4):345-6. [pmid: 8874367].
230 Carroll BJ. Sertraline and the Cheshire cat in geriatric depression. Am J Psychiatry. 2004;161(6):1145-6. [pmid: 15169734].
231 Carroll BJ. Citalopram and the Curate's egg in geriatric depression. Am J Psychiatry. 2005;162(9):1762. author reply 1762–3. [pmid: 16135653].
232 Chelben J, Strous RD, Lustig M, Baruch Y. Remission of SSRI-induced akathisia after switch to nefazodone. J Clin Psychiatry. 2001;62(7):570-1. [pmid: 11488371].
233 Christensen RC. Adverse interaction of paroxetine and cyproheptadine. J Clin Psychiatry. 1995;56(9):433-4. [pmid: 7665546].
234 Cohen BJ, Mahelsky M, Adler L. More cases of SIADH with fluoxetine. Am J Psychiatry. 1990;147(7):948-9. [pmid: 2356883].
235 Coplan JD, Gorman JM. Detectable levels of fluoxetine metabolites after discontinuation: an unexpected serotonin syndrome. Am J Psychiatry. 1993;150(5):837. [pmid: 8480837].
236 Cornelius JR, Bukstein OG, Salloum IM, Kelly TM, Wood DS, Clark DB. Fluoxetine in depressed AUD adolescents: a 1-year follow-up evaluation. J Child Adolesc Psychopharmacol. 2004;14(1):33-8. [pmid: 15142389].
237 Crews JR, Potts NL, Schreiber J, Lipper S. Hyponatremia in a patient treated with sertraline. Am J Psychiatry. 1993;150(10):1564. [pmid: 8379571].
238 Crowe D, Collins JP, Rosse RB. Thyroid hormone supplementation of fluoxetine treatment. J Clin Psychopharmacol. 1990;10(2):150-1. [pmid: 2341594].
239 de Jong J, Hoogenboom B, van Troostwijk LD, de Haan L. Interaction of olanzapine with fluvoxamine. Psychopharmacology (Berl). 2001;155(2):219-20. [pmid: 11401013].
240 DeVane CL, Markowitz JS, Hardesty SJ, Mundy S, Gill HS. Fluvoxamine-induced theophylline toxicity. Am J Psychiatry. 1997;154(9):1317-8. [pmid: 9286199].
241 Devarajan S. Interaction of fluoxetine and chloral hydrate. Can J Psychiatry. 1992;37(8):590-1. [pmid: 1423165].
242 Divinsky M. A clinical dilemma. Can Fam Physician. 1996;42:406. [pmid: 8616279].
243 D'Mello DA, Meland R, Ransom S. Nefazodone and hypotension: complication or coincidence. J Clin Psychopharmacol. 1997;17(2):136. [pmid: 10950489].
244 Droulers A, Bodak N, Oudjhani M, Lefevre des Noettes V, Bodak A. Decrease of valproic acid concentration in the blood when coprescribed with fluoxetine. J Clin Psychopharmacol. 1997;17(2):139-40. [pmid: 10950492].
245 Duggal HS, Fetchko J. Serotonin syndrome and atypical antipsychotics. Am J Psychiatry. 2002;159(4):672-3. [pmid: 11925312].
246 Entsuah R, Derivan A, Kikta D. Early onset of antidepressant action of venlafaxine: pattern analysis in intent-to-treat patients. Clin Ther. 1998;20(3):517-26. [pmid: 9663367].
247 Extein IL. Recent fluoxetine treatment and complications of tricyclic therapy. Am J Psychiatry. 1991;148(11):1601-2. [pmid: 1928480].
248 Fava GA, Ruini C, Sonino N. Management of recurrent depression in primary care. Psychother Psychosom. 2003;72(1):3-9. [pmid: 12466632].
249 Fichtner CG, Jobe TH, Braun BG. Does fluoxetine have a therapeutic window?. Lancet. 1991;338(8765):520-1. [pmid: 1678484].
250 Finfgeld DL. SSRI-related hyponatremia among aging adults. J Psychosoc Nurs Ment Health Serv. 2003;41(4):12-6. [pmid: 12698818].
251 Finnegan KT, Gabiola JM. Fluoxetine overdose. Am J Psychiatry. 1988;145(12):1604. [pmid: 3264119].
252 Fisfalen ME, Hsiung RC. Glucose dysregulation and mirtazapine-induced weight gain. Am J Psychiatry. 2003;160(4):797. [pmid: 12668379].
253 Flint AJ, Crosby J, Genik JL. Recurrent hyponatremia associated with fluoxetine and paroxetine. Am J Psychiatry. 1996;153(1):134. [pmid: 8540575].
254 Franco K, Malhotra S. Poststroke depression. Am J Psychiatry. 2001;158(4):658-60. [pmid: 11282720].
255 Gagiano CA, Muller PG, Fourie J, Le Roux JF. The therapeutic efficacy of paroxetine: (a) an open study in patients with major depression not responding to antidepressants; (b) a double-blind comparison with amitriptyline in depressed outpatients. Acta Psychiatr Scand Suppl. 1989;350:130-1. [pmid: 2530765].
256 Goldberg JF, Sacks MH, Kocsis JH. Attenuation of response to serotonin reuptake inhibitors. Am J Psychiatry. 1995;152(6):954. [pmid: 7755133].
257 Goldstein L, Barker M, Segall F, Asihene R, Balser S, Lautenbach D, et al. Seizure and transient SIADH associated with sertraline. Am J Psychiatry. 1996;153(5):732. [pmid: 8615425].
258 Gonzalez-Pinto A, Imaz H, De Heredia JL, Gutierrez M, Mico JA. Mania and tramadol-fluoxetine combination. Am J Psychiatry. 2001;158(6):964-5. [pmid: 11384912].
259 Gupta S, Major LF. Hair loss associated with fluoxetine. Br J Psychiatry. 1991;159:737-8. [pmid: 1756373].
260 Gupta S, Ghaly N, Dewan M. Augmenting fluoxetine with dextroamphetamine to treat refractory depression. Hosp Community Psychiatry. 1992;43(3):281-3. [pmid: 1555827].
261 Gupta AK, Saravay SM. Venlafaxine-induced hyponatremia. J Clin Psychopharmacol. 1997;17(3):223-5. [pmid: 9169969].
262 Hargrave R, Martinez D, Bernstein AJ. Fluoxetine-induced seizures. Psychosomatics. 1992;33(2):236-9. [pmid: 1557494].
263 Hendrick V, Altshuler L. Management of major depression during pregnancy. Am J Psychiatry. 2002;159(10):1667-73. [pmid: 12359670].
264 Hirschfeld RM. Efficacy of SSRIs and newer antidepressants in severe depression: comparison with TCAs. J Clin Psychiatry. 1999;60(5):326-35. [pmid: 10362442].
265 Hollister LE, Krajewski K, Rustin T, Gillespie H. Drugs for cocaine dependence: not easy. Arch Gen Psychiatry. 1992;49(11):905-6. [pmid: 1444730].
266 Hon D, Preskorn SH. Mania during fluoxetine treatment for recurrent depression. Am J Psychiatry. 1989;146(12):1638-9. [pmid: 2589562].
267 Hwang JP, Yang CH, Tsai SJ. Comparison study of venlafaxine and paroxetine for the treatment of depression in elderly Chinese inpatients. Int J Geriatr Psychiatry. 2004;19(2):189-90. [pmid: 14758586].
268 Isaac MT, Tome MB. Pindolol-paroxetine combination. Am J Psychiatry. 1997;154(12):1790-1. [pmid: 9396965].
269 Isaac MT, Tome MB. Selective serotonin reuptake inhibitors plus pindolol. Lancet. 1997;350(9073):288-9. [pmid: 9242815].
270 Jarvik LF. Trazodone for treatment of older depressed patients: comment. J Clin Psychopharmacol. 1988;8(6):449-50. [pmid: 3069883].
271 Jerome L. Bupropion and drug-induced parkinsonism. Can J Psychiatry. 2001;46(6):560-1. [pmid: 11526815].
272 Kaneda Y, Ohmori T, Okabe H. Possible mild serotonin syndrome related to co-prescription of tandospirone and trazodone. Gen Hosp Psychiatry. 2001;23(2):98-101. [pmid: 11354048].
273 Karnik NS, Maldonado JR. Antidepressant and statin interactions: a review and case report of simvastatin and nefazodone-induced rhabdomyolysis and transaminitis. Psychosomatics. 2005;46(6):565-8. [pmid: 16288136].
274 Kaufeler R, Meier B, Brattstrom A. Efficacy and tolerability of Ze 117 St. John's wort extract in comparison with placebo, imipramine and fluoxetine for the treatment of mild to moderate depression according to ICD-10. An overview. Pharmacopsychiatry. 2001;34(Suppl 1):S49-50. [pmid: 11518076].
275 Keller MB. Citalopram therapy for depression: a review of 10 years of European experience and data from U.S. clinical trials. J Clin Psychiatry. 2000;61(12):896-908. [pmid: 11206593].
276 Kellett JM. Fluvoxamine: an antidepressant for the elderly?. J Psychiatry Neurosci. 1991;16(2 Suppl 1):26-9. [pmid: 1931933]. [pmcid: 1188309].
277 Khan A, Shad MU, Preskorn SH. Lack of sertraline efficacy probably due to an interaction with carbamazepine. J Clin Psychiatry. 2000;61(7):526-7. [pmid: 10937612].
278 Kirsch MA, Louie AK. Paroxetine and irritable bowel syndrome. Am J Psychiatry. 2000;157(9):1523-4. [pmid: 10964877].
279 Kumar S. Prophylaxis of depression in older people. Br J Psychiatry. 2003;183:365. author reply 365. [pmid: 14519617].
280 Labbate LA. Bupropion-SR-induced increased libido and spontaneous orgasm. Can J Psychiatry. 1998;43(6):644-5. [pmid: 9729695].
281 Lanes T, Ravaris CL. Prolonged ECT seizure duration in a patient taking trazodone. Am J Psychiatry. 1993;150(3):525. [pmid: 8434678].
282 Langlois RP, Paquette D. Sustained bradycardia during fluvoxamine and buspirone intoxication. Can J Psychiatry. 1994;39(2):126-7. [pmid: 8149317].
283 Lapierre YD. Controlling acute episodes of depression. Int Clin Psychopharmacol. 1991;6(Suppl 2):23-35. [pmid: 1806627].
284 Leentjens AF, Vreeling FW, Luijckx GJ, Verhey FR. SSRIs in the treatment of depression in Parkinson's disease. Int J Geriatr Psychiatry. 2003;18(6):552-4. [pmid: 12789682].
285 Lefkowitz D, Kilgo G, Lee S. Seizures and trazodone therapy. Arch Gen Psychiatry. 1985;42(5):523. [pmid: 3985762].
286 Leroi I, Walentynowicz MA. Fluoxetine-imipramine interaction. Can J Psychiatry. 1996;41(5):318-9. [pmid: 8793156].
287 Leung M, Remick R. Sertraline-associated hyponatremia. Can J Psychiatry. 1995;40(8):497-8. [pmid: 8681276].
288 Levsky ME, Schwartz JB. Sertraline-induced hyponatremia in an older patient. J Am Geriatr Soc. 1998;46(12):1582-3. [pmid: 9848826].
289 Linet LS. Treatment of a refractory depression with a combination of fluoxetine and d-amphetamine. Am J Psychiatry. 1989;146(6):803-4. [pmid: 2786343].
290 Liu CY, Yang YY, Wang SJ, Fuh JL, Liu HC. Fluoxetine-related suicidality and muscle aches in a patient with poststroke depression. J Clin Psychopharmacol. 1996;16(6):466-7. [pmid: 8959479].
291 Lock JD, Gwirtsman HE, Targ EF. Possible adverse drug interactions between fluoxetine and other psychotropics. J Clin Psychopharmacol. 1990;10(5):383-4. [pmid: 2258459].
292 Lucena MI, Blanco E, Corrales MA, Berthier ML. Interaction of fluoxetine and valproic acid. Am J Psychiatry. 1998;155(4):575. [pmid: 9546010].
293 Lydiard RB, Anton RF, Cunningham T. Interactions between sertraline and tricyclic antidepressants. Am J Psychiatry. 1993;150(7):1125-6. [pmid: 8317590].
294 Malek-Ahmadi P, Allen SA. Paroxetine-molindone interaction. J Clin Psychiatry. 1995;56(2):82-3. [pmid: 7852260].
295 Marsland TW, Newton W. Are there differences by gender in response to pharmacotherapy for depression?. J Fam Pract. 2000;49(12):1149. [pmid: 11132066].
296 Masand P, Gupta S, Dewan M. Suicidal ideation related to fluoxetine treatment. N Engl J Med. 1991;324(6):420. [pmid: 1987466].
297 McCue RE, Joseph M. Venlafaxine- and trazodone-induced serotonin syndrome. Am J Psychiatry. 2001;158(12):2088-9. [pmid: 11729039].
298 McIntosh D. A mild case of serotonin syndrome?. Can J Psychiatry. 2000;45(6):571-2. [pmid: 10986578].
299 Michael A, Owen A. Venlafaxine-induced increased libido and spontaneous erections. Br J Psychiatry. 1997;170:193. [pmid: 9093519].
300 Mirassou MM. Rectal antidepressant medication in the treatment of depression. J Clin Psychiatry. 1998;59(1):29. [pmid: 9491063].
301 Mizoguchi Y, Monji A. Low-dose-trazodone-induced disorganized type psychosis. J Neuropsychiatry Clin Neurosci. 2005;17(2):253-4. [pmid: 15939985].
302 Moss JH. A novel placebo lead-in behavior strategy for sertraline dosing in a depressed patient highly sensitive to medication side effects. J Clin Psychiatry. 1997;58(9):405-6. [pmid: 9378695].
303 Moustgaard G. Treatment-refractory depression successfully treated with the combination of mirtazapine and lithium. J Clin Psychopharmacol. 2000;20(2):268. [pmid: 10770470].
304 Noveske FG, Hahn KR, Flynn RJ. Possible toxicity of combined fluoxetine and lithium. Am J Psychiatry. 1989;146(11):1515. [pmid: 2510522].
305 Okada F, Okajima K. Increased sexual desire during fluvoxamine treatment. Can J Psychiatry. 2000;45(8):762-3. [pmid: 11086562].
306 Olivera AO. Sertraline and akathisia: spontaneous resolution. Biol Psychiatry. 1997;41(2):241-2. [pmid: 9018398].
307 Panzer PG, Fullilove MT. Belinda's puzzle: assembling the pieces of an illness. Am J Psychiatry. 1997;154(5):677-80. [pmid: 9137125].
308 Paton C, Ferrier IN. SSRIs and gastrointestinal bleeding. Bmj. 2005;331(7516):529-30. [pmid: 16150746]. [pmcid: 1200576].
309 Pearson HJ. Interaction of fluoxetine with carbamazepine. J Clin Psychiatry. 1990;51(3):126. [pmid: 2353956].
310 Pinkofsky HB, Stone KD, Reeves RR. Serotonin, cigarettes, and nausea. J Clin Psychopharmacol. 1997;17(6):492. [pmid: 9408816].
311 Postolache TT, Rosenthal RN, Hellerstein DJ, Aromin R, Kelton GM, Muran JC, et al. Early augmentation of sertraline with methylphenidate. J Clin Psychiatry. 1999;60(2):123-4. [pmid: 10084641].
312 Purdon SE, Snaterse M. Selective serotonin reuptake inhibitor modulation of clozapine effects on cognition in schizophrenia. Can J Psychiatry. 1998;43(1):84-5. [pmid: 9494753].
313 Rajagopalan M. Comparison of venlafaxine and imipramine in depressive illness. Acta Psychiatr Scand. 1998;97(5):384-5. [pmid: 9611090].
314 Ramasubbu R. Minor strokes related to paroxetine discontinuation in an elderly subject: emergent adverse events. Can J Psychiatry. 2003;48(4):281-2. [pmid: 12776398].
315 Ratan DA. Fluoxetine and suicidal ideation. J Clin Psychopharmacol. 1997;17(1):61-2. [pmid: 9004066].
316 Reed SM, Glick JW. Fluoxetine and reactivation of the herpes simplex virus. Am J Psychiatry. 1991;148(7):949-50. [pmid: 1647143].
317 Roose SP. Tolerability and patient compliance. J Clin Psychiatry. 1999;60(Suppl 17):14-7. discussion 46–8. [pmid: 10446736].
318 Ropert R. Fluoxetine versus clomipramine in major depressive disorders. Int Clin Psychopharmacol. 1989;4(Suppl 1):89-95. [pmid: 2644343].
319 Saraf M, Schrader G. Seizure associated with sertraline. Aust N Z J Psychiatry. 1999;33(6):944-5. [pmid: 10619229].
320 Schouten WE, Sepers JM. Hyponatraemia associated with the use of a selective serotonin-reuptake inhibitor in an older patient. Age Ageing. 2001;30(1):94. [pmid: 11322690].
321 Schraml F, Benedetti G, Hoyle K, Clayton A. Fluoxetine and nortriptyline combination therapy. Am J Psychiatry. 1989;146(12):1636-7. [pmid: 2589560].
322 Segraves RT, Segraves KB, Bubna CN. Sexual function in patients taking bupropion sustained release. J Clin Psychiatry. 1995;56(8):374. [pmid: 7635855].
323 Selzer JA. Fluoxetine, suicidal ideation, and aggressive behavior. Am J Psychiatry. 1992;149(5):708-9. [pmid: 1575263].
324 Settle EC Jr. Akathisia and sertraline. J Clin Psychiatry. 1993;54(8):321. [pmid: 8253701].
325 Shad MU, Harvey AT, Lucot JB. A possible pharmacokinetic interaction between fluoxetine and acetylsalicylic acid. J Clin Psychiatry. 1997;58(12):549-50. [pmid: 9448661].
326 Shader RI, Oesterheld JR. Case 2: Dizzy Giuseppi or the vertiginous virtuoso. J Clin Psychopharmacol. 1994;14(6):437. [pmid: 7884033].
327 Shang CY, Soong WT, Lin HN. Hypokalemia with venlafaxine. J Clin Psychiatry. 2002;63(11):1049-50. [pmid: 12469691].
328 Sharma V. Venlafaxine: loss of antidepressant effect and its management. J Clin Psychiatry. 1998;59(7):381-2. [pmid: 9714268].
329 Soutullo CA, McElroy SL, Keck PE Jr. Hypomania associated with mirtazapine augmentation of sertraline. J Clin Psychiatry. 1998;59(6):320. [pmid: 9671349].
330 Sternbach H. Fluoxetine-associated potentiation of calcium-channel blockers. J Clin Psychopharmacol. 1991;11(6):390-1. [pmid: 1770159].
331 Straton JB, Cronholm P. Are paroxetine, fluoxetine, and sertraline equally effective for depression?. J Fam Pract. 2002;51(3):285. [pmid: 11978244].
332 Terao T. Rapid synergistic effects of lithium and antidepressants. Psychopharmacology (Berl). 1995;122(2):206-7. [pmid: 8848539].
333 Thompson C. Bridging the gap between psychiatric practice and primary care. Int Clin Psychopharmacol. 1992;7(Suppl 2):31-6. [pmid: 1484176].
334 Thompson C. Management of depression in real-life settings: knowledge gained from large-scale clinical trials. Int Clin Psychopharmacol. 1994;9(Suppl 3):21-5. [pmid: 7963447].
335 Thompson C. Discontinuation of antidepressant therapy: emerging complications and their relevance. J Clin Psychiatry. 1998;59(10):541-8. [pmid: 9818638].
336 Thompson M, Samuels S. Rhabdomyolysis with simvastatin and nefazodone. Am J Psychiatry. 2002;159(9):1607. [pmid: 12202291].
337 Trappler B, Miyashiro AM. Bupropion-amantadine-associated neurotoxicity. J Clin Psychiatry. 2000;61(1):61-2. [pmid: 10695649].
338 Turkington D, Smith PP, Grant J. Idiopathic genital pain and fluvoxamine. Br J Psychiatry. 1992;160:871. [pmid: 1617380].
339 Vaughan DA. Interaction of fluoxetine with tricyclic antidepressants. Am J Psychiatry. 1988;145(11):1478. [pmid: 3263809].
340 Vilaplana J, Botey E, Lecha M, Herrero C, Romaguera C. Photosensitivity induced by paroxetine. Contact Dermatitis. 2002;47(2):118-9. [pmid: 12455545].
341 Walley T, Pirmohamed M, Proudlove C, Maxwell D. Interaction of metoprolol and fluoxetine. Lancet. 1993;341(8850):967-8. [pmid: 8096308].
342 Weintraub D. Nortriptyline toxicity secondary to interaction with bupropion sustained-release. Depress Anxiety. 2001;13(1):50-2. [pmid: 11233461].
343 Wenger TL, Stern WC. The cardiovascular profile of bupropion. J Clin Psychiatry. 1983;44(5 Pt 2):176-82. [pmid: 6406453].
344 Wheatley D. Trazodone in depression. Int Pharmacopsychiatry. 1980;15(4):240-6. [pmid: 7021449].
345 Willetts J, Lippa A, Beer B. Clinical development of citalopram. J Clin Psychopharmacol. 1999;19(5 Suppl 1):36S-46S. [pmid: 10507507].
346 Wirshing WC, Van Putten T, Rosenberg J, Marder S, Ames D, Hicks-Gray T. Fluoxetine, akathisia, and suicidality: is there a causal connection?. Arch Gen Psychiatry. 1992;49(7):580-1. [pmid: 1627050].
347 Workman EA, Short DD. Bupropion-induced carbohydrate craving and weight gain. Am J Psychiatry. 1992;149(10):1407-8. [pmid: 1530081].
348 Yuksel FV, Tuzer V, Goka E. Escitalopram intoxication. Eur Psychiatry. 2005;20(1):82. [pmid: 15642453].
349 Zanardi R, Benedetti F, Di Bella D, Catalano M, Smeraldi E. Efficacy of paroxetine in depression is influenced by a functional polymorphism within the promoter of the serotonin transporter gene. J Clin Psychopharmacol. 2000;20(1):105-7. [pmid: 10653220].
350 Zhalkovsky B, Walker D, Bourgeois JA. Seizure activity and enzyme elevations after venlafaxine overdose. J Clin Psychopharmacol. 1997;17(6):490-1. [pmid: 9408815].

### Wrong Study Design

351 Altamura AC, Montgomery SA, Wernicke JF. The evidence for 20mg a day of fluoxetine as the optimal dose in the treatment of depression. Br J Psychiatry Suppl 1988(3):109–12.
352 Amore M, Ricci M, Zanardi R, Perez J, Ferrari G. Long-term treatment of geropsychiatric depressed patients with venlafaxine. J Affect Disord. 1997;46(3):293-6. [pmid: 9547127].
353 Appelhof BC, Brouwer JP, van Dyck R, Fliers E, Hoogendijk WJ, Huyser J, et al. Triiodothyronine addition to paroxetine in the treatment of major depressive disorder. J Clin Endocrinol Metab. 2004;89(12):6271-6. [pmid: 15579788].
354 Arranz FJ, Ros S. Effects of comorbidity and polypharmacy on the clinical usefulness of sertraline in elderly depressed patients: an open multicentre study. J Affect Disord. 1997;46(3):285-91. [pmid: 9547126].
355 Baldwin DS, Hawley CJ, Mellors K. A randomized, double-blind controlled comparison of nefazodone and paroxetine in the treatment of depression: safety, tolerability and efficacy in continuation phase treatment. J Psychopharmacol. 2001;15(3):161-5. [pmid: 11565622].
356 Beasley CM Jr, Sayler ME, Cunningham GE, Weiss AM, Masica DN. Fluoxetine in tricyclic refractory major depressive disorder. J Affect Disord. 1990;20(3):193-200. [pmid: 2148340].
357 Beasley CM Jr, Sayler ME, Weiss AM, Potvin JH. Fluoxetine: activating and sedating effects at multiple fixed doses. J Clin Psychopharmacol. 1992;12(5):328-33. [pmid: 1479050].
358 Beasley CM Jr, Potvin JH. Fluoxetine: activating and sedating effects. Int Clin Psychopharmacol. 1993;8(4):271-5. [pmid: 8277147].
359 Beasley CM Jr, Nilsson ME, Koke SC, Gonzales JS. Efficacy, adverse events, and treatment discontinuations in fluoxetine clinical studies of major depression: a meta-analysis of the 20-mg/day dose. J Clin Psychiatry. 2000;61(10):722-8. [pmid: 11078032].
360 Benedetti F, Campori E, Colombo C, Smeraldi E. Fluvoxamine treatment of major depression associated with multiple sclerosis. J Neuropsychiatry Clin Neurosci. 2004;16(3):364-6. [pmid: 15377746].
361 Berk M, du Plessis AD, Birkett M, Richardt D. An open-label study of duloxetine hydrochloride, a mixed serotonin and noradrenaline reuptake inhibitor, in patients with DSM-III-R major depressive disorder. Lilly Duloxetine Depression Study Group. Int Clin Psychopharmacol. 1997;12(3):137-40. [pmid: 9248869].
362 Bertschy G, Ragama-Pardos E, Muscionico M, Ait-Ameur A, Roth L, Osiek C, et al. Trazodone addition for insomnia in venlafaxine-treated, depressed inpatients: a semi-naturalistic study. Pharmacol Res. 2005;51(1):79-84. [pmid: 15519538].
363 Biswas PN, Wilton LV, Shakir SA. The pharmacovigilance of mirtazapine: results of a prescription event monitoring study on 13554 patients in England. J Psychopharmacol. 2003;17(1):121-6. [pmid: 12680749].
364 Blumenfield M, Levy NB, Spinowitz B, Charytan C, Beasley CM Jr, Dubey AK, et al. Fluoxetine in depressed patients on dialysis. Int J Psychiatry Med. 1997;27(1):71-80. [pmid: 9565715].
365 Bogetto F, Bellino S, Revello RB, Patria L. Discontinuation syndrome in dysthymic patients treated with selective serotonin reuptake inhibitors: a clinical investigation. CNS Drugs. 2002;16(4):273-83. [pmid: 11945110].
366 Bourin M. Use of paroxetine for the treatment of depression and anxiety disorders in the elderly: a review. Hum Psychopharmacol. 2003;18(3):185-90. [pmid: 12672169].
367 Brannan SK, Mallinckrodt CH, Detke MJ, Watkin JG, Tollefson GD. Onset of action for duloxetine 60 mg once daily: double-blind, placebo-controlled studies. J Psychiatr Res. 2005;39(2):161-72. [pmid: 15589564].
368 Bremner JD, Smith WT. Org 3770 VS amitriptyline in the continuation treatment of depression: A placebo controlled trial. European Journal of Psychiatry. 1996;10(1):5-15.
369 Brown WA, Harrison W. Are patients who are intolerant to one SSRI intolerant to another?. Psychopharmacol Bull. 1992;28(3):253-6. [pmid: 1480728].
370 Brown WA, Harrison W. Are patients who are intolerant to one serotonin selective reuptake inhibitor intolerant to another?. J Clin Psychiatry. 1995;56(1):30-4. [pmid: 7836337].
371 Burrows AB, Salzman C, Satlin A, Noble K, Pollock BG, Gersh T. A randomized, placebo-controlled trial of paroxetine in nursing home residents with non-major depression. Depress Anxiety. 2002;15(3):102-10. [pmid: 12001178].
372 Caley CF, Weber SS. Paroxetine: a selective serotonin reuptake inhibiting antidepressant. Ann Pharmacother. 1993;27(10):1212-22. [pmid: 8251692].
373 Carpenter LL, Jocic Z, Hall JM, Rasmussen SA, Price LH. Mirtazapine augmentation in the treatment of refractory depression. J Clin Psychiatry. 1999;60(1):45-9. [pmid: 10074878].
374 Cassano P, Soares CN, Cusin C, Mascarini A, Cohen LS, Fava M. Antidepressant response and well-being in pre-, peri- and postmenopausal women with major depressive disorder treated with fluoxetine. Psychother Psychosom. 2005;74(6):362-5. [pmid: 16244512].
375 Catalano MC, Catalano G, Kanfer SN, Toner LC, Stock SL, Taylor WD. The effect of sertraline on routine blood chemistry values. Clin Neuropharmacol. 2000;23(5):267-70. [pmid: 11154094].
376 Cervera-Enguix S, Baca-Baldomero E, Garcia-Calvo C, Prieto-Lopez R. Depression in primary care: effectiveness of venlafaxine extended-release in elderly patients; Observational study. Arch Gerontol Geriatr. 2004;38(3):271-80. [pmid: 15066313].
377 Claxton A, de Klerk E, Parry M, Robinson JM, Schmidt ME. Patient compliance to a new enteric-coated weekly formulation of fluoxetine during continuation treatment of major depressive disorder. J Clin Psychiatry. 2000;61(12):928-32. [pmid: 11206598].
378 Clayton AH, Warnock JK, Kornstein SG, Pinkerton R, Sheldon-Keller A, McGarvey EL. A placebo-controlled trial of bupropion SR as an antidote for selective serotonin reuptake inhibitor-induced sexual dysfunction. J Clin Psychiatry. 2004;65(1):62-7. [pmid: 14744170].
379 Cornelius JR, Salloum IM, Cornelius MD, Perel JM, Thase ME, Ehler JG, et al. Fluoxetine trial in suicidal depressed alcoholics. Psychopharmacol Bull. 1993;29(2):195-9. [pmid: 8290665].
380 Cornelius JR, Salloum IM, Ehler JG, Jarrett PJ, Cornelius MD, Perel JM, et al. Fluoxetine in depressed alcoholics. A double-blind, placebo-controlled trial. Arch Gen Psychiatry. 1997;54(8):700-5. [pmid: 9283504].
381 Cornelius JR, Salloum IM, Thase ME, Haskett RF, Daley DC, Jones-Barlock A, et al. Fluoxetine versus placebo in depressed alcoholic cocaine abusers. Psychopharmacol Bull. 1998;34(1):117-21. [pmid: 9564208].
382 Cornelius JR, Salloum IM, Haskett RF, Daley DC, Cornelius MD, Thase ME, et al. Fluoxetine versus placebo in depressed alcoholics: a 1-year follow-up study. Addict Behav. 2000;25(2):307-10. [pmid: 10795957].
383 Currier MB, Molina G, Kato M. Citalopram treatment of major depressive disorder in Hispanic HIV and AIDS patients: a prospective study. Psychosomatics. 2004;45(3):210-6. [pmid: 15123845].
384 Davidson JR, Meoni P, Haudiquet V, Cantillon M, Hackett D. Achieving remission with venlafaxine and fluoxetine in major depression: its relationship to anxiety symptoms. Depress Anxiety. 2002;16(1):4-13. [pmid: 12203668].
385 de Klerk E. Patient compliance with enteric-coated weekly fluoxetine during continuation treatment of major depressive disorder. J Clin Psychiatry. 2001;62(Suppl 22):43-7. [pmid: 11599648].
386 de Montigny C, Silverstone PH, Debonnel G, Blier P, Bakish D. Venlafaxine in treatment-resistant major depression: a Canadian multicenter, open-label trial. J Clin Psychopharmacol. 1999;19(5):401-6. [pmid: 10505581].
387 DeBattista C, Solvason HB, Poirier J, Kendrick E, Schatzberg AF. A prospective trial of bupropion SR augmentation of partial and non-responders to serotonergic antidepressants. J Clin Psychopharmacol. 2003;23(1):27-30. [pmid: 12544372].
388 Devanand DP, Pelton GH, Marston K, Camacho Y, Roose SP, Stern Y, et al. Sertraline treatment of elderly patients with depression and cognitive impairment. Int J Geriatr Psychiatry. 2003;18(2):123-30. [pmid: 12571820].
389 Diaz-Martinez A, Benassinni O, Ontiveros A, Gonzalez S, Salin R, Basquedano G, et al. A randomized, open-label comparison of venlafaxine and fluoxetine in depressed outpatients. Clin Ther. 1998;20(3):467-76. [pmid: 9663362].
390 Dornseif BE, Dunlop SR, Potvin JH, Wernicke JF. Effect of dose escalation after low-dose fluoxetine therapy. Psychopharmacol Bull. 1989;25(1):71-9. [pmid: 2672072].
391 Duboff EA. Long-term treatment of major depressive disorder with paroxetine. J Clin Psychopharmacol. 1993;13(6 Suppl 2):28S-33S. [pmid: 8106653].
392 Dunner DL, Hendricksen HE, Bea C, Budech CB, Friedman SD. Dysthymic disorder: treatment with citalopram. Depress Anxiety. 2002;15(1):18-22. [pmid: 11816048].
393 Dunner DL, Goldstein DJ, Mallinckrodt C, Lu Y, Detke MJ. Duloxetine in treatment of anxiety symptoms associated with depression. Depress Anxiety. 2003;18(2):53-61. [pmid: 12964171].
394 Dunner DL, Wohlreich MM, Mallinckrodt CH, Watkin JG, Fava M. Clinical consequences of initial duloxetine dosing strategies: comparison of 30 and 60 mg QD starting doses. Current Therapeutic Research. 2005;66(6):522-40.
395 Elliott AJ, Russo J, Bergam K, Claypoole K, Uldall KK, Roy-Byrne PP. Antidepressant efficacy in HIV-seropositive outpatients with major depressive disorder: an open trial of nefazodone. J Clin Psychiatry. 1999;60(4):226-31. [pmid: 10221282].
396 Elliott AJ, Russo J, Roy-Byrne PP. The effect of changes in depression on health related quality of life (HRQoL) in HIV infection. Gen Hosp Psychiatry. 2002;24(1):43-7. [pmid: 11814533].
397 Entsuah AR, Rudolph RL, Chitra R. Effectiveness of venlafaxine treatment in a broad spectrum of depressed patients: a meta-analysis. Psychopharmacol Bull. 1995;31(4):759-66. [pmid: 8851650].
398 Fann JR, Uomoto JM, Katon WJ. Sertraline in the treatment of major depression following mild traumatic brain injury. J Neuropsychiatry Clin Neurosci. 2000;12(2):226-32. [pmid: 11001601].
399 Fava M, Rappe SM, Pava JA, Nierenberg AA, Alpert JE, Rosenbaum JF. Relapse in patients on long-term fluoxetine treatment: response to increased fluoxetine dose. J Clin Psychiatry. 1995;56(2):52-5. [pmid: 7852252].
400 Fava M, Dunner DL, Greist JH, Preskorn SH, Trivedi MH, Zajecka J, et al. Efficacy and safety of mirtazapine in major depressive disorder patients after SSRI treatment failure: an open-label trial. J Clin Psychiatry. 2001;62(6):413-20. [pmid: 11465517].
401 Fava M, Schmidt ME, Zhang S, Gonzales J, Raute NJ, Judge R. Treatment approaches to major depressive disorder relapse. Part 2: reinitiation of antidepressant treatment. Psychother Psychosom. 2002;71(4):195-9. [pmid: 12097784].
402 Fava M, Papakostas GI, Petersen T, Mahal Y, Quitkin F, Stewart J, et al. Switching to bupropion in fluoxetine-resistant major depressive disorder. Ann Clin Psychiatry. 2003;15(1):17-22. [pmid: 12839429].
403 Fava M, Mallinckrodt CH, Detke MJ, Watkin JG, Wohlreich MM. The effect of duloxetine on painful physical symptoms in depressed patients: do improvements in these symptoms result in higher remission rates?. J Clin Psychiatry. 2004;65(4):521-30. [pmid: 15119915].
404 Fawcett J, Marcus RN, Anton SF, O'Brien K, Schwiderski U. Response of anxiety and agitation symptoms during nefazodone treatment of major depression. J Clin Psychiatry. 1995;56(Suppl 6):37-42. [pmid: 7649972].
405 Feiger AD, Flament MF, Boyer P, Gillespie JA. Sertraline versus fluoxetine in the treatment of major depression: a combined analysis of five double-blind comparator studies. Int Clin Psychopharmacol. 2003;18(4):203-10. [pmid: 12817154].
406 Feighner JP, Entsuah AR, McPherson MK. Efficacy of once-daily venlafaxine extended release (XR) for symptoms of anxiety in depressed outpatients. J Affect Disord. 1998;47(13):55-62. [pmid: 9476744].
407 Feldmann HS, Denber HC. Long-term study of fluvoxamine: a new rapid-acting antidepressant. Int Pharmacopsychiatry. 1982;17(2):114-22. [pmid: 6809683].
408 Fontaine R, Ontiveros A, Elie R, Vezina M. Lithium carbonate augmentation of desipramine and fluoxetine in refractory depression. Biol Psychiatry. 1991;29(9):946-8. [pmid: 1904782].
409 Franchini L, Rossini D, Bongiorno F, Spagnolo C, Smeraldi E, Zanardi R. Will a second prophylactic treatment with a higher dosage of the same antidepressant either prevent or delay new depressive episodes?. Psychiatry Res. 2000;96(1):81-5. [pmid: 10980329].
410 Gelenberg AJ, McGahuey C, Laukes C, Okayli G, Moreno F, Zentner L, et al. Mirtazapine substitution in SSRI-induced sexual dysfunction. J Clin Psychiatry. 2000;61(5):356-60. [pmid: 10847310].
411 Giannelli A, Rabboni M, Zarattini F, Malgeri C, Magnolfi G. A combination of hypothalamic phospholipid liposomes with trazodone for treatment of depression. An open controlled study. Acta Psychiatr Scand. 1989;79(1):52-8. [pmid: 2648767].
412 Golden RN, Nemeroff CB, McSorley P, Pitts CD, Dube EM. Efficacy and tolerability of controlled-release and immediate-release paroxetine in the treatment of depression. J Clin Psychiatry. 2002;63(7):577-84. [pmid: 12143913].
413 Goldstein DJ, Lu Y, Detke MJ, Hudson J, Iyengar S, Demitrack MA. Effects of duloxetine on painful physical symptoms associated with depression. Psychosomatics. 2004;45(1):17-28. [pmid: 14709757].
414 Greco T, Eckert G, Kroenke K. The outcome of physical symptoms with treatment of depression. J Gen Intern Med. 2004;19(8):813-8. [pmid: 15242465]. [pmcid: 1492507].
415 Halaris AE, Stern W, Harto-Truax N. Clinical efficacy of the new antidepressant bupropion (Wellbutrin) [proceedings]. Psychopharmacol Bull. 1981;17(1):140-2. [pmid: 6785817].
416 Harrison CL, Ferrier N, Young AH. Tolerability of high-dose venlafaxine in depressed patients. J Psychopharmacol. 2004;18(2):200-4. [pmid: 15260908].
417 Hebenstreit GF, Fellerer K, Zochling R, Zentz A, Dunbar GC. A pharmacokinetic dose titration study in adult and elderly depressed patients. Acta Psychiatr Scand Suppl. 1989;350:81-4. [pmid: 2530795].
418 Heiligenstein JH, Tollefson GD, Faries DE. Response patterns of depressed outpatients with and without melancholia: a double-blind, placebo-controlled trial of fluoxetine versus placebo. J Affect Disord. 1994;30(3):163-73. [pmid: 8006243].
419 Hellerstein DJ, Yanowitch P, Rosenthal J, Samstag LW, Maurer M, Kasch K, et al. A randomized double-blind study of fluoxetine versus placebo in the treatment of dysthymia. Am J Psychiatry. 1993;150(8):1169-75. [pmid: 8328559].
420 Hellerstein DJ, Yanowitch P, Rosenthal J, Hemlock C, Kasch K, Samstag LW, et al. Long-term treatment of double depression: a preliminary study with serotonergic antidepressants. Prog Neuropsychopharmacol Biol Psychiatry. 1994;18(1):139-47. [pmid: 8115668].
421 Houck C. An open-label pilot study of fluvoxamine for mixed anxiety-depression. Psychopharmacol Bull. 1998;34(2):225-7. [pmid: 9641005].
422 Hudson JI, Wohlreich MM, Kajdasz DK, Mallinckrodt CH, Watkin JG, Martynov OV. Safety and tolerability of duloxetine in the treatment of major depressive disorder: analysis of pooled data from eight placebo-controlled clinical trials. Human Psychopharmacology: Clinical and Experimental. 2005;20(5):327-41. [pmid: 15912562].
423 Huyse FJ, Zwaan WA, Kupka R. The applicability of antidepressants in the depressed medically ill: an open clinical trial with fluoxetine. J Psychosom Res. 1994;38(7):695-703. [pmid: 7877124].
424 Iosifescu DV, Nierenberg AA, Alpert JE, Papakostas GI, Perlis RH, Sonawalla S, et al. Comorbid medical illness and relapse of major depressive disorder in the continuation phase of treatment. Psychosomatics. 2004;45(5):419-25. [pmid: 15345787].
425 Jacobsen FM. Fluoxetine-induced sexual dysfunction and an open trial of yohimbine. J Clin Psychiatry. 1992;53(4):119-22. [pmid: 1564046].
426 Jindal RD, Friedman ES, Berman SR, Fasiczka AL, Howland RH, Thase ME. Effects of sertraline on sleep architecture in patients with depression. J Clin Psychopharmacol. 2003;23(6):540-8. [pmid: 14624183].
427 Joffe RT, Levitt AJ, Sokolov ST, Young LT. Response to an open trial of a second SSRI in major depression. J Clin Psychiatry. 1996;57(3):114-5. [pmid: 8617695].
428 Joffe RT, Marshall AM, Lee DK. A large open-label study of venlafaxine in depressed outpatients by community-based physicians. J Clin Psychiatry. 1998;59(10):515-20. [pmid: 9818632].
429 Joo JH, Lenze EJ, Mulsant BH, Begley AE, Weber EM, Stack JA, et al. Risk factors for falls during treatment of late-life depression. J Clin Psychiatry. 2002;63(10):936-41. [pmid: 12416604].
430 Judge R, Plewes JM, Kumar V, Koke SC, Kopp JB. Changes in energy during treatment of depression: an analysis of fluoxetine in double-blind, placebo-controlled trials. J Clin Psychopharmacol. 2000;20(6):666-72. [pmid: 11106139].
431 Kaynak H, Kaynak D, Gozukirmizi E, Guilleminault C. The effects of trazodone on sleep in patients treated with stimulant antidepressants. Sleep Med. 2004;5(1):15-20. [pmid: 14725822].
432 Klieser E, Lehmann E. Experimental comparison between the effect of standardized trazodone-amitriptyline and placebo treatment in vitalized depressive patients. Psychopharmacology (Berl). 1988;95(Suppl):S3-5. [pmid: 3133710].
433 Kuhn KU, Quednow BB, Thiel M, Falkai P, Maier W, Elger CE. Antidepressive treatment in patients with temporal lobe epilepsy and major depression: a prospective study with three different antidepressants. Epilepsy Behav. 2003;4(6):674-9. [pmid: 14698701].
434 Lam RW, Hossie H, Solomons K, Yatham LN. Citalopram and bupropion-SR: combining versus switching in patients with treatment-resistant depression. J Clin Psychiatry. 2004;65(3):337-40. [pmid: 15096072].
435 Lauritzen L, Odgaard K, Clemmesen L, Lunde M, Ohrstrom J, Black C, et al. Relapse prevention by means of paroxetine in ECT-treated patients with major depression: a comparison with imipramine and placebo in medium-term continuation therapy. Acta Psychiatr Scand. 1996;94(4):241-51. [pmid: 8911559].
436 Lenderking WR, Tennen H, Nackley JF, Hale MS, Turner RR, Testa MA. The effects of venlafaxine on social activity level in depressed outpatients. J Clin Psychiatry. 1999;60(3):157-63. [pmid: 10192590].
437 Leo RJ. Movement disorders associated with the serotonin selective reuptake inhibitors. J Clin Psychiatry. 1996;57(10):449-54. [pmid: 8909330].
438 Lepola U, Wade A, Andersen HF. Do equivalent doses of escitalopram and citalopram have similar efficacy? A pooled analysis of two positive placebo-controlled studies in major depressive disorder. Int Clin Psychopharmacol. 2004;19(3):149-55. [pmid: 15107657].
439 Lesperance F, Frasure-Smith N, Laliberte MA, White M, Lafontaine S, Calderone A, et al. An open-label study of nefazodone treatment of major depression in patients with congestive heart failure. Can J Psychiatry. 2003;48(10):695-701. [pmid: 14674053].
440 Letizia C, Kapik B, Flanders WD. Suicidal risk during controlled clinical investigations of fluvoxamine. J Clin Psychiatry. 1996;57(9):415-21. [pmid: 9746450].
441 Linden M, Gothe H, Dittmann RW, Schaaf B. Early termination of antidepressant drug treatment. J Clin Psychopharmacol. 2000;20(5):523-30. [pmid: 11001236].
442 Llorca PM, Azorin JM, Despiegel N, Verpillat P. Efficacy of escitalopram in patients with severe depression: a pooled analysis. Int J Clin Pract. 2005;59(3):268-75. [pmid: 15857321].
443 Louie AK, Lewis TB, Lannon RA. Use of low-dose fluoxetine in major depression and panic disorder. J Clin Psychiatry. 1993;54(11):435-8. [pmid: 8270588].
444 Lowe B, Schenkel I, Bair MJ, Gobel C. Efficacy, predictors of therapy response, and safety of sertraline in routine clinical practice: prospective, open-label, non-interventional postmarketing surveillance study in 1878 patients. J Affect Disord. 2005;87(23):271-9. [pmid: 15979151].
445 Lyketsos CG, Sheppard JM, Steele CD, Kopunek S, Steinberg M, Baker AS, et al. Randomized, placebo-controlled, double-blind clinical trial of sertraline in the treatment of depression complicating Alzheimer's disease: initial results from the Depression in Alzheimer's Disease study. Am J Psychiatry. 2000;157(10):1686-9. [pmid: 11007727].
446 Mallinckrodt CH, Goldstein DJ, Detke MJ, Lu Y, Watkin JG, Tran PV. Duloxetine: A New Treatment for the Emotional and Physical Symptoms of Depression. Prim Care Companion J Clin Psychiatry. 2003;5(1):19-28. [pmid: 15156243]. [pmcid: 353030].
447 Marcus RN, Mendels J. Nefazodone in the treatment of severe, melancholic, and recurrent depression. J Clin Psychiatry. 1996;57(Suppl 2):19-23. [pmid: 8626359].
448 Mauri MC, Fiorentini A, Cerveri G, Volonteri LS, Regispani F, Malvini L, et al. Long-term efficacy and therapeutic drug monitoring of sertraline in major depression. Hum Psychopharmacol. 2003;18(5):385-8. [pmid: 12858326].
449 McGrath PJ, Stewart JW, Petkova E, Quitkin FM, Amsterdam JD, Fawcett J, et al. Predictors of relapse during fluoxetine continuation or maintenance treatment of major depression. J Clin Psychiatry. 2000;61(7):518-24. [pmid: 10937611].
450 Mendels J, Kiev A, Fabre LF. Double-blind comparison of citalopram and placebo in depressed outpatients with melancholia. Depress Anxiety. 1999;9(2):54-60. [pmid: 10207659].
451 Menting JE, Honig A, Verhey FR, Hartmans M, Rozendaal N, de Vet HC, et al. Selective serotonin reuptake inhibitors (SSRIs) in the treatment of elderly depressed patients: a qualitative analysis of the literature on their efficacy and side-effects. Int Clin Psychopharmacol. 1996;11(3):165-75. [pmid: 8923095].
452 Michelson D, Schmidt M, Lee J, Tepner R. Changes in sexual function during acute and six-month fluoxetine therapy: a prospective assessment. J Sex Marital Ther. 2001;27(3):289-302. [pmid: 11354934].
453 Miller SM, Naylor GJ, Murtagh M, Winslow G. A double-blind comparison of paroxetine and placebo in the treatment of depressed patients in a psychiatric outpatient clinic. Acta Psychiatr Scand Suppl. 1989;350:143-4. [pmid: 2530772].
454 Miner CM, Brown EB, Gonzales JS, Munir R. Switching patients from daily citalopram, paroxetine, or sertraline to once-weekly fluoxetine in the maintenance of response for depression. J Clin Psychiatry. 2002;63(3):232-40. [pmid: 11926723].
455 Mitchell PB, Schweitzer I, Burrows G, Johnson G, Polonowita A. Efficacy of venlafaxine and predictors of response in a prospective open-label study of patients with treatment-resistant major depression. J Clin Psychopharmacol. 2000;20(4):483-7. [pmid: 10917411].
456 Montgomery SA. Safety of mirtazapine: a review. Int Clin Psychopharmacol. 1995;10(Suppl 4):37-45. [pmid: 8930008].
457 Montgomery SA, Reimitz PE, Zivkov M. Mirtazapine versus amitriptyline in the long-term treatment of depression: a double-blind placebo-controlled study. Int Clin Psychopharmacol. 1998;13(2):63-73. [pmid: 9669186].
458 Morishita S, Arita S. Differential effects of milnacipran, fluvoxamine and paroxetine for depression, especially in gender. Eur Psychiatry. 2003;18(8):418-20. [pmid: 14680720].
459 Morishita S, Arita S. Differential period of onset of action of fluvoxamine, paroxetine and milnacipran for depression. Hum Psychopharmacol. 2003;18(6):479-82. [pmid: 12923828].
460 Mulrow CD, Williams JW Jr, Trivedi M, Chiquette E, Aguilar C, Cornell JE, et al. Treatment of depression—newer pharmacotherapies. Psychopharmacol Bull. 1998;34(4):409-795. [pmid: 10513454].
461 Nelson EC. An open-label study of nefazodone in the treatment of depression with and without comorbid obsessive compulsive disorder. Ann Clin Psychiatry. 1994;6(4):249-53. [pmid: 7647834].
462 Nelson JC, Wohlreich MM, Mallinckrodt CH, Detke MJ, Watkin JG, Kennedy JS. Duloxetine for the treatment of major depressive disorder in older patients. Am J Geriatr Psychiatry. 2005;13(3):227-35. [pmid: 15728754].
463 Nemeroff CB, Schatzberg AF, Goldstein DJ, Detke MJ, Mallinckrodt C, Lu Y, et al. Duloxetine for the treatment of major depressive disorder. Psychopharmacol Bull. 2002;36(4):106-32. [pmid: 12858150].
464 Nierenberg AA, Cole JO, Glass L. Possible trazodone potentiation of fluoxetine: a case series. J Clin Psychiatry. 1992;53(3):83-5. [pmid: 1548249].
465 Nierenberg AA, Adler LA, Peselow E, Zornberg G, Rosenthal M. Trazodone for antidepressant-associated insomnia. Am J Psychiatry. 1994;151(7):1069-72. [pmid: 8010365].
466 Nierenberg AA, Feighner JP, Rudolph R, Cole JO, Sullivan J. Venlafaxine for treatment-resistant unipolar depression. J Clin Psychopharmacol. 1994;14(6):419-23. [pmid: 7884023].
467 Nierenberg AA, Quitkin FM, Kremer C, Keller MB, Thase ME. Placebo-controlled continuation treatment with mirtazapine: acute pattern of response predicts relapse. Neuropsychopharmacology. 2004;29(5):1012-8. [pmid: 14997172].
468 Ninan PT, Hassman HA, Glass SJ, McManus FC. Adjunctive modafinil at initiation of treatment with a selective serotonin reuptake inhibitor enhances the degree and onset of therapeutic effects in patients with major depressive disorder and fatigue. J Clin Psychiatry. 2004;65(3):414-20. [pmid: 15096082].
469 Norton KR, Sireling LI, Bhat AV, Rao B, Paykel ES. A double-blind comparison of fluvoxamine, imipramine and placebo in depressed patients. J Affect Disord. 1984;7(34):297-308. [pmid: 6241211].
470 Orengo CA, Kunik ME, Molinari V, Workman RH. The use and tolerability of fluoxetine in geropsychiatric inpatients. J Clin Psychiatry. 1996;57(1):12-6. [pmid: 8543541].
471 Ottevanger EA. The efficacy of fluvoxamine in patients with severe depression. Prog Neuropsychopharmacol Biol Psychiatry. 1994;18(4):731-40. [pmid: 7938563].
472 Oxman TE, Barrett JE, Sengupta A, Katon W, Williams JW Jr, Frank E, et al. Status of minor depression or dysthymia in primary care following a randomized controlled treatment. Gen Hosp Psychiatry. 2001;23(6):301-10. [pmid: 11738460].
473 Pae CU, Kim YJ, Won WY, Kim HJ, Lee S, Lee CU, et al. Paroxetine in the treatment of depressed patients with haematological malignancy: an open-label study. Hum Psychopharmacol. 2004;19(1):25-9. [pmid: 14716708].
474 Pande AC, Sayler ME. Severity of depression and response to fluoxetine. Int Clin Psychopharmacol. 1993;8(4):243-5. [pmid: 8277142].
475 Papakostas GI, Petersen T, Denninger JW, Tossani E, Pava JA, Alpert JE, et al. Psychosocial functioning during the treatment of major depressive disorder with fluoxetine. J Clin Psychopharmacol. 2004;24(5):507-11. [pmid: 15349006].
476 Pitts WM, Fann WE, Halaris AE, Dressler DM, Sajadi C, Snyder S, et al. Bupropion in depression: a tri-center placebo-controlled study. J Clin Psychiatry. 1983;44(5 Pt 2):95-100. [pmid: 6406473].
477 Pope HG Jr, McElroy SL, Nixon RA. Possible synergism between fluoxetine and lithium in refractory depression. Am J Psychiatry. 1988;145(10):1292-4. [pmid: 3262313].
478 Quitkin FM, Stewart JW, McGrath PJ, Taylor BP, Tisminetzky MS, Petkova E, et al. Are there differences between women's and men's antidepressant responses?. Am J Psychiatry. 2002;159(11):1848-54. [pmid: 12411218].
479 Quitkin FM, McGrath PJ, Stewart JW, Deliyannides D, Taylor BP, Davies CA, et al. Remission rates with 3 consecutive antidepressant trials: effectiveness for depressed outpatients. J Clin Psychiatry. 2005;66(6):670-6. [pmid: 15960558].
480 Rabkin JG, Wagner GJ, Rabkin R. Fluoxetine treatment for depression in patients with HIV and AIDS: a randomized, placebo-controlled trial. Am J Psychiatry. 1999;156(1):101-7. [pmid: 9892304].
481 Ravindran AV, Charbonneau Y, Zaharia MD, al-Zaid K, Wiens A, Anisman H. Efficacy and tolerability of venlafaxine in the treatment of primary dysthymia. J Psychiatry Neurosci. 1998;23(5):288-92. [pmid: 9846033]. [pmcid: 1188956].
482 Robinson DS, Roberts DL, Smith JM, Stringfellow JC, Kaplita SB, Seminara JA, et al. The safety profile of nefazodone. J Clin Psychiatry. 1996;57(Suppl 2):31-8. [pmid: 8626361].
483 Roose SP, Nelson JC, Salzman C, Hollander SB, Rodrigues H. Open-label study of mirtazapine orally disintegrating tablets in depressed patients in the nursing home. Curr Med Res Opin. 2003;19(8):737-46. [pmid: 14687445].
484 Rosenthal J, Hemlock C, Hellerstein DJ, Yanowitch P, Kasch K, Schupak C, et al. A preliminary study of serotonergic antidepressants in treatment of dysthymia. Prog Neuropsychopharmacol Biol Psychiatry. 1992;16(6):933-41. [pmid: 1513932].
485 Rush AJ, Bose A, Heydorn WE. Naturalistic study of the early psychiatric use of citalopram in the United States. Depress Anxiety. 2002;16(3):121-7. [pmid: 12415537].
486 Rush AJ, Carmody TJ, Haight BR, Rockett CB, Zisook S. Does pretreatment insomnia or anxiety predict acute response to bupropion SR?. Ann Clin Psychiatry. 2005;17(1):1-9. [pmid: 15941026].
487 Rush AJ, Bose A. Escitalopram in clinical practice: results of an open-label trial in a naturalistic setting. Depress Anxiety. 2005;21(1):26-32. [pmid: 15786487].
488 Saiz-Ruiz J, Ibanez A, Diaz-Marsa M, Arias F, Padin J, Martin-Carrasco M, et al. Efficacy of venlafaxine in major depression resistant to selective serotonin reuptake inhibitors. Prog Neuropsychopharmacol Biol Psychiatry. 2002;26(6):1129-34. [pmid: 12452535].
489 Saiz-Ruiz J, Ibanez A, Diaz-Marsa M, Arias F, Carrasco JL, Huertas D, et al. Nefazodone in the treatment of elderly patients with depressive disorders: a prospective, observational study. CNS Drugs. 2002;16(9):635-43. [pmid: 12153334].
490 Saletu-Zyhlarz GM, Abu-Bakr MH, Anderer P, Semler B, Decker K, Parapatics S, et al. Insomnia related to dysthymia: polysomnographic and psychometric comparison with normal controls and acute therapeutic trials with trazodone. Neuropsychobiology. 2001;44(3):139-49. [pmid: 11586054].
491 Satterlee WG, Faries D. The effects of fluoxetine on symptoms of insomnia in depressed patients. Psychopharmacol Bull. 1995;31(2):227-37. [pmid: 7491373].
492 Schneider LS, Small GW, Clary CM. Estrogen replacement therapy and antidepressant response to sertraline in older depressed women. Am J Geriatr Psychiatry. 2001;9(4):393-9. [pmid: 11739065].
493 Schweitzer I, Burrows G, Tuckwell V, Polonowita A, Flynn P, George T, et al. Sustained response to open-label venlafaxine in drug-resistant major depression. J Clin Psychopharmacol. 2001;21(2):185-9. [pmid: 11270915].
494 Settle EC, Stahl SM, Batey SR, Johnston JA, Ascher JA. Safety profile of sustained-release bupropion in depression: results of three clinical trials. Clin Ther. 1999;21(3):454-63. [pmid: 10321415].
495 Sheehan D, Dunbar GC, Fuell DL. The effect of paroxetine on anxiety and agitation associated with depression. Psychopharmacol Bull. 1992;28(2):139-43. [pmid: 1387484].
496 Shelton C, Entsuah R, Padmanabhan SK, Vinall PE. Venlafaxine XR demonstrates higher rates of sustained remission compared to fluoxetine, paroxetine or placebo. Int Clin Psychopharmacol. 2005;20(4):233-8. [pmid: 15933485].
497 Spigset O, Adielsson G. Combined serotonin syndrome and hyponatraemia caused by a citalopram-buspirone interaction. Int Clin Psychopharmacol. 1997;12(1):61-3. [pmid: 9179637].
498 Stahl SM, Entsuah R, Rudolph RL. Comparative efficacy between venlafaxine and SSRIs: a pooled analysis of patients with depression. Biol Psychiatry. 2002;52(12):1166-74. [pmid: 12488062].
499 Steffens DC, Doraiswamy PM, McQuoid DR. Bupropion SR in the naturalistic treatment of elderly patients with major depression. Int J Geriatr Psychiatry. 2001;16(9):862-5. [pmid: 11571765].
500 Stern WC, Harto-Truax N, Bauer N. Efficacy of bupropion in tricyclic-resistant or intolerant patients. J Clin Psychiatry. 1983;44(5 Pt 2):148-52. [pmid: 6406447].
501 Suri RA, Altshuler LL, Rasgon NL, Calcagno JL, Frye MA, Gitlin MJ, et al. Efficacy and response time to sertraline versus fluoxetine in the treatment of unipolar major depressive disorder. Journal Of Clinical Psychiatry. 2000;61(12):942-946. [pmid: 11206600].
502 Tam LW, Parry BL. Does estrogen enhance the antidepressant effects of fluoxetine?. Journal Of Affective Disorders. 2003;77(1):87-92. [pmid: 14550939].
503 Taragano F, Lyketsos CG, Paz J, Schapira M, Comesana Diaz E, Klimovsky S. An open-label trial of sertraline for the treatment of major depression in primary care. Ann Clin Psychiatry. 1999;11(2):67-71. [pmid: 10440523].
504 Taylor FB, Prather MR. The efficacy of nefazodone augmentation for treatment-resistant depression with anxiety symptoms or anxiety disorder. Depress Anxiety. 2003;18(2):83-8. [pmid: 12964175].
505 Teicher MH, Glod C, Cole JO. Emergence of intense suicidal preoccupation during fluoxetine treatment. Am J Psychiatry. 1990;147(2):207-10. [pmid: 2301661].
506 Thase ME, Blomgren SL, Birkett MA, Apter JT, Tepner RG. Fluoxetine treatment of patients with major depressive disorder who failed initial treatment with sertraline. J Clin Psychiatry. 1997;58(1):16-21. [pmid: 9055832].
507 Thase ME, Friedman ES, Fasiczka AL, Berman SR, Frank E, Nofzinger EA, et al. Treatment of men with major depression: a comparison of sequential cohorts treated with either cognitive-behavioral therapy or newer generation antidepressants. J Clin Psychiatry. 2000;61(7):466-72. [pmid: 10937603].
508 Tollefson GD, Tollefson SL, Sayler ME, Luxenberg MG. Absence of emergent suicidal ideation during treatment: A comparative, controlled, double-blind analysis employing several distinct antidepressants. Depression. 1994;2(2):73-79.
509 Tollefson GD, Holman SL, Sayler ME, Potvin JH. Fluoxetine, placebo, and tricyclic antidepressants in major depression with and without anxious features. J Clin Psychiatry. 1994;55(2):50-9. [pmid: 8077155].
510 Trappler B, Cohen CI. Use of SSRIs in “very old” depressed nursing home residents. Am J Geriatr Psychiatry. 1998;6(1):83-9. [pmid: 9469218].
511 Tyra JM, Greenawald MH. TCAs or SSRIs as initial therapy for depression?. J Fam Pract. 1999;48(11):845-6. [pmid: 10907616].
512 Van Houdenhove B, Onghena P, Floris M, Janssen F, De Nayer AR, Boxus A, et al. An open study of sertraline in acute and continuation treatment of depressed out-patients. J Int Med Res. 1997;25(6):340-53. [pmid: 9427167].
513 Van Wyck Fleet J, Manberg PJ, Miller LL, Harto-Truax N, Sato T, Fleck RJ, et al. Overview of clinically significant adverse reactions to bupropion. J Clin Psychiatry. 1983;44(5 Pt 2):191-6. [pmid: 6406456].
514 Verhoeven WM, Veendrik-Meekes MJ, Jacobs GA, van den Berg YW, Tuinier S. Citalopram in mentally retarded patients with depression: a long-term clinical investigation. Eur Psychiatry. 2001;16(2):104-8. [pmid: 11311174].
515 Wagner W, Plekkenpol B, Gray TE, Vlaskamp H, Essers H. Review of fluvoxamine safety database. Drugs. 1992;43(Suppl 2):48-53. discussion 53–4. [pmid: 1378374].
516 Walker PW, Cole JO, Gardner EA, Hughes AR, Johnston JA, Batey SR, et al. Improvement in fluoxetine-associated sexual dysfunction in patients switched to bupropion. J Clin Psychiatry. 1993;54(12):459-65. [pmid: 8276736].
517 Weintraub D, Streim JE, Datto CJ, Katz IR, DiFilippo SD, Oslin DW. Effect of increasing the dose and duration of sertraline trial in the treatment of depressed nursing home residents. J Geriatr Psychiatry Neurol. 2003;16(2):109-11. [pmid: 12801161].
518 Wernicke JF, Sayler ME, Koke SC, Pearson DK, Tollefson GD. Fluoxetine and concomitant centrally acting medication use during clinical trials of depression: the absence of an effect related to agitation and suicidal behavior. Depress Anxiety. 1997;6(1):31-9. [pmid: 9394873].
519 White K, Wykoff W, Tynes LL, Schneider L, Zemansky M. Fluvoxamine in the treatment of tricyclic-resistant depression. Psychiatr J Univ Ott. 1990;15(3):156-8. [pmid: 2123039].
520 Whyte EM, Basinski J, Farhi P, Dew MA, Begley A, Mulsant BH, et al. Geriatric depression treatment in nonresponders to selective serotonin reuptake inhibitors. J Clin Psychiatry. 2004;65(12):1634-41. [pmid: 15641868].
521 Wohlreich MM, Mallinckrodt CH, Watkin JG, Hay DP. Duloxetine for the long-term treatment of major depressive disorder in patients aged 65 and older: an open-label study. BMC Geriatr. 2004;4:11. [pmid: 15585058]. [pmcid: 544561].
522 Yohannes AM, Connolly MJ, Baldwin RC. A feasibility study of antidepressant drug therapy in depressed elderly patients with chronic obstructive pulmonary disease. Int J Geriatr Psychiatry. 2001;16(5):451-4. [pmid: 11376459].
523 Zajecka JM. The effect of nefazodone on comorbid anxiety symptoms associated with depression: experience in family practice and psychiatric outpatient settings. J Clin Psychiatry. 1996;57(Suppl 2):10-4. [pmid: 8626357].
524 Zanardi R, Cusin C, Rossini D, De Ronchi D, Serretti A. Comparison of response to fluvoxamine in nondemented elderly compared to younger patients affected by major depression. J Clin Psychopharmacol. 2003;23(6):535-9. [pmid: 14624182].
525 Zarate CA, Kando JC, Tohen M, Weiss MK, Cole JO. Does intolerance or lack of response with fluoxetine predict the same will happen with sertraline?. J Clin Psychiatry. 1996;57(2):67-71. [pmid: 8591971].