# Search Strategy

#16 Search “Antidepressive Agents, Second-Generation”[MeSH] OR “Fluoxetine”[MeSH] OR “Sertraline”[MeSH] OR “Paroxetine”[MeSH] OR “Citalopram”[MeSH] OR “Fluvoxamine”[MeSH] OR “Bupropion”[MeSH] OR “nefazodone”[Substance Name] OR “mirtazapine”[Substance Name] OR “venlafaxine”[Substance Name] OR “escitalopram” [tw] OR “duloxetine”[Substance Name] OR “Trazodone”[MeSH] =13604

#22 Search (“Depressive Disorder”[MeSH] OR “Depressive Disorder, Major”[MeSH]) OR “depression, involutional” [tw] OR “Dysthymic Disorder”[MeSH]OR “subsyndronal depressive disorder” [tw] 47030

#23 Search #16 AND #22 = 4043

#24 Search #16 AND #22 Field: All Fields, Limits: All Adult: 19+ years, English, Humans = 2783

#29 Search (“Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials”[MeSH]) OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] = 292497

#30 Search #24 AND #29 = 1056

#35 Search #24 NOT #30 Field: All Fields = 1727

#38 Search “Quality of Life”[MeSH] OR “Hospitalization”[MeSH] = 137196

#39 Search #35 AND #38 = 43

## Adverse Events

#42 Search “adverse events” [tw] OR “drug hypersensitivity” [mh] OR “drug toxicity” [mh] OR hyponatremia [mh] OR seizures [mh] OR suicide [mh] OR “weight gain” [mh] OR “gastroesophogeal reflux” [mh] OR libido [mh] OR hepatoxicity [tw] = 124762

## Longitudinal Studies

#44 Search longitudinal studies [mh] OR cohort studies [mh] OR case-control studies [mh] OR comparative study [mh] OR “observational studies” [tw] = 1819544

#45 Search #35 AND #42 = 226

#46 Search #35 AND #44 = 371

## Drug Interactions

#47 Search drug interactions [mh] = 103115

#48 Search #35 AND #47 = 144

#51 Search “Recurrence”[MeSH] OR remission [tw] OR relapse [tw] = 193920

#52 Search #35 AND #51 = 173

Similar Search Strategy in EMBASE = 133

Total Database = 1922