# Acknowledgments

This study was supported by Contract 290-02-0016 from the Agency for Healthcare Research and Quality (AHRQ), Task No. 7. We acknowledge the continuing support of Beth Collins Sharp, PhD, RN, Acting Director of the AHRQ Evidence-Based Practice Center (EPC) Program, and Lia Snyder, MPH, the AHRQ Task Order Officer for this project.

We extend our appreciation to our Technical Expert Panel (TEP): Susan G. Kornstein, MD., Professor of Psychiatry and Obstetrics and Gynecology, Virginia Commonwealth University, Richmond; Anand Kumar, MD, Professor of Psychiatry and Director of Geriatric Ambulatory Care Programs, University of California at Los Angeles; and John Williams, MD, Professor of Medicine and Psychiatry, Duke University, Durham, North Carolina. All provided thoughtful advice and input during our research process.

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI International and the University of North Carolina (UNC). We would particularly acknowledge Timothy Carey, MD, MPH, for insightful comments on the first draft and helpful suggestions throughout the project; Lynn Whitener, DrPH, MSLS, our EPC Librarian; and UNC supporting staff Stacey Williams and Jonathan Ward. We also express our gratitude to RTI staff Tammeka Swinson, Research Analyst, and both Jennifer Drolet, MA and Melissa Fisch, BA, editors.