# Peer Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this report and provided us with constructive feedback. The peer reviewers were asked to provide comments on the content, structure, and format of the evidence report and to complete a checklist. Their comments and suggestions formed the basis of our revisions to the evidence report. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.

- Susan G. Kornstein, MD., Professor of Psychiatry and Obstetrics and Gynecology, Virginia Commonwealth University, Richmond;
- John Williams, MD, Professor of Medicine and Psychiatry, Duke University, Durham, North Carolina;
- Mark Helfand, MD, MPH, Professor of Medicine and Medical Informatics and Clinical Epidemiology, and Director, Oregon Evidence-based Practice Center, Oregon Health and Science University, Portland;
- Staff of the National Institute for Mental Health, Rockville, Maryland;
- Staff of the Oregon Health and Science University Scientific Resource Center, Portland; and
- Staff of the Agency for Healthcare Research and Quality, Rockville, Maryland