# Appendixes

Appendix A Peer Reviewers

Appendix B Search Strategy

Appendix C Excluded Studies

Appendix D Evidence Tables

Appendix E Characteristics of Studies with Poor Internal Validity

Appendix F Placebo Studies Included in Meta-Regression

Appendix G Placebo Studies Excluded from Meta-Regression

Appendix H Meta-analyses of Discontinuation Rates

Appendix I Publications Appearing Only as Abstracts

Appendix J Acknowledgments