# Results

The search and selection of articles are summarized in the study flow diagram (Figure 2). Database searches resulted in 8,206 potentially relevant articles related to screening for hepatitis C virus (HCV) infection in asymptomatic nonpregnant adults and 2,580 potentially relevant articles related to screening for HCV infection in pregnant women. After dual review of abstracts and titles, 289 articles related to screening for HCV infection in asymptomatic adults were selected for full-text review, and 106 were determined by dual review at the full-text level to meet inclusion criteria. In addition, 116 studies were found by reviewing reference lists of published studies and through peer review and public comments. After dual review of abstracts and titles, 444 studies related to screening for HCV infection in pregnant women were selected for full-text review, and 17 were determined by dual review at the full-text level to be relevant. A total of 182 studies were included in this review. We identified no relevant unpublished studies from searches on clinical trials registries and grants databases.

Figure 2 Study flow diagram: Screening for hepatitis C virus infection in asymptomatic adults and pregnant women

^a^ Includes studies found through Peer Review and Public Comment.

^b^ One study used for two Key Questions.

^c^ One study resulting in two publications.

This figure is a flow chart that summarizes the search and selection of articles related to screening for hepatitis C virus infection in asymptomatic adults, as well as articles realted to screening for hepatitis C virus infection in pregnant women. Citations were identified through bibliographnic databases, including CCRCT, CDSR, MEDLINE, Scopus, and PsychINFO, as well as through other sources, including experts, reference lists and gray literature. For screening for hepatitis C virus infection in asymptomatic adults: there were 8,206 abstracts of potentially relevant articles reviewed along with 36 articles included in the previous report. After removing 156 duplicates and 7,725 abstracts that were not relevant to key questions, a set of 289 articles was identified for full text review. Of those 289 full text articles reviewed, 161 were excluded for the following reasons: wrong population, wrong intervention, wrong outcomes, wrong study design for key question, no original data, not English language, or not relevant. Of the 289 full text articles reviewed, 128 were intially included, along with 77 additional studies found through reference list searches and peer review. After reviewing additional studies, a final total of 166 studies were included in the review of hepatitis C virus infection in asymptomatic adults (of the additional studies found through peer review and public comment, all 39 were excluded). For screening in pregnant women, there were 2,580 abstracts of potentially relevant articles reviewed. After removing 81 duplicates and excluding 2,055 abstracts that were not relevant to key question 7, a set of 444 articles was identified for full text review. Of those 444 articles, 416 were excluded for the following reasons: wrong population, wrong intervention, wrong outcomes, wrong study design for key question, no original data, not English language, or not relevant. Of the 444 full text articles reviewed, 17 are included in the review. The articles found for each key question were: none for Key Question 1, none for Key Question 2a, 5 for Key Question 2b, 5 for Key Question 3, 135 articles for Key Question 4a, 3 articles for Key Question 4b, 6 articles for Key Question 5, 1 article for Key Question 6a, 5 articles for Key question 6b, 4 articles for Key Question 6c, and 17 articles for Key Question 7.

## Key Question 1a Does screening for HCV infection in asymptomatic nonpregnant adults reduce mortality and morbidity due to HCV, affect quality of life, or reduce transmission of HCV?

- No randomized trials or observational studies compared clinical outcomes between individuals screened and not screened for HCV infection (strength of evidence: insufficient).

No randomized trials or observational studies compared clinical outcomes between individuals (either in the general adult population or in higher-risk populations) screened and not screened for HCV infection. Two studies evaluated a screening intervention compared with no screening but did not meet inclusion criteria. One, a cluster randomized trial of methadone patients (n=196) in general practitioner offices in Ireland did not meet inclusion criteria because it evaluated a complex intervention that included provider education on screening for HCV as well as components related to evaluation, referral, and treatments for those found to be hepatitis C positive and was not designed or powered to evaluate clinical outcomes.78 It reported no deaths at 6 months, and did not report other clinical outcomes such as morbidity due to HCV, quality of life, and incidence or transmission of HCV infection. The second—a nonrandomized study comparing a screening intervention (targeted at patients aged 30–54 years in an area of Scotland with high HCV and injection drug use prevalence) with no intervention—also did not evaluate clinical outcomes.79 In the practice that implemented the intervention, 72 percent (421/584) of those in the target age group were offered HCV screening. Of these, 117 (of 421) were tested, 15 of those tested were HCV antibody positive, two received antiviral therapy, and one achieved a sustained virologic response. No patients in the target age group underwent HCV screening in the comparison practice.

## Key Question 1b Does screening for HCV infection during pregnancy reduce vertical transmission of HCV or improve mortality or morbidity for the mother or child?

- No randomized trials or observational studies evaluated vertical transmission rates of HCV infection in women screened for HCV infection during pregnancy compared with those not screened (strength of evidence: insufficient).
- No randomized trials or observational studies evaluated clinical outcomes in women screened for HCV during pregnancy compared with those not screened, or in infants of women screened compared with those not screened (strength of evidence: insufficient).

## Key Question 2a What is the effectiveness of different risk-or prevalence-based methods for screening for HCV infection on clinical outcomes?

- No randomized trials of observational studies compared clinical outcomes associated with different risk-or prevalence-based strategies for targeted HCV screening (strength of evidence: insufficient).

## Key Question 2b What is the sensitivity and number needed to screen to identify one case of HCV infection of different risk- or prevalence-based methods for screening for HCV infection?

- Five studies found that screening strategies targeting multiple risk factors were associated with sensitivities of over 90 percent and numbers needed to screen to identify one case of HCV infection of less than 20. More narrowly targeted screening strategies were associated with numbers needed to screen of less than two, but with the trade-off of missing up to two-thirds of infected patients. All studies were retrospective and had methodological shortcomings. (strength of evidence: low).

Four cross-sectional studies (samples sizes 985 to 3,367) provided data to calculate effects of applying alternative screening criteria on diagnostic accuracy and yield (Table 2, Table 3, Evidence Table 1, Appendix G).80–83 Three of the studies were published after the 2004 USPSTF review.44 Two studies evaluated patients attending sexually transmitted disease clinics80, 83 and two evaluated patients attending urban primary care clinics.81, 82 Three studies evaluated higher-prevalence populations (HCV prevalence 4.6 to 8.3 percent)80–82 and one evaluated a lower-prevalence population (HCV prevalence 1.0 percent).83 One smaller study (n=429) in primary care and gastroenterology clinics (n=429) also evaluated alternative screening criteria, but used a case-control design.84 All of the studies applied and evaluated alternative screening criteria retrospectively. Other limitations of the studies were that high proportions of potentially eligible patients were not included in analyses because of unknown HCV status, or the study did not report the proportion with unknown HCV status (Evidence Table 2, Appendix G). Although the studies used different criteria for targeted screening, several factors (a personal history of injection drug use, sexual intercourse with an injection drug user, and pre-1992 blood transfusion) were consistently used across studies to identify higher-risk individuals

Table 2 Studies of alternative screening strategies (Key Question 2b)

Author, Year Country | Study Design | Sample Size | Setting Population Characteristics | HCV Screening Strategies | Quality
Gunn, 2003 USA 80 | Cross-sectional | n=3,367 | STD clinic Age ≥30 years: 4.6% Female: Not reported Self-reported intravenous drug use: 5.7% | A: Screen all B: Ever injected drugs (self-report) C: Ever injected drugs or blood transfusions before 1992 (self-report) D: Same as C, or sex partner used injection drugs (self-report) E: Same as D (self-report or identified by clinic staff) F: Same as E, plus bacterial sexually transmitted disease in last 5 years G: Same as F, plus age ≥30 years | Fair
McGinn, 2008 USA 81 | Cross-sectional | n=1,000 | Urban primary care clinic Age: Mean 50 years Female: 73% Non-white: 90% | A: Screen all B: Positive findings in >=1 of 3 domains C: Positive findings in >=2 domains D: Positive findings in 3 domains | Fair
Nguyen, 2005 USA84 | Case-control | n=429 (225 HCV-positive, 204 HCV-negative) | Gastroenterology and primary care clinics Born 1940–1949: 20% Born 1950–1959: 38% Back 1960–1969: 18% Female: 58% Non-white: 37% Reports seeing use of injecting drugs: 34% | A: Screen all B: At least 1 risk factor, based on 7-item instrument (self-report history of sex with a prostitute, history of exposure to potentially infected blood during transfusion, rejection as a blood donor, refused life insurance, witnessing use of injecting drugs, sexual intercourse with an injecting drug user, self-report of HBV infection) C: At least 2 risk factors D: At least 3 risk factors E: Four or more risk factors | Poor
Zuniga, 2006 USA82 | Cross-sectional | n=2,263 | Urban primary care clinics Age 40–54 years: 31% White: 78% Female: 3.9% Vietnam era veteran: 50% Blood transfusion prior to 1992: 17% Any intravenous drug use: 4.5% Abnormal liver function tests: 9.1% | A: Any of 11 risk factors (Vietnam era veteran, multiple sexual contacts, tattoo/body piercing, intemperate alcohol use, blood transfusion prior to 1992, intranasal cocaine use, blood exposure (mucous membranes), abnormal liver enzymes, injection drug use (past or present), unexplained liver disease, hemodialysis) B: Any of 5 risk factors (Vietnam era veteran, tattoo/body piercing, blood transfusion prior to 1992, abnormal liver enzymes, injection drug use) C: Self-reported injection drug use (past or present) | Fair
Zuure, 2010^83^ Netherlands | Cross-sectional | n=985 | STD clinics Population characteristics not reported | A: Screen all B: At least 1 risk factor, based on 20-item questionnaire | Fair

HBV = hepatitis B virus; HCV = hepatitis C virus; STD = sexually transmitted disease

Table 3 Screening strategies: Effects of applying alternative screening criteria on sensitivity and number needed to screen to identify one case of HCV infection (Key Question 2b)

Author, Year Country | HCV Prevalence | Screening Strategy | Proportion Screened | Sensitivity | Specificity | Number Needed To Screen To Identify One Case of HCV Infection
Gunn, 2003 USA80 | 4.9% (165/3,367) | A: Screened all B: IVDU (self-report) C: IVDU or blood transfusions (self-report) D: IVDU, blood transfusions, or sex partner was an IVDU (self-report) E: Same as D (self-report or identified by clinic staff) F: Same as E, plus bacterial sexually transmitted disease in last 5 years G: Same as F, plus age ≥30 years | A: 100% (3,356/3,356) B: 5.8% (193/3,356) C: 7.5% (253/3,356) D: 10% (347/3,356) E: 12% (413/3,356) F: 34% (1,145/3,356) G: 63% (2,127/3,356) | A: 100% (165/165) B: 60% (99/165) C: 64% (105/165) D: 67% (110/165) E: 70% (116/165) F: 81% (134/165) G: 97% (160/165) | A: 0% (0/3191) B: 97% (3097/3191) C: 95% (3043/3191) D: 93% (2954/3191) E: 91% (2894/3191) F: 68% (2180/3191) G: 38% (1224/3191) | A: 20 (3,356/165) B: 1.9 (193/99) C: 2.4 (253/105) D: 3.2 (347/110) E: 3.6 (413/116) F: 8.5 (1,145/134) G: 13 (2,127/160)
McGinn, 2008 USA81 | 8.3% (83/1,000) | A: Screen all B: Positive findings in >=1 of 3 domains C: Positive findings in >=2 domains D: Positive findings in 3 domains | A: 100% (1,000/1,000) B: 71% (709/1,000) C: 23% (228/1,000) D: 5.6% (56/1,000) | A: 100% (83/83) B: 92% (76/83) C: 65% (54/83) D: 34% (28/83) | A: 0% (0/917) B: 31% (284/917) C: 81% (743/917) D: 97% (889/917) | A: 12 (1,000/83) B: 9.3 (709/76) C: 4.2 (228/54) D: 2.0 (56/28)
Nguyen, 2005 USA84 | Case-control design: 225 HCV-positive, 204 HCV-negative | A: Screen all B: At least 1 risk factor, based on 7-item instrument C: At least 2 risk factors D: At least 3 risk factors E: Four or more risk factors | A: 100% (429/429) B: 78% (335/429) C: 48% (207/429) D: 28% (118/429) E: 13% (56/429) | A: 100% (225/225) B: 94% (212/225) C: 79% (178/225) D: 51% (115/225) E: 24% (55/225) | A: 0% (0/204) B: 35% (81/204) C: 86% (175/204) D: 99% (201/204) E: 100% (203/204) | Not applicable (case control design)
Zuniga, 2006 USA82 | 4.6% (103/2,263) | A: Any of 11 risk factors B: Any of 5 risk factors C: Self-reported injection drug use (past or present) | A: 100% (2,263/2,263) B: 78% (1,776/2,263) C: 3.0% (68/2,263)^*^ | A: 100% (103/103) B: 97% (100/103) C: 41% (42/103) | A: 0% (0/2160) B: 22% (484/2160) C: 99% (2134/2160) | A: 22 (2,263/103) B: 18 (1,776/100) C: 1.6 (68/42)
Zuure, 2010^83^ Netherlands | 1.0% (98/985) | A: Screen all B: At least 1 risk factor, based on 20-item questionnaire | A: 100% (985/985) B: 21% (207/985) | A: 100% (98/98) B: 90% (88/98) | A: 0% (0/887) B: 87% (768/887) | A: 10 (985/98) B: 2.4 (207/88)

HCV = hepatitis C virus; IVDU = intravenous drug user; STD = sexually transmitted disease

One cross-sectional study evaluated a lower-prevalence population (n=985, HCV seroprevalence 1 percent).83 It found that targeted screening for HCV infection in a Dutch sexually transmitted diseases clinic based on presence of one or more positive items on a 20-item questionnaire was associated with a sensitivity of 90 percent for identifying persons with HCV infection, and a number needed to screen to identify one case of HCV infection of 2.4.

Three cross-sectional studies in higher-prevalence populations found that screening strategies targeting multiple risk factors were associated with sensitivities of over 90 percent and numbers needed to screen of 9.3 to 18.^80–82^ One cross-sectional study in a sexually transmitted disease clinic (n=3,367, HCV seroprevalence 4.9 percent) found that screening patients with one of five risk factors (injection drug user, sex partners of injection drug user, received a pre-1992 blood transfusion, bacterial sexually transmitted disease in last 5 years, or age ≥30 years) would have resulted in testing 63 percent of clinic attendees, with a sensitivity of 97 percent for identifying HCV infection and a number needed to screen of 13.^80^ One study of patients in an inner city primary care clinic (n=1,000; HCV seroprevalence 8.3 percent) found that screening patients with positive findings in at least one of three domains (medical history, exposure history, or social history) would have resulted in screening 71 percent of the population, with a sensitivity of 92 percent for identifying HCV infection and a number needed to screen of 9.3 to identify one case of HCV infection.81 A study of U.S. veterans (n=2,263, HCV seroprevalence 4.6 percent) found that screening patients based on presence of one or more of five risk factors (Vietnam era veteran, tattoo/body piercing, blood transfusion prior to 1992, abnormal liver enzymes, past or present injection drug use) would have resulted in screening 78 percent of the population compared to screening based on presence of these or six additional risk factors (multiple sexual contacts, intemperate alcohol use, intranasal cocaine use, blood exposure (mucous membranes), unexplained liver disease, hemodialysis), with a sensitivity of 97 percent and number needed to screen of 18.^82^

More narrowly targeted screening strategies evaluated in these studies were associated with specificities of over 95 percent and numbers needed to screen of less than two, but missed up to two-thirds of infected patients.80–82 Two studies found that screening injection drug users would have resulted in testing 3.0 percent and 5.8 percent of the population, respectively, with sensitivities of 41 percent and 60 percent, and numbers needed to screen of 1.6 and 1.9.^80, 82^ One study found that screening patients with positive findings in three different domains (medical, exposure, or social history) would have resulted in testing 5.6 percent of the population, with a sensitivity of 34 percent and number needed to screen of 2.0.^81^

A case-control study (222 cases) found that screening based on presence of four or more of seven risk factors (self-reported history of sex with a prostitute, history of exposure to potentially infected blood transfusion, rejections as a blood donor, refused life insurance, witnessed use of injecting drugs, sexual intercourse with an injection drug user, or self-reported hepatitis B virus [HBV] infection) would have identified 24 percent of HCV-infected persons, with a specificity of nearly 100 percent (203/204).84 Screening patients with one or more risk factors would have identified 94 percent of infected persons, with a specificity of 35 percent.

The 2004 USPSTF review44 included a post-hoc analysis of data from the National Hepatitis Screening Survey that found that screening patients using one of three different risk factor models would have identified between 53 to 69 percent of patients with chronic HCV infection.85

A large study based on a French national survey (n=14,416, HCV seroprevalence 0.8 percent) compared different screening strategies but did not meet inclusion criteria because it did not report the proportion screened, the sensitivity, or the number needed to screen to identify one case of HCV infection with each strategy.86 It found screening based on a model that included 11 variables (age, sex, pre-1992 blood transfusion, intravenous drug use, receipt of medical welfare, previous surgeries, illicit nasal drug use, previous HCV screening, tattoo, raised alanine aminotransferase level, and birth in a country with higher HCV prevalence) performed better than screening based on a model with six of these variables (intravenous drug use, elevated alanine aminotransferase level, pre-1992 blood transfusion, tattoo, acupuncture, high HCV prevalence birth region) for discriminating seropositive from seronegative individuals (c-statistic 0.87 [95% confidence interval (CI) 0.86 to 0.87] vs. 0.82 [95% CI 0.81 to 0.82]). The strongest predictors of HCV seropositivity other than intravenous drug use (odds ratio [OR] 36) or history of elevated alanine aminotransferase level (OR 11) was being 40 to 80 years old (the study was based on data collected in 2004), with ORs ranging from 11–36 depending on the 10-year age cohort. The Centers for Disease Control and Prevention (CDC) recently initiated a study to evaluate a screening strategy targeted at the highest-prevalence birth cohort (those born between 1945 and 1965), which is in progress.48

## Key Question 3 What are the harms associated with screening for HCV infection, including adverse effects such as anxiety, labeling, and impact on relationships?

- Five studies of patients diagnosed with HCV infection suggested potential negative psychological and social effects, but are difficult to interpret due to small sample sizes and methodological shortcomings, including no unscreened comparison group (strength of evidence: insufficient).

Few studies evaluated harms associated with screening for HCV infection. A small, fair-quality cross-sectional study (n=34) of intravenous drug users with chronic HCV infection found those aware of their HCV status reported worse quality of life compared with those who were not aware of their status.12 A retrospective, before-after study of patients with HCV infection (n=161) found that 44 percent reported a negative impact on psychological status (not otherwise defined); the proportion was similar regardless of time since diagnosis (≤1, >1 to ≤5, or >5 years).87 The proportion reporting a negative psychological impact was also similar in the subgroup of patients who reported receiving counseling (not characterized further) from a general practitioner. A study that evaluated a series of 15 newly diagnosed patients with HCV infection found that four binged on alcohol and two thought they were positive for a different virus within 2 weeks of receiving their result.79 A survey of 44 patients who were diagnosed with HCV infection through a screening program found that 33 percent reported strain on their relationship with their spouse or significant other and that 40 percent reported difficulty obtaining health insurance.88 However, 86 percent reported satisfaction with the decision to be tested and none reported discrimination at work—though in about half of the patients no one at work was aware of the patient’s positive HCV status or the patient did not work.

The 2004 USPSTF report44 included a small (n=34) controlled trial, published only in abstract form, that found that a brief counseling program helped improve sense of well-being in women diagnosed with HCV.89

## Key Question 4a What is the comparative effectiveness and comparative diagnostic accuracy of various tests and strategies for the workup to guide treatment decisions in patients who are HCV positive?

- One retrospective cohort study (n=156) of patients who received interferon plus ribavirin therapy found no difference in sustained virologic rates between patients who did not undergo biopsy prior to treatment compared with matched patients who did undergo biopsy. The study was not designed or powered to evaluate longer-term clinical outcomes (strength of evidence: insufficient).
- 135 studies (thirteen good quality) evaluated various noninvasive tests against liver biopsy for diagnosing fibrosis or cirrhosis in patients with HCV infection. Sensitivity and specificity varied depending on the cutoff used to define a positive test.
- For fibrosis (METAVIR F2-F4, Ishak 3–6, or equivalent), the median AUROC was 0.75 to 0.86 for the aspartate transaminase platelet ratio index (APRI), the Enhanced Liver Fibrosis Index (ELF), FIB-4, the Fibrometer, the FibroSpect II, the Fibrotest, Forns’ Index, and Hepascore (strength of evidence: moderate to high, depending on test).
- For cirrhosis (METAVIR F4, Ishak 5–6, or equivalent), the median AUROC ranged from 0.80 to 0.91 for platelet count, the age-platelet index, the APRI, the Enhanced Liver Fibrosis Index, FIB-4, Fibrometer, Fibrotest, Hepascore, and the Lok Index (strength of evidence: moderate to high, depending on test).
- 47 studies evaluated multiple indices against liver biopsy for diagnosing fibrosis or cirrhosis, allowing for direct comparisons of diagnostic accuracy.
  ○ Sixteen studies (some of which evaluated overlapping populations) consistently found no differences between the APRI and Fibrotest based on the AUROC (strength of evidence: moderate).
  ○ Twelve of 14 studies found the AST/ALT ratio associated with a lower AUROC compared with various other indices (strength of evidence: moderate).

### Effectiveness

One study evaluated clinical outcomes associated with different workup strategies in patients with HCV infection (Evidence Table 3 and Evidence Table 4, Appendix G).90 A retrospective cohort study of 156 HCV-positive patients who received interferon plus ribavirin therapy found no difference in sustained virologic response rates between patients who did not undergo biopsy prior to treatment compared with matched patients who did undergo biopsy (41 vs. 44 percent, p=0.87). About three-quarters of the patients who did not undergo biopsy refused it and about one-quarter had contraindications. The study was not designed or powered to evaluate longer-term clinical outcomes and did not report harms associated with biopsy.

### Diagnostic Accuracy

One hundred thirty-five studies evaluated the diagnostic accuracy of noninvasive tests for fibrosis or cirrhosis in patients with HCV infection (Evidence Table 5, Appendix G).91–223 We also reviewed four subsequent reports224–227 of diagnostic accuracy from three included studies.149, 156, 177

All studies compared the accuracy of noninvasive tests against liver biopsy as the reference standard. Thirteen studies were rated good quality,91, 112, 113, 118, 131, 155, 173–175, 178, 200, 214, 223 four poor quality,100, 125, 128, 194 and the remainder fair quality (Evidence Table 6, Appendix G). Fifty-nine did not describe interpretation of liver biopsies blinded to results of the test being evaluated, 72 studies did not describe enrollment of a consecutive or random sample of patients meeting pre-defined inclusion criteria, and 78 did not evaluate clearly predefined test cutoff values. The studies were primarily conducted in the United States, Europe, and Asia, in referral populations. No study specifically evaluated a screen-detected population of patients with chronic HCV infection. Studies varied with respect to inclusion criteria, including presence of elevated aminotransferases, antiviral therapy status, alcohol use status, and other factors.

#### Platelet Counts

Fifteen studies evaluated platelet counts (Supplemental Table 1).93, 98, 112, 117, 134, 136, 147, 148, 151, 156, 164, 169, 188, 200, 204 For fibrosis (defined as METAVIR F2-F4, Ishak 3–6, or equivalent), the median AUROC was 0.71 (range 0.38 to 0.94, 5 studies) (Table 4).93, 98, 117, 156, 204 At a cutoff of <140,000 to <163,000, median sensitivity was 0.51 (range 0.28 to 0.70) and median specificity 0.92 (range 0.71 to 1.0) in seven studies.93, 117, 136, 147, 156, 169, 188

Table 4 Diagnostic accuracy summary table

| Fibrosis (METAVIR F2-F4, Ishak 3–6, or Equivalent)^a^ | | | | Cirrhosis (METAVIR F4, Ishak 3–6, or Equivalent)
| Cutoff (for Sensitivity and Specificity) | Sensitivity: Median (Range); n Samples | Specificity: Median (Range); n Samples | AUROC: Median (Range); n Samples | Cutoff (for Sensitivity and Specificity) | Sensitivity: Median (Range); n Samples | Specificity: Median (Range); n Samples | AUROC: Median (Range); n Samples
Platelet count | <140,000 to <163,000 | 0.51 (0.28–0.70); 7 | 0.92 (0.71–1.0); 7 | 0.71 (0.38–0.94); 5 | <140,000–<155,000 | 0.82 (0.41–0.93); 7 | 0.88 (0.84–0.99); 7 | 0.89 (0.64–0.99); 5
Age-platelet index | >3.5 or >4.0 | 0.70 and 0.50; 2 | 0.74 and 0.77; 2 | 0.69 (0.64–0.77); 4 | >5.0 or ≥6.0 | 0.72 (0.67–0.80); 3 | 0.89 (0.87–0.93); 3 | 0.89 (0.67–0.91); 4
Age-platelet index | >6.0 | 0.51 and 0.19; 2 | 0.93 and 0.86; 2
Aspartate aminotransferase-platelet ratio index | ≥0.5 to >0.55 | 0.82 (0.29–0.98); 25 | 0.55 (0.13–0.94); 25 | 0.76 (0.58–0.95); 44 | >1.0 or ≥1.0 | 0.77 (0.33–1.0); 17 | 0.75 (0.30–0.87); 17 | 0.85 (0.61–0.92); 32
Aspartate aminotransferase-platelet ratio index | >1.5 or ≥1.5 | 0.41 (0–0.72); 21 | 0.95 (0.58–1.0); 21 | | >2.0 or ≥2.0 | 0.49 (0.30–0.76); 17 | 0.94 (0.65–0.97; 17
Aspartate aminotransferase-alanine aminotransferase ratio | >1.0 | 0.35 (0.10–0.45); 5 | 0.77 (0.62–1.0); 5 | 0.59 (0.50–0.82); 9 | >1.0 | 0.36 (0.12–0.78); 16 | 0.92 (0.68–1.0); 16 | 0.66 (0.52–0.91); 11
Cirrhosis Discriminant Score | Only AUROC reported | Not reported | Not reported | 0.67 (0.64–0.71); 3 | >2.0 or >3.0 | 0.85 and 1.0; 2 | 0.22 and 0.58; 2 | 0.77 (0.70–0.91); 6
Cirrhosis Discriminant Score | Only AUROC reported | Not reported | Not reported | 0.67 (0.64–0.71); 3 | >7.0 | 0.15 and 0.17; 2 | 1.0 and 1.0; 2
Enhanced Liver Fibrosis Index or Simplified Enhanced Liver Fibrosis Index | Varied | Not calculated | Not calculated | 0.81 (0.72–0.87); 7 | Varied | Not calculated | Not calculated | 0.88 (0.78–0.91); 6
FIB-4 | >1.45 or ≥1.45 | 0.74 (0.72–0.92); 5 | 0.67 (0.51–0.80); 5 | 0.86 (0.73–0.90); 4 | >1.45 | 0.90; 1 | 0.55; 1 | 0.87 (0.83–0.92); 6
FIB-4 | >3.25 | 0.38 (0.28–0.59); 5 | 0.98 (0.82–1.0); 5 | | >3.25 | 0.55; 1 | 0.92; 1
FibroIndex | >1.25 | 0.94 (0.62–0.97); 3 | 0.40 (0.40–0.48); 3 | 0.71 (0.58–0.86); 5 | >1.6 | 0.90; 1 | 0.74; 1 | 0.86 and 0.92; 2
FibroIndex | >2.25 or ≥2.25 | 0.30 (0.17–0.36); 3 | 0.97 (0.87–1.0); 3
Fibrometer | >0.419 to >0.59 | 0.69 (0.64–0.80); 3 | 0.81 (0.76–0.81); 3 | 0.82 (0.78–0.85); 8 | Varied | Not calculated | Not calculated | 0.91 (0.89–0.94); 5
FibroSpect II | Varied | Not calculated | Not calculated | 0.86 (0.82–0.90); 4 | No studies | No studies | No studies | No studies
Fibrotest | >0.10 to >0.22 | 0.92 (0.88–0.97); 5 | 0.46 (0.27–0.56); 5 | 0.79 (0.70–0.89); 21 | >0.56 or >0.66 | 0.85 and 0.82; 2 | 0.74 and 0.77; 2 | 0.86 (0.71–0.92); 11
Fibrotest | >0.70 or >0.80 | 0.30 (0.20–0.50); 4 | 0.96 (0.95–0.98); 4 | | ≥[underlined: 0.73,] ≥0.75 or >0.862 | 0.56 (0.30–1.0); 7 | 0.81 (0.24–0.96); 7
Forns’ Index | >4.2 or ≥4.2 | 0.88 (0.57–0.94); 12 | 0.52 (0.20–0.58); 12 | 0.75 (0.60–0.86); 16 | >4.2 | 0.98; 1 | 0.27; 1 | 0.88 (0.85–0.91); 6
Forns’ Index | >6.9 | 0.42 (0.18–0.61); 9 | 0.94 (0.66–0.99); 9 | | >6.9 | 0.67; 1 | 0.91; 1
Hepascore | >0.46 to ≥0.55 | 0.66 (0.54–0.82); 5 | 0.79 (0.65–0.86); 5 | 0.79 (0.69–0.82); 9 | >0.801 or ≥0.84 | 0.71 (0.71–0.80); 5 | 0.84 (0.81–0.89); 5 | 0.89 (0.88–0.94); 8
Lok Index | No studies | No studies | No studies | No studies | ≥0.2 | 0.90 (0.67–1.0); 6 | 0.56 (0.30–0.82);6 | 0.80 (0.61–0.91); 8
Lok Index | No studies | No studies | No studies | No studies | ≥0.5 or >0.6 | 0.52 (0.40–0.79); 6 | 0.91 (0.60–0.95); 6
Pohl Index | Positive | 0.20 (0.09–0.86); 5 | 0.98 (0.84–0.98); 5 | 0.53; 1 | Positive | 0.27 (0.26–0.34); 3 | 0.99 (0.98–0.99; 3 | 0.64 and 0.66; 2

AUROC = area under the receiver operating characteristic curve

Note: Some studies reported results for more than one population sample.

Note: Medians not calculated for <3 studies (results from individual studies provided).

a Fibrosis results for FIB-4 and Pohl Index are for severe fibrosis (METAVIR F3-F4, Ishak 4–6, or equivalent).

For cirrhosis (defined as METAVIR F4, Ishak 5–6, or equivalent), the median AUROC was 0.89 (range 0.64 to 0.99) in five studies.93, 112, 156, 200, 204 At a cutoff of <140,000 to <155,000, median sensitivity was 0.82 (range 0.41 to 0.93) and median specificity 0.88 (range 0.84 to 0.99) in seven studies.112, 148, 156, 164, 188, 200, 204

#### Other Individual Blood Tests and Indices

Other individual blood tests evaluated for diagnostic accuracy in a number of studies included serum ALT,100, 168, 186, 215–217, 219, 220 AST,100, 127, 219 bilirubin,93, 138, 191 gamma-glutamyl transferase (GGT),100, 138, 176, 191, 203 hyaluronic acid,100, 140, 141, 143, 159, 166, 168, 176, 182, 184, 194, 220, 223 matrix metalloproteinase-2 (MMP-2),100, 126, 168, 217 procollagen-III-peptide,133, 140, 141, 159, 161, 168, 194, 212, 215 tissue inhibitor of metalloproteinase-1 and -2 (TIMP-1 and -2),100, 126, 168, 217 and type IV collagen (Supplemental Table 1).168, 169, 194, 212, 216 For these tests, different cutoffs or assays were evaluated across studies, precluding summary estimates of sensitivity and specificity. In addition, few studies reported the AUROC, which incorporates data across different cutoffs. For ALT, three studies that appeared to evaluate the same or overlapping populations reported AUROCs that ranged from 0.51 to 0.59.^215–217^ A fourth study reported an AUROC of 0.82.^186^ For hyaluronic acid, the median AUROC was 0.75 (range 0.65 to 0.88; seven samples in six studies143, 159, 176, 184, 194, 223) for fibrosis and 0.91 (range 0.85 to 0.97; five samples in four studies140, 143, 176, 194) for cirrhosis.

Individual blood tests evaluated in one or two studies included albumin,93, 100 alkaline phosphatase,93, 100 apolipoprotein A1,^138, 191^ a-glutathione-S-transferase,220 haptoglobin,138, 191 laminin P1,^133, 216^ alpha-2 macroglobulin,138, 191 prothrombin index,112 soluble inter-cellular adhesion molecule-1,^161^ soluble vascular cell adhesion molecule-1,^161^ and YKL-40 (Supplemental Table 1).194 One study evaluated body mass index.209

##### Age-Platelet Index

Six studies evaluated the age-platelet index (Supplemental Table 2).102, 124, 125, 129, 156, 160 For fibrosis, the median AUROC was 0.69 (range 0.64 to 0.77) in four studies (Table 4).124, 129, 156, 160 At a cutoff of >3.5 or >4.0, sensitivity was 0.70 and 0.50 and specificity 0.74 and 0.77 in two studies.124, 160 At a cutoff of >6.0, sensitivity was 0.51 and 0.19 and specificity 0.93 and 0.86 in two studies.156, 160

For cirrhosis, the median AUROC was 0.89 (range 0.67 to 0.91) in four studies.102, 124, 125, 129 At a cutoff of >5.0 or ≥6.0, median sensitivity was 0.72 (range 0.67 to 0.80) and median specificity was 0.89 (range 0.87 to 0.93) in three studies.102, 124, 125

##### Aspartate Aminotransferase-Platelet Ratio Index (APRI)

Fifty-eight studies evaluated the aspartate aminotransferase-platelet (APRI) index (Supplemental Table 2).92, 93, 96, 98, 99, 102, 103, 105, 106, 109, 110, 112, 114–119, 122, 124, 125, 127, 129, 130, 135, 137, 142, 145, 146, 148, 151, 153, 156–158, 160, 162, 165, 175, 176, 178, 180, 189, 196–201, 204–206, 209, 213, 214, 219, 221, 223 For fibrosis, the median AUROC was 0.76 (range 0.58 to 0.95; 44 samples in 42 studies) (Table 4).92, 93, 98, 105, 109, 110, 114–117, 119, 122, 123, 129, 135, 137, 142, 145, 146, 151, 156–158, 160, 162, 165, 176, 178, 189, 196–198, 200, 201, 205, 206, 209, 213, 214, 219, 221, 223 At a cutoff of >0.5, ≥0.5, ≥0.53, or >0.55, the median sensitivity was 0.82 (range 0.29 to 0.98) and median specificity was 0.55 (range 0.13 to 0.94) in 25 samples reported in 24 studies.93, 99, 105, 110, 118, 123, 137, 142, 146, 153, 156, 158, 160, 165, 180, 189, 197, 198, 200, 201, 204, 205, 214, 219 At a cutoff of >1.5 or ≥1.5, median sensitivity was 0.41 (range 0.0 to 0.72) and median specificity was 0.95 (range 0.58 to 1.0) in 21 samples reported in 20 studies.93, 99, 105, 118, 137, 142, 146, 153, 156, 158, 160, 165, 180, 197, 198, 200, 201, 205, 214, 219 Excluding an outlier study160 with unusually poor sensitivity and high specificity narrowed the ranges but had no effect on median values.

For cirrhosis, the median AUROC was 0.85 (range 0.61 to 0.92) in 32 studies.92, 102, 103, 105, 106, 109, 112, 116, 119, 124, 125, 129, 130, 135, 137, 142, 145, 146, 151, 156, 157, 162, 165, 176, 196, 197, 199–201, 204, 214, 223 At a cutoff of ≥1.0 or >1.0, median sensitivity was 0.77 (range 0.33 to 1.0) and median specificity was 0.75 (range 0.30 to 0.87) in 17 studies.99, 102, 105, 109, 112, 118, 137, 142, 146, 151, 156, 165, 196, 197, 200, 201, 214 At a cutoff of ≥2.0 or >2.0, the median sensitivity was 0.49 (range 0.30 to 0.76) and median specificity was 0.94 (0.65 to 0.97) in 17 studies.99, 102, 105, 112, 118, 137, 142, 146, 148, 156, 165, 197, 199–201, 205, 214

##### Aspartate Aminotransferase to Alanine Aminotransferase Ratio (AST/ALT Ratio, or AAR)

Twenty-seven studies evaluated the AST/ALT ratio (Supplemental Table 2).93, 95, 98, 101, 102, 112, 117, 125, 127, 129, 134–136, 146, 148, 150, 156, 160, 164, 176, 177, 183, 187, 198, 200, 202, 218 For fibrosis, the median AUROC was 0.59 (range 0.50 to 0.82) in nine studies (Table 4).98, 117, 129, 135, 146, 156, 160, 176, 198 At a cutoff of >1.0, the median sensitivity was 0.35 (range 0.10 to 0.45) and median specificity was 0.77 (range 0.62 to 1.0) in five studies.117, 146, 160, 183, 198

For cirrhosis, the median AUROC was 0.66 (range 0.52 to 0.91) in 11 studies.93, 102, 112, 125, 129, 135, 146, 156, 176, 177, 200 At a cutoff of >1.0, the median sensitivity was 0.36 (range 0.12 to 0.78) and the median specificity was 0.92 (0.68 to 1.0) in 16 studies.93, 95, 102, 112, 134, 146, 148, 150, 156, 164, 176, 177, 187, 200, 202, 218

##### Cirrhosis Discriminant Score (CDS)

The cirrhosis discriminant score (CDS) or Bonacini index (based on the platelet count, AST/ALT ratio, prothrombin index, presence of ascites, and presence of spider angiomata) was evaluated in eight studies (Table 4).101, 102, 121, 124, 129, 130, 156, 192 For cirrhosis, the median AUROC was 0.77 (range 0.70 to 0.91) in six studies (Table 4).102, 124, 129, 130, 156, 192 At a cutoff of >2.0 or >3.0, two studies reported sensitivities of 0.85 and 1.0 and specificities of 0.22 and 0.58.^102, 192^ At a cutoff of >7.0, the same studies reported sensitivities of 0.15 and 0.17, and both reported a specificity of 1.0. Although the CDS was developed to identify cirrhosis, three studies reported a median AUROC of 0.67 (range of 0.64 to 0.71) for fibrosis.124, 129, 156

##### European Liver Fibrosis Index (ELF) and Enhanced Liver Fibrosis Index (simplified ELF)

Seven studies evaluated the European liver fibrosis index (ELF) index (based on age, hyaluronic acid, amino-terminal propeptide of type III collagen, and TIMP-1) or the enhanced liver fibrosis (simplified ELF) index (a subsequent version, without age) (Supplemental Table 2).115, 119, 132, 165, 179, 190, 223 For fibrosis, the median AUROC was 0.81 (range 0.72 to 0.87) in seven samples reported in five studies (Table 4).115, 119, 165, 179, 223 For cirrhosis, the median AUROC was 0.88 (range 0.78 to 0.91) in six population samples reported in four studies.119, 165, 179, 223 AUROC estimates were similar when studies were stratified according to whether they evaluated the ELF or simplified ELF. Cutoffs varied across studies and differed for the ELF and simplified ELF, precluding summary estimates of sensitivity or specificity.

##### FIB-4 Index

The FIB-4 index (based on age, AST, ALT, and platelet count) was evaluated in fifteen studies (Supplemental Table 2).92, 93, 96, 110, 115, 122, 124, 142, 165, 180, 200, 204, 207, 211, 223 The FIB-4 has primarily been evaluated for identification of severe (METAVIR F3-F4, Ishak 3–6, or equivalent) fibrosis. In four studies, the median AUROC for severe fibrosis was 0.86 (range 0.73 to 0.90) (Table 4).92, 93, 165, 211 The AUROC was similar for cirrhosis in six studies (median 0.87, range 0.83 to 0.92).92, 124, 142, 165, 204, 223 At a cutoff of >1.45 or ≥1.45, the median sensitivity for severe fibrosis was 0.74 (range 0.72 to 0.92) and median specificity was 0.67 (range 0.51 to 0.80) in five studies.93, 96, 165, 207, 211 At a cutoff of >3.25, the median sensitivity for severe fibrosis was 0.38 (range 0.28 to 0.59) and median specificity was 0.98 (range 0.82 to 1.0) in the same five studies.

##### FibroIndex

The FibroIndex (based on platelet count, AST, and gamma globulin) was evaluated in four studies (Supplemental Table 2).92, 129, 155, 198 For fibrosis, the median AUROC was 0.71 (range 0.58 to 0.86) in five samples reported in four studies (Table 4).92, 129, 155, 198 At a cutoff of >1.25, median sensitivity was 0.94 (range 0.62 to 0.97) and median specificity 0.40 (range 0.40 to 0.48) in three samples reported in two studies.155, 198 At a cutoff of >2.25 or ≥2.25, median sensitivity was 0.30 (range 0.17 to 0.36) and median specificity 0.97 (range 0.87 to 1.0) in the same three samples.

For cirrhosis, two studies reported AUROCs of 0.86 and 0.92.^92, 129^ Only one study reported sensitivity or specificity (Table 4).129

##### Fibrometer

The Fibrometer (based on age, sex, alpha-2-macroglobulin, prothrombin time, platelet count, AST, urea, GGT, and ALT) was evaluated in eight studies (Supplemental Table 2).106, 107, 110, 111, 122, 145, 157, 223 For fibrosis, the median AUROC was 0.82 (range 0.78 to 0.85) in eight samples reported in seven studies (Table 4).107, 110, 111, 122, 145, 157, 223 At a cutoff of >0.419 to >0.59, median sensitivity was 0.69 (range 0.64 to 0.80) and median specificity was 0.81 (range 0.76 to 0.81) in three studies.110, 122, 145 For cirrhosis, the median AUROC was 0.91 (range 0.89 to 0.94) in five studies.106, 111, 145, 157, 223 Cutoffs varied across studies, precluding summary estimates of sensitivity and specificity.

##### FibroSpect II

The FibroSpect II (based on TIMP-1, alpha-2 macroglobulin, and hyaluronic acid) was evaluated in four studies (Supplemental Table 2).180, 181, 206, 222 For fibrosis, the median AUROC was 0.86 (range 0.82 to 0.90) in the four studies (Table 4).180, 181, 206, 222 Cutoffs varied across studies, precluding summary estimates of sensitivity and specificity. No study evaluated the diagnostic accuracy of FibroSpect II for cirrhosis.

##### Fibrotest (Fibrosure)

Twenty-eight studies evaluated the Fibrotest (marketed as Fibrosure in the United States) (Supplemental Table 2).92, 104, 106, 110, 112, 114, 120, 122, 132, 138, 144, 145, 149, 157, 158, 170, 180, 184, 185, 191, 193, 198–201, 207, 219, 223 The original derivation study for the Fibrotest evaluated a six-marker version based on alpha-2-macroglobulin, haptoglobin, gamma-globulin, apolipoprotein A1, GGT, and total bilirubin.149 Subsequently, the Fibrotest was modified to a five-marker version without gamma-globulin.

For fibrosis, the median AUROC for was 0.79 (range 0.70 to 0.89) in 21 samples reported in 20 studies (Table 4).92, 110, 114, 122, 138, 144, 145, 149, 157, 158, 170, 180, 184, 185, 191, 193, 200, 201, 219, 223 In one study, the AUROC was slightly worse in the subgroup with normal ALT (0.70, 95% CI 0.59 to 0.81) compared with those with elevated ALT (0.79, 95% CI 0.74 to 0.84), but confidence intervals overlapped.198 At a cutoff of >0.10 to >0.22, median sensitivity was 0.92 (range 0.88 to 0.97) and median specificity 0.46 (range 0.27 to 0.56) in five studies.144, 149, 158, 170, 191, 193 At a cutoff of >0.70 or >0.80, median sensitivity was 0.30 (range 0.20 to 0.50) and median specificity 0.96 (range 0.95 to 0.98) in four studies.144, 149, 170, 191 At a cutoff of >0.435 to >0.50, median sensitivity was 0.68 (range 0.56 to 1.0) and median specificity 0.79 (range 0.61 to 0.82) in seven studies.110, 138, 145, 180, 193, 200, 201 Excluding studies that evaluated earlier versions of the Fibrotest did not affect median estimates or ranges.

For cirrhosis, the median AUROC was 0.86 (range 0.71 to 0.92) in 11 studies.92, 104, 106, 112, 145, 157, 193, 199–201, 223 In two studies that evaluated cutoffs of >0.56 and >0.66, sensitivities were 0.85 and 0.82 and specificities were 0.74 and 0.77.^106, 145^ In seven studies that evaluated cutoffs of >0.73, ≥0.75 or >0.862, median sensitivity was 0.56 (range 0.30 to 1.0) and median specificity 0.81 (range 0.24 to 0.96).106, 112, 132, 193, 200, 201, 207

##### Forns’ Index

Eighteen studies evaluated the Forns’ Index (based on age, GGT, cholesterol, and platelet count) (Supplemental Table 2).92, 103, 105, 115, 122, 129, 131, 142, 148, 158, 165, 180, 189, 198, 200, 201, 204, 223 For fibrosis, the median AUROC was 0.75 (range 0.60 to 0.86) in sixteen samples reported in fifteen studies (Table 4).92, 103, 105, 115, 122, 129, 131, 142, 158, 165, 189, 200, 201, 204, 223 At a cutoff of >4.2 to >4.57, median sensitivity was 0.88 (range 0.57 to 0.94) and median specificity was 0.52 (range 0.20 to 0.58) in twelve samples reported in eleven studies.105, 122, 131, 158, 165, 180, 189, 198, 200, 201, 204 At a cutoff of >6.9, median sensitivity was 0.42 (range 0.18 to 0.61) and median specificity was 0.94 (range 0.66 to 0.99) in nine samples reported in eight studies.105, 131, 142, 158, 165, 198, 200, 201

For cirrhosis, six studies reported a median AUROC of 0.88 (range 0.85 to 0.91).92, 103, 129, 142, 165, 204 Only one study reported sensitivity or specificity (Table 4).142

##### Hepascore

Eleven studies evaluated the Hepascore (based on α_2_-macroglobulin, hyaluronic acid, gamma GGT, total bilirubin, age, and sex) (Supplemental Table 2).91, 96, 104, 106, 110, 122, 139, 145, 157, 158, 223 For fibrosis, the median AUROC was 0.79 (range 0.69 to 0.82) in nine studies (Table 4).96, 104, 110, 122, 139, 145, 157, 158, 223 At a cutoff of >0.46 to ≥0.55, the median sensitivity was 0.66 (range 0.54 to 0.82) and median specificity 0.79 (range 0.65 to 0.86) in five studies.96, 104, 110, 139, 158

For cirrhosis, the median AUROC was 0.89 (range 0.88 to 0.94) in eight samples reported in seven studies.91, 104, 106, 139, 145, 157, 223 At a cutoff of >0.801 to >0.84, the median sensitivity was 0.71 (range 0.71 to 0.80) and median specificity was 0.84 (range 0.81 to 0.89) in five samples reported in four studies.91, 104, 106, 139

##### Lok Index

Eight studies evaluated the Lok Index (based on platelet count, AST/ALT ratio, and INR (Supplemental Table 2).112, 117, 125, 130, 156, 163, 200, 204 For cirrhosis, the median AUROC was 0.80 (range 0.61 to 0.91) in eight samples reported in six studies (Table 4).112, 125, 130, 163, 200, 204 At a cutoff of ≥0.2, median sensitivity was 0.90 (range 0.67 to 1.0) and median specificity 0.56 (range 0.30 to 0.82) in six samples reported in four studies.112, 156, 163, 200, 204 At a cutoff of ≥0.5 or >0.6, median sensitivity was 0.52 (range 0.40 to 0.79) and median specificity was 0.91 (range 0.60 to 0.95) in six samples reported in five studies.112, 125, 156, 163, 200 For fibrosis, one study reported an AUROC Of 0.70 (95% CI 0.62 to 0.77)204 and for severe fibrosis, one study reported an AUROC of 0.69 (95% CI 0.69 to 0.74).117 No study evaluated diagnostic accuracy of the Lok Index for fibrosis.

##### Pohl Index

Ten studies evaluated the Pohl Index (positive result defined as AST/ALT ratio >1 and platelet count <150,000)102, 117, 124, 125, 148, 154, 156, 164, 183 or variants with slightly lower platelet count cutoffs (<140,000 or <130,000) (Supplemental Table 2).134, 164 The Pohl Index has primarily been evaluated for identification of more advanced fibrosis. For severe fibrosis (METAVIR F3-F4, Ishak 3–6, or equivalent), one study reported an AUROC of 0.53 (95% CI 0.51 to 0.56) (Table 4).117 The median sensitivity was 0.20 (range 0.09 to 0.86) and median specificity was 0.98 (range 0.84 to 0.99) in five studies.117, 148, 154, 156, 183

For cirrhosis, the AUROC was 0.64 and 0.66 in two studies that evaluated the standard Pohl Index.124, 125 With the standard Pohl Index or using a platelet count cutoff of <140,000, median sensitivity was 0.27 (range 0.26 to 0.34) and median specificity was 0.99 (range 0.98 to 0.99) in three studies.102, 125, 164 In one study that used a platelet count cutoff of <130,000, sensitivity was higher (0.72) and specificity was similar (0.99).134

#### Sensitivity Analyses

Only one study rated as poor quality evaluated the indices described above.125 Its exclusion had no effect on medians or ranges for diagnostic accuracy. Excluding studies that reported results from samples used to derive the various indices also had little effect on findings.91, 101, 124, 131, 149, 163, 183, 214 Excluding multiple studies reporting results from similar or overlapping populations also had little effect on findings.

Restriction of analyses to studies that reported a median biopsy length of >15 mm and >5 portal tracts also had little effect on estimates of diagnostic accuracy, though many studies did not report biopsy quality. In addition, there was no consistent association between shorter biopsy length and lower AUROCs or other markers of diagnostic accuracy in studies that stratified results based on biopsy specimen length.123, 158, 163, 180, 197 Excluding studies that restricted enrollment to patients with normal serum aminotransferase levels generally had little effect on medians. For diagnosing fibrosis with the APRI at a cutoff of >0.5, one study that restricted enrollment to patients with normal aminotransferases appeared to be an outlier,160 with a much lower sensitivity (0.29) than the other studies (range 0.67 to 0.97). However, there were relatively few cases (n=21) and the AUROC (0.67) was within the range reported from other studies (0.62–0.92). Studies that stratified patients according to whether they had normal or elevated aminotransferases found no clear effect on the AUROC.155, 198, 199

#### Other Indices and Combined or Algorithmic Approaches

A number of other indices were evaluated in three or fewer studies, including the Fibro-αScore,174 Fibrosis Index,93, 173 Fibrosis-Cirrhosis Index,93 Fibrosis Probability Index (also known as the Sud Index),189, 208 the Fibrosis-protein Index,116 the FibroQ Index,146 the Goteburg University Cirrhosis Index,125, 151 the Globulin/albumin ratio,148, 164 the HALT-C model,130 the King’s Score,103, 123, 124 the MP3 score,158, 159 the Sabadell NIHCED index,97, 172 the Significant Fibrosis Index,115 the Zeng Index,115 and others (Supplemental Table 2).94, 128, 152, 167, 171, 178, 209 Due to the small numbers of studies, there was insufficient evidence to draw firm conclusions about diagnostic accuracy, though AUROCs when reported generally appeared comparable to other, better-studied indices.

Nine studies evaluated combinations of indices (Supplemental Table 2).102, 108, 113, 122, 148, 164, 197, 201, 206 The Sequential Algorithm for Fibrosis Evaluation (SAFE) was evaluated in four studies.108, 113, 197, 201 For fibrosis, SAFE (based on the sequential application of the APRI and Fibrotest based on an algorithm) was associated with an AUROC of 0.90 and 0.94 in two studies.113, 197 Median sensitivity was 1.0 (range 1.0 to 1.0) and median specificity 0.82 (range 0.77 to 0.88) in four studies.108, 113, 197, 201 For cirrhosis, SAFE was associated with a median AUROC of 0.87 (range 0.87 to 0.92) in three studies.113, 197, 201 Median sensitivity was 0.84 (range 0.62 to 0.90) and median specificity 0.92 (range 0.90 to 0.93) in four studies.108, 113, 197, 201 In single studies, the Leroy and Fibropaca algorithms and various combinations of APRI, FibroSpect II, Fibrotest, FIB-4, and Fibrometer were also associated with diagnostic accuracy somewhat higher than observed with single indices.122, 201, 206

#### Imaging Findings

Eight studies evaluated the diagnostic accuracy of various imaging findings for fibrosis or cirrhosis on liver biopsy, including hepatic transit time, spleen size, portal vein diameter, presence of liver nodularity, splenic artery pulsatility index, and assessments of portal or hepatic venous flow (Supplemental Table 1).119, 121, 147, 160, 175, 195, 196, 209 Few studies reported AUROCs, making it difficult to draw firm conclusions about diagnostic accuracy. In one study, the AUROC for hepatic transit time was 0.71 (95% CI 0.59 to 0.84) for fibrosis and 0.83 (95% CI 0.69 to 0.97) for cirrhosis.119 Other studies reported AUROCs for fibrosis of 0.86 (95% CI 0.78 to 0.95) for the splenic artery pulsatility index160 and 0.74 (95% CI 0.63 to 0.84) for the platelet-spleen diameter ratio209 and an AUROC for cirrhosis of 0.80 (CI not reported) for portal venous flow.195 Two studies found presence of liver surface nodularity associated with sensitivities of 0.60 and 0.16 for fibrosis, and specificities of 0.92 and 0.97.^121, 147^

#### Direct Comparisons

Forty-seven studies reported the AUROC for multiple indices for diagnosing fibrosis or cirrhosis against liver biopsy, allowing for direct comparisons of diagnostic accuracy (Supplemental Table 3).91–93, 98, 102–106, 110–112, 114–117, 119, 122, 124, 125, 127, 129, 130, 134, 142, 145, 151, 155–158, 160, 165, 170, 171, 176, 178, 180, 189, 198–201, 204, 206, 219, 223 Nine of these studies also compared different indices with platelet counts alone.93, 98, 112, 117, 124, 156, 170, 200, 204

The most frequent direct comparison was of the APRI with the Fibrotest, which was evaluated in 16 studies, though several evaluated overlapping populations (Table 5).92, 105, 106, 110, 112, 114, 122, 145, 157, 158, 198–201, 219, 223 There was no clear pattern suggesting differences between the APRI and the Fibrotest, with most tests reporting similar AUROC estimates. Twelve93, 98, 102, 112, 117, 125, 129, 156, 160, 176, 198, 200 of fourteen127, 134 studies found the AST/ALT ratio associated with lower AUROCs compared with various other indices (Table 6). Seven93, 112, 117, 124, 156, 200, 204 of nine98, 170 studies found no clear difference in AUROCs for platelet counts compared with various multicomponent indices (Table 7).

Table 5 Aspartate aminotransferase-platelet ratio index compared with Fibrotest

Study, Year | Country | N | Diagnosis | APRI: AUROC (95% CI) | Fibrotest: AUROC (95% CI)
Adler, 2008^92^ | Belgium | 152 | A: Fibrosis (METAVIR F2-F4) B: Severe fibrosis (METAVIR F3-F4) C: Cirrhosis (METAVIR F4) | A: 0.74 (CI not reported) B: 0.89 (CI not reported) C: 0.92 (CI not reported) | A: 0.79 (CI not reported) B: 0.90 (CI not reported) C: 0.92 (CI not reported)
Bourliere, 2006^a,105^ | France | 235 | Fibrosis (METAVIR F2-F4) | 0.71 (0.67 to 0.79) | 0.81 (0.76 to 0.86)
Boursier, 2009^b,106^ | France | 1,056 | A: Severe fibrosis (METAVIR F3-F4) B: Cirrhosis (METAVIR F4) | A: 0.82 (0.79 to 0.85) B: 0.84 (0.80 to 0.88) | A: 0.84 (0.81 to 0.86) B: 0.88 (0.86 to 0.91)
Cales, 2008^b,110^ | France | 1,056 | Fibrosis (METAVIR F2-F4) | 0.79 (CI not reported) | 0.81 (CI not reported)
Castera, 2009^d,228^ | France | 298 | Cirrhosis (METAVIR F4) | 0.80 (0.74 to 0.86) | 0.82 (0.73 to 0.86)
Castera, 2005^114^ | France | 193 | A: Fibrosis (METAVIR F2-F4) B: Severe fibrosis (METAVIR F3-F4) | A: 0.78 (0.70 to 0.85) B: 0.84 (0.78 to 0.89) | A: 0.85 (0.78 to 0.90) B: 0.90 (0.85 to 0.94)
Crisan, 2012^122^ | Romania | 446 | A: Fibrosis (METAVIR F2-F4) B: Severe fibrosis (METAVIR F3-F4) | A: 0.73 (CI not reported) B: 0.74 (CI not reported) | A: 0.78 (CI not reported) B: 0.78 (CI not reported)
Halfon, 2007^a,c,145^ | France | 356 | A: Fibrosis (METAVIR F2-F4) B: Severe fibrosis (METAVIR F3-F4) C: Cirrhosis (METAVIR F4) | A: 0.76 (0.72 to 0.81) B: 0.81 (0.76 to 0.85) C: 0.92 (0.88 to 0.94) | A: 0.79 (0.75 to 0.83) B: 0.81 (0.77 to 0.85) C: 0.86 (0.82 to 0.89)
Leroy, 2008^157^ | France | 825 | A: Fibrosis (METAVIR F2-F4) B: Severe fibrosis (METAVIR F3-F4) C: Cirrhosis (METAVIR F4) | A: 0.79 (0.76 to 0.82) B: 0.84 (0.80 to 0.87) C: 0.86 (0.82 to 0.90) | A: 0.80 (0.77 to 0.83) B: 0.85 (0.82 to 0.88) C: 0.89 (0.86 to 0.92)
Leroy, 2007^c,158^ | France | 180 | A: Fibrosis (METAVIR F2-F4) B: Severe fibrosis (METAVIR F3-F4) | A: 0.81 (0.74 to 0.88) B: 0.82 (0.74 to 0.90) | A: 0.84 (0.79 to 0.90) B: 0.87 (0.81 to 0.93)
Sebastiani, 2008^e,198^ | Italy | 244 (80 normal ALT, 164 elevated ALT) | Fibrosis (METAVIR F2-F4) | Normal ALT: 0.69 (0.54 to 0.85) Elevated ALT: 0.75 (0.65 to 0.85) | Normal ALT: 0.70 (0.59 to 0.81) Elevated ALT: 0.79 (0.74 to 0.84)
Sebastiani, 2006^e,199^ | Italy | 190 | A: Fibrosis (METAVIR F2-F4) B: Cirrhosis (METAVIR F4) | A: 0.69 (0.54 to 0.85) (elevated ALT) and 0.77 (0.63 to 0.91) (normal ALT) B: 0.61 (0.49 to 0.73) (whole sample) | A: 0.81 (0.72 to 0.91) (elevated ALT) and 0.71 (0.49 to 0.92) (normal ALT) B: 0.71 (0.60 to 0.82) (whole sample)
Sebastiani, 2011^200^ | Europe | 1,810 | A: Fibrosis (METAVIR F2-F4) B: Cirrhosis (METAVIR F4) | A: 0.70 (0.65 to 0.75) (whole sample) and 0.63 (0.57 to 0.71) (normal ALT) B: 0.76 (0.71 to 0.81) (whole sample) and 0.65 (0.60 to 0.70) (normal ALT) | A: 0.70 (0.65 to 0.75) (whole sample) and 0.65 (0.60 to 0.70) (normal ALT) B: 0.72 (0.67 to 0.77) (whole sample and 0.65 (0.60 to 0.70) (normal ALT)
Sebastiani, 2012^201^ | Europe | 1,013 | A: Fibrosis (METAVIR F2-F4) B: Cirrhosis (METAVIR F4) | A: 0.70 (0.64 to 0.76) B: 0.77 (0.71 to 0.83) | A: 0.71 (0.64 to 0.78) B: 0.72 (0.67 to 0.77)
Wilson, 2006^219^ | USA | 119 | Ishak 3–4 fibrosis | 0.70 (CI not reported) | 0.74 (CI not reported)
Zarski, 2012^223^ | France | 436 | A: Fibrosis (METAVIR F2-F4) B: Cirrhosis (METAVIR F4) | A: 0.76 (0.72 to 0.81) B: 0.86 (0.81 to 0.91) | A: 0.80 (0.75 to 0.84) B: 0.86 (0.83 to 0.90)

ALT = alanine aminotransferase; APRI = aspartate aminotransferase (AST) to platelets ratio; AUROC = area under the receiver operating characteristic curve; CI = confidence interval

a Evaluated overlapping populations from the FIBROPACA study.

b Evaluated the same population.

c Population included in Cales 2008.

d Incorporated population evaluated in Castera 2005.

e Populations overlap.

Table 6 Aspartate aminotransferase/alanine aminotransferase ratio compared with other indices

Study, Year | Country | N | Diagnosis | AST/ALT Ratio: AUROC (95% CI) | Other Predictive Index: AUROC (95% CI)
Ahmad, 2011^a,93^ | Pakistan | 157 | Cirrhosis (METAVIR F4) | 0.61 (0.48 to 0.74) for cutoff >1, 0.47 (0.38 to 0.56) for cutoff <1 | Platelet count: 0.99 (0.98 to 1.0) Fibrosis to cirrhosis index: 1.0 (0.99 to 1.0) Fibrosis Index: 0.99 (0.98 to 1.0)
Borroni, 2006^102^ | Italy | 228 | Cirrhosis (Knodell F4) | 0.76 (0.68 to 0.84) | Age-platelet index: 0.88 (0.82 to 0.94) APRI: 0.86 (0.79 to 0.93) Cirrhosis Discriminant Score: 0.83 (0.75 to 0.92)
Castera, 2009^b,112^ | France | 298 | Cirrhosis (METAVIR F4) | 0.61 (0.53 to 0.70) | APRI: 0.80 (0.74 to 0.86) Fibrotest: 0.82 (0.73 to 0.86) Lok Index: 0.80 (0.73 to 0.86)
Cheung, 2008^117^ | USA | 490 | A: Fibrosis (Batts-Ludwig F2-F4) B: Severe fibrosis (Batts-Ludwig F3-F4) | A: 0.54 (0.48 to 0.59) B: 0.52 (0.47 to 0.58) | APRI A: 0.69 (0.64 to 0.74); B: 0.76 (0.71 to 0.81) Pohl Index A: 0.52 (0.51 to 0.54); B: 0.53 (0.51 to 0.56)
Cross, 2009^124^ | United Kingdom | 602 (derivation sample) 105 (validation sample) | A: Fibrosis (Ishak ≥3) B: Cirrhosis (Ishak 5–6) | A: 0.58 (0.51 to 0.64) B: 0.68 (0.60 to 0.75) | Age-platelet index A: 0.77 (0.73 to 0.81); B: 0.90 (0.86 to 0.93) APRI A: 0.76 (0.72 to 0.80); B: 0.88 (0.85 to 0.92) Cirrhosis Discriminant Score A: 0.67 (0.62 to 0.72); B: 0.74 (0.68 to 0.81) FIB-4 A: 0.76 (0.68 to 0.83); B: 0.91 (0.89 to 0.94) King's Score A: 0.79 (0.75 to 0.83)^*^; B: 0.91 (0.89 to 0.94)^*^ Pohl Index A: 0.53 (0.46 to 0.59); B: 0.64 (0.55 to 0.73)
Ehsan, 2008^125^ | Egypt | 116 | Cirrhosis (Ishak 5–6) | 0.65 (CI not reported) | Age-platelet index: 0.91 (CI not reported) APRI: 0.86 (CI not reported) Lok Index: 0.88 (CI not reported) Cirrhosis discriminate score: 0.87 (CI not reported) Goteborg University Cirrhosis Index: 0.86 (CI not reported) Pohl Index: 0.66 (CI not reported)
El-Sayed, 2011^127^ | Egypt | 37 | Severe fibrosis (METAVIR F3-F4) | 0.76 (CI not reported) | APRI: 0.63 (CI not reported)
Fabris, 2008^129^ | Italy | 167 | A: Fibrosis (METAVIR F2-F4) B: Cirrhosis (METAVIR F4) | A: 0.59 (0.51 to 0.66) B: 0.66 (0.58 to 0.73) | Age-platelet index A: 0.64 (0.56 to 0.72); B: 0.67 (0.59 to 0.74) APRI A: 0.72 (0.64 to 0.79); B: 0.86 (0.79 to 0.90) Cirrhosis Discriminant Score A: 0.64 (0.56 to 0.71); B: 0.71 (0.64 to 0.78) Fibroindex A: 0.71 (0.63 to 0.77)l; B: 0.86 (0.80 to 0.91) Forns' Index A: 0.70 (0.62 to 0.76); B: 0.86 (0.80 to 0.91)
Giannini, 2003b135 | Italy | 239 | Fibrosis (criteria not reported) | A: 0.82 (CI not reported) B: 0.91 (CI not reported) | APRI A: 0.77 (CI not reported) B: 0.81 (CI not reported)
Ben Jazia, 2009^98^ | Tunisia | 35 | Fibrosis (METAVIR F2-F4) | 0.68 (CI not reported) | APRI: 0.91 (CI not reported)
Lackner, 2005^156^ and Lackner, 2006^224^ | Austria | 194 | A: Fibrosis (Ishak ≥3) B: Cirrhosis (Ishak 5–6) | A: 0.57 (0.48 to 0.65) B: 0.73 (0.63 to 0.83) | Age-platelet index A: 0.74 (0.67 to 0.81); B: 0.91 (0.87 to 0.96) APRI A: 0.80 (0.73 to 0.86); B: 0.90 (0.85 to 0.95) Cirrhosis Discriminant Score A: 0.71 (0.63 to 0.79); B: 0.91 (0.85 to 0.96)
Liu, 2006^160^ | Taiwan | 79 | Fibrosis (METAVIR F2-F4) | A: 0.50 (0.35 to 0.66) | Age-platelet index: 0.64 (0.51 to 0.77) APRI: 0.67 (0.54 to 0.81)
Parise, 2006^176^ | Brazil | 206 | A: Fibrosis (Batts-Ludwig F2-F4) B: Cirrhosis (Batts-Ludwig F4) | A: 0.59 (0.51 to 0.67) B: 0.65 (0.56 to 0.75) | APRI A: 0.82 (0.77 to 0.88) B: 0.84 (0.77 to 0.90)
Sebastiani, 2008^c,198^ | Italy | 244 (80 normal ALT, 164 elevated ALT) | Fibrosis (METAVIR F2-F4) | Normal ALT: 0.51 (0.40 to 0.62) Elevated ALT: 0.54 (0.48 to 0.60) | Normal ALT and elevated ALT, respectively APRI 0.69 (0.54 to 0.85); 0.75 (0.65 to 0.85) Fibrotest 0.70 (0.59 to 0.81); 0.79 (0.74 to 0.84) Forns' Index 0.60 (0.50 to 0.71); 0.76 (0.71 to 0.81) Fibroindex 0.58 (0.43 to 0.73); 0.74 (0.63 to 0.85)
Sebastiani, 2011^200^ | Europe | 1,810 (595 normal ALT) | Cirrhosis (METAVIR F4) | Normal ALT: 0.52 (0.46 to 0.58) | Normal ALT APRI: 0.65 (0.60 to 0.70) Fibrotest: 0.65 (0.60 to 0.70) Lok Index: 0.61 (0.57 to 0.69) Platelet count: 0.64 (0.58 to 0.70)

ALT = alanine aminotransferase; APRI = aspartate aminotransferase (AST) to platelets ratio; CI = confidence interval

a Study reported different AUROCs for the same test and diagnosis.

b Incorporated population evaluated in Castera 2005.

c Populations substantially overlap.

Table 7 Platelet count compared with multicomponent indices

Study, Year | Country | N | Diagnosis | Platelet Count | Other Predictive Index
Ahmad, 2011 a,93 | Egypt | 157 | A: Fibrosis (METAVIR F2-F4) B: Cirrhosis (F4) | A: 0.94 (0.90 to 0.97) B: 0.99 (0.98 to 1.0) | Fibrosis-cirrhosis index A: 0.93 (0.90 to 0.97) B: 1.0 (0.99 to 1.0) APRI A: 0.88 (0.78 to 0.97) for cutoff >1.5, 0.72 (0.64 to 0.780) for cutoff <0.5 Fibrosis Index A: 0.94 (0.90 to 0.97) B: 0.99 (0.98 to 1.0) AST/ALT ratio B: 0.61 (0.48 to 0.74) for cutoff >1, 0.47 (0.38 to 0.56) for cutoff <1
Castera, 2009^b,228^ | France | 298 | Cirrhosis (METAVIR F4) | 0.79 (0.72 to 0.85) | APRI: 0.80 (0.74 to 0.86) AST/ALT ratio: 0.61 (0.53 to 0.70) Fibrotest: 0.82 (0.73 to 0.86) Lok Index: 0.80 (0.73 to 0.86)
Cheung, 2008^117^ | USA | 490 | A: Fibrosis (Batts-Ludwig F2-F4) B: Severe fibrosis (Batts-Ludwig F3-F4) | A: 0.60 (0.56 to 0.63) for <150; 0.52 (0.51 to 0.53) for <100^ B: 0.64 (0.60 to 0.68) for <150; 0.53 (0.52 to 0.55) for <100^ | APRI A: 0.69 (0.64 to 0.74); B: 0.76 (0.71 to 0.81) AST/ALT ratio A: 0.54 (0.48 to 0.59); B: 0.52 (0.47 to 0.58) Pohl Index A: 0.52 (0.51 to 0.54); B: 0.53 (0.51 to 0.56)
Cross, 2009^124^ | United Kingdom | 602 (derivation sample) 105 (validation sample) | A: Fibrosis (Ishak ≥3) B: Cirrhosis (Ishak 5–6) | A: 0.66 (0.60 to 0.72) B: 0.88 (0.85 to 0.91) | Age-platelet index A: 0.77 (0.73 to 0.81); B: 0.90 (0.86 to 0.93) APRI A: 0.76 (0.72 to 0.80); B: 0.88 (0.85 to 0.92) AST/ALT ratio A: 0.58 (0.51 to 0.64); B: 0.68 (0.60 to 0.75) Cirrhosis Discriminant Score A: 0.67 (0.62 to 0.72); B: 0.74 (0.68 to 0.81) FIB-4 A: 0.76 (0.68 to 0.83); B: 0.91 (0.89 to 0.94) King's Score A: 0.79 (0.75 to 0.83)^*^; B: 0.91 (0.89 to 0.94)^*^ Pohl Index A: 0.53 (0.46 to 0.59); B: 0.64 (0.55 to 0.73)
Ben Jazia, 2009^98^ | Tunisia | 35 | Fibrosis (METAVIR F2-F4) | 0.38 (CI not reported) | APRI: 0.91 (CI not reported) AST/ALT ratio: 0.68 (CI not reported)
Lackner, 2005^156^ and Lackner, 2006^224^ | Austria | 194 | A: Fibrosis (Ishak ≥3) B: Cirrhosis (Ishak 5–6) | A: 0.71 (0.64 to 0.79) B: 0.89 (0.83 to 0.94) | Age-platelet index A: 0.74 (0.67 to 0.81); B: 0.91 (0.87 to 0.96) APRI A: 0.80 (0.73 to 0.86); B: 0.90 (0.85 to 0.95) AST/ALT ratio A: 0.57 (0.48 to 0.65); B: 0.73 (0.63 to 0.83) Cirrhosis Discriminant Score A: 0.71 (0.63 to 0.79); B: 0.91 (0.85 to 0.96)
Myers, 2003^c,170^ | France | 323 | A: Fibrosis (METAVIR F2-F4) B: Severe fibrosis (METAVIR F3-F4) | A: 0.67 (0.64 to 0.70) B: 0.74 (0.70 to 0.78) | Age-platelet index A: 0.72 (0.69 to 0.75); B: 0.81 (0.78 to 0.84) Fibrotest A: 0.84 (0.82 to 0.86); B: 0.92 (0.90 to 0.94)
Sebastiani, 2011^200^ | Europe | 1,810 (595 normal ALT) | Cirrhosis (METAVIR F4) | Normal ALT subgroup: 0.64 (0.58 to 0.70) | Normal ALT subgroup APRI: 0.65 (0.60 to 0.70) Fibrotest: 0.65 (0.60 to 0.70) AST/ALT ratio: 0.52 (0.46 to 0.58) Lok Index: 0.61 (0.57 to 0.69)
Sirli, 2010^204^ | Romania | 150 | A: Fibrosis (METAVIR F2-F4) B: Cirrhosis (METAVIR F4) | A: 0.73 (0.65 to 0.80) B: 0.90 (0.84 to 0.94) | APRI A: 0.77 (0.69 to 0.83) B: 0.91 (0.85 to 0.95) Forns’ Index A: 0.75 (0.67 to 0.82) B: 0.91 (0.85 to 0.95) Lok Index A: 0.70 (0.62 to 0.77) B: 0.87 (0.81 to 0.92) FIB-4 A: 0.69 (0.60 to 0.76) B: 0.84 (0.77 to 0.90)

APRI = aspartate aminotransferase (AST) to platelets ratio; AST/ALT = aspartate aminotransferase–alanine aminotransferase; CI = confidence interval

a Study reported different AUROCs for the same test and diagnosis.

b Incorporated population evaluated in Castera 2005.

c Evaluated same population.

Three studies found no clear differences between blood tests compared with imaging findings based on the AUROC (Table 8).119, 196, 209

Table 8 Blood tests compared with imaging

Study, Year | Country | N | Proportion with Fibrosis or Cirrhosis | Population Characteristics | Diagnosis | APRI: AUROC (95% CI) | Imaging Findings: AUROC (95% CI)
Cobbold, 2009^229^ | UK | 67 | Fibrosis (Ishak ≥3): 55% Cirrhosis (Ishak 5 or 6): 21% | Age: 50 years Female: 34% Genotype 1: Not reported No current antiviral treatment Excluded if >20 g alcohol/day | A: Fibrosis (Ishak ≥3) B: Cirrhosis (Ishak 5–6) | APRI A: 0.83 (0.73 to 0.93) B: 0.86 (0.75 to 0.97) ELF Index A: 0.82 (0.73 to 0.92) B: 0.91 (0.82 to 1.0) | Hepatic transit time A: 0.71 (0.59 to 0.84) B: 0.83 (0.69 to 0.97)
Schneider, 2006^196^ | Germany | 83 | Fibrosis (Ishak ≥3): 57% Cirrhosis (Ishak 5 or 6): 23% | Age: 48 years Female: 51% Genotype 1: 84% | Cirrhosis (Ishak 5–6) | APRI: 0.71 (CI not reported) | Portal venous flow: 0.80 (CI not reported)
Testa, 2006^209^ | Italy | 75 | Fibrosis (Ishak ≥3): 49% Cirrhosis (Ishak 5 or6): 12% | Age: 50 years Female: 32% Genotype 1b: 43% All elevated aminotransferases No alcohol abuse | Fibrosis (Ishak ≥3) | Fibrosis (Ishak ≥3) APRI: 0.72 (0.60 to 0.82) | Platelet-spleen diameter ratio: 0.74 (0.63 to 0.84) Fibrosis model 1: 0.80 (0.69 to 0.88)^a^

APRI = aspartate aminotransferase (AST) to platelets ratio; AUROC = area under the receiver operating characteristic curve; CI = confidence interval

a Based on sample used to derive the risk prediction instrument.

## Key Question 4b What proportion of patients with screen-detected HCV infection receives treatment?

- Three intervention series reported that 15 to 33 percent of patients with screen-detected chronic HCV infection received treatment (strength of evidence: moderate).

Three longitudinal intervention series (n=449, 5,646, and 12,485) evaluated the proportion of screen-detected patients with HCV infection who received treatment (Table 9, Evidence Table 7, Appendix G).230–232 Two studies were conducted in (different) Veterans Affairs (VA) centers230, 232 and one evaluated a non-VA population of active and former drug users.231 The proportions of HCV-antibody-positive patients who were viremic ranged from 58 to 76 percent, and the proportions of viremic patients who received treatment ranged from 15 to 33 percent. One factor that could confound estimates of treatment rates is differences in how patients were assessed as eligible for treatment. For example, one of the studies classified patients with genotype 1 or 4 HCV infection and less than moderate fibrosis as ineligible for treatment,231 but another232 did not describe genotype as a treatment eligibility consideration. In addition, although both studies reported general medical or psychiatric contraindications as reasons for ineligibility, specific contraindications were not well described. In the two studies, the proportion of viremic patients categorized as eligible for treatment were 57 and 71 percent. The third study did not report reasons for treatment ineligibility.230 Other challenges in interpreting these studies included failure to report liver biopsy protocols and use of poorly defined and standardized eligibility criteria (which were applied retrospectively in one study232).

Table 9 Proportion of screened patients who were treated

Author, Year Country | Study Population Number Screened Study Design | Number HCV Antibody Positive | Proportion HCV Antibody Positive who were Viremic | Proportion Viremic who Received Treatment | Proportion Viremic Classified as Eligible for Treatment | Reasons for Ineligibility: Percent (n) | Proportion Classified as Eligible for Treatment who Received Treatment
Groom, 2008^230^ USA | Veterans Affairs patients who tested positive for anti-HCV antibody by risk-based screening n=12,385 Retrospective intervention series | 681 | 76% (520/681) | 24% (124/520) | Not reported | Not reported | Not reported
Lindenburg, 2011^231^ The Netherlands | Active and former drug users who tested positive for anti-HCV antibody n=449 Prospective intervention series | 267 | 64% (134/208, HIV-negative); 84/134 completed further screening | 33% (44/134) | 71% (60/84) | Medical, social, or psychiatric contraindication: 33% (8) Genotype 1 or 4 with less than moderate fibrosis on liver biopsy (treatment postponed): 67% (16) | 73% (44/60)
Mallette, 2008^232^ USA | Veterans Affairs patients who tested positive for anti-HCV antibody by risk-based screening n=5,646 Retrospective intervention series | 260 (newly diagnosed) | 58% (122/211) | 15% (18/122) | 57% (70/122) | Ongoing substance or alcohol abuse: 24% (29) Major medical contraindication: 7.4% (9) Severe psychiatric disease: 6.6% (8) Refused further evaluation: 4.9% (6) | 26% (18/70)

HCV = hepatitis C virus

## Key Question 5 What are the harms associated with the workup for guiding treatment decisions?

- One study (n=2,740) of patients with chronic HCV infection and compensated cirrhosis with an Ishak fibrosis score of ≥3 reported serious adverse events in 1.1 percent of patients, including 0.6 percent serious bleeds and 0.3 percent severe pain, with no deaths. Five large (n=1,398 to 61,184) interventions series published since 2004 of patients undergoing percutaneous liver biopsy for a variety of reasons reported peri-procedural mortality in <0.2 percent and serious complications in 0.3 to 1.0 percent (strength of evidence: moderate).

Few studies evaluated harms associated with liver biopsy specifically in HCV-infected patients. One study of 2,740 percutaneous liver biopsies in HCV-infected patients with compensated cirrhosis and an Ishak fibrosis score of 3 or greater reported 29 serious adverse events (defined as complications requiring hospitalization, additional costly investigations, blood transfusion, or complications that led to perforation of an organ, surgery, or death), for a rate of 1.1 percent.233 The most common serious adverse event was bleeding (16 cases), followed by severe pain (seven cases). No deaths occurred. Predictors of bleeding were platelet count <60,000/mm^3^ and INR >1.3. Patients with platelet counts <60,000/mm^3^ accounted for 25 percent (4 of 16) cases, but only 2 percent of biopsies. Most biopsies (80 percent) were performed with bedside ultrasound guidance. There was no clear association between use of ultrasound guidance, operator experience, or type of needle used and risk of complications. Two other small studies (n=126 and 166) included in the 2004 USPSTF review reported no episodes of bleeding, perforation, or death following percutaneous liver biopsy in patients with HCV infection, including those with known or suspected cirrhosis.192, 234 No study of percutaneous liver biopsies specifically examined asymptomatic patients with chronic HCV who may be at lower risk for complications.

In patients undergoing liver biopsy for a variety of reasons, large series (n=1,398 to 61,184) published since 2004 reported peri-procedural mortality rates of 0 to 0.2 percent.235–239 Major complications (primarily bleeding) occurred after 0.3 to 1.0 percent of biopsies. The largest study (n=61,184) reported substantially higher mortality risk in patients with cancer as the indication for biopsy (1.2 percent) compared with those undergoing biopsy for other indications (≤0.01 percent).239 It also found use of image guidance associated with slightly increased risk of complications, perhaps due to tendency towards increased use in more complicated patients. One study reported minor complications following 14 percent of biopsies.238 Another study reported that 30 percent of patients who underwent liver biopsy experienced pain requiring strong analgesic medications.240

The newer studies were consistent with earlier studies that reported mortality rates of <0.1 percent and major complications in 0 to 3.7 percent of patients undergoing liver biopsy for a variety of reasons.241–247 Older studies comparing blind with ultrasound-guided biopsy have generally reported higher risk for complications with the blind technique.248

## Key Question 6a How effective is counseling or immunization of patients with HCV infection at improving health outcomes or reducing the spread of HCV?

- One randomized trial found a self-management program associated with slight improvements in SF-36 vitality scores compared with provision of educational materials after 6 weeks, but there were no effects on other measures of generic or HCV-related quality of life (strength of evidence: insufficient).
- No study evaluated effects of immunizations of patients with HCV infection on health outcomes (strength of evidence: insufficient).

One randomized trial of HCV-infected VA patients (n=137) found a self-management program based on cognitive-behavioral principles that included information dissemination, problem solving, and development and re-evaluation of action plans (six weekly sessions, 2 to 2.5 hours each) associated with slightly greater improvements in SF-36 vitality scores after 6 weeks (mean change -2.1 vs. 4.6, p=0.040) compared with provision of educational materials (Evidence Table 8, Appendix G).249 There were no differences in other SF-36 scores or measures of depression, global health status, or HCV-specific quality of life. The trial was rated fair quality due to failure to describe allocation concealment and failure to blind outcome assessors/data analysts (Evidence Table 9, Appendix G).

No study evaluated the effect of counseling regarding alcohol consumption or the effect of formal alcohol treatment programs after diagnosis of HCV on subsequent clinical outcomes such as cirrhosis and related complications. No study evaluated effects of counseling regarding risky behaviors on transmission rates from patients with HCV infection or estimated rates of transmission from patients with HCV infection aware of their status compared with those not aware of their status.

No study evaluated the effect of immunization for hepatitis A virus (HAV) or HBV infection after diagnosis of HCV on subsequent clinical outcomes or estimated risk of serious HAV or HBV infection in patients with HCV infection aware of their serostatus compared with those unaware of their status. Although evidence described in the 2004 USPSTF review showed high rates of protective seroconversion following HAV and HBV vaccination in patients with HCV infection, they were not designed to assess subsequent clinical outcomes.250

## Key Question 6b Does becoming aware of positive HCV infection status decrease high-risk behaviors?

- Three retrospective studies reported substantial reductions in alcohol use following diagnosis of HCV infection, but two prospective studies found no evidence of sustained reductions in high-risk behaviors (alcohol use or injection drug use behaviors) following diagnosis. Results from two cross-sectional studies were mixed (strength of evidence: low).

Five studies compared self-reported behaviors in patients before and after becoming aware of their positive HCV status.88, 251–254 Two cross-sectional studies compared self-reported behaviors in HCV-positive infected patients aware and unaware of their status.42, 255 All of the studies relied on patient self-report to assess behaviors.

Two prospective before-after studies found no evidence of sustained reductions in high-risk behaviors following diagnosis of HCV infection.252, 254 A study of young (<30 years old), HCV-negative injection drug users (n=112) who underwent quarterly testing reported decreased likelihood of self-reported alcohol use (OR 0.51, 95% CI 0.27 to 0.97) immediately after becoming aware of seroconversion compared with before becoming aware of their status, but effects were not sustained after 6 or 12 months (OR 0.84, 95% CI 0.42 to 1.6).254 There was no significant effect on likelihood of injection drug use, lending or sharing of injecting equipment, or unprotected intercourse at any time. Another prospective study, included in the 2004 review,44 found no significant reduction in high-risk behaviors (such as backloading or sharing needles, syringes, or other injection paraphernalia) in young (age 15 to 30 years) injection drug users (n=46) 6 months after notification of positive HCV infection status compared with behaviors prior to testing.252 For example, 17 percent of patients reported no change in needle sharing, 17 percent reported an increase, and 11 reported percent a decrease. There was also no change in reported alcohol consumption.

Three retrospective before-after studies reported substantial reductions in risky behaviors following diagnosis of HCV infection.88, 251, 253 Due to their retrospective design, such studies may be more susceptible to recall bias. One study of 275 HCV-positive patients found that of the 153 subjects reporting alcohol use at the time of diagnosis, 58 percent reported giving up alcohol and another 16 percent reported reducing alcohol use a median of 5 years following diagnosis.253 Another study of patients who were surveyed 1 to 3 years after diagnosis with chronic HCV infection found that 85 percent (28/33) who drank at the time of screening reported decreased alcohol use, with 64 percent (21/33) reporting abstinence.88 Of the seven injection drug users at the time of diagnosis, four reported no injection drug use. A French observational study included in the 2003 review found that out of 25 patients who reported “excessive” alcohol consumption prior to HCV diagnosis, 9/25 reported that they had become completely abstinent and 14/25 reported cutting back to “moderate” intake.251

Two cross-sectional studies that compared risky behaviors of HCV-positive patients aware of their status compared with HCV-positive patients unaware of their status reported inconsistent results.42, 255 One study found HCV-positive injection drug users unaware of their positive status (n=97) more likely than those aware (n=39) to use a previously used needle (59 vs. 28 percent, p<0.001), share drug paraphernalia (70 vs. 53 percent, p<0.05), and report not always injecting safely (63 vs. 44 percent, p<0.05).255 However, another study of young (15–30 years of age) injection drug users found no significant difference in the number of injection partners or reported alcohol use between those aware of their HCV-positive status (n=288), those who thought they were negative (n=414), and those who did not know their status (n=331).42

## Key Question 6c How effective is counseling and immunization of patients with HCV infection at improving intermediate outcomes, including change in high-risk behaviors?

- Two randomized trials reported somewhat mixed results regarding effects of counseling interventions based on behavioral principles compared with simple educational interventions, though one trial that trained patients to serve as peer mentors reported sustained absolute decreases of about 15 percent in the proportion engaging in risky injection drug behaviors. Two before-after studies of HCV-infected heavy drinkers following found 36 to 44 percent reported abstinence 6 to 22 months after a counseling intervention. No study evaluated intermediate outcomes associated with immunizations in patients with HCV infection (strength of evidence: insufficient).

Two randomized trials256, 257 and one before-after study258 evaluated effects of counseling interventions in patients with HCV infection (Evidence Table 8, Appendix G). Both trials were rated fair quality (Evidence Table 9, Appendix G). Shortcomings included failure to describe adequate allocation concealment methods,256, 257 baseline differences between randomized groups,257 and high loss to followup.256, 257 Due to the nature of the interventions, patients and care providers could not be blinded. Neither trial blinded outcome assessors.

One trial of HCV-infected injection drug users (n=418) evaluated effects of a behavioral intervention that trained drug users to be peer mentors regarding safer injecting practices compared with participation in a video discussion control group.256 The trial was based on the hypothesis that training to be a peer mentor would positively impact injection drug behaviors in the mentors through education, discussion, and self-modeling of safer behaviors, and reinforce such behavior by providing a more positive social identity. It found the behavioral intervention associated with decreased risk of self-reported distributed risk behaviors (lending used syringes, sharing drug preparation equipment, or dividing drugs with syringe used by oneself) at 3 months (44 vs. 59 percent, adjusted OR 0.46, 95% CI 0.27 to 0.79) and 6 months (37 vs. 53 percent, adjusted OR 0.51, 95% CI 0.31 to 0.83), with the difference mainly attributable to a decrease in frequency of sharing drug preparation equipment (41 vs. 55 percent at 3 months and 35 vs. 47 percent at 6 months). The intervention was also associated with increased likelihood of refraining from injection drug use (24 vs. 10 percent at 3 months, adjusted OR 3.6, 95% CI 1.6 to 7.8 and 34 vs. 23 percent at 6 months, adjusted OR 1.6, 95% CI 0.96 to 2.7).

A trial of 851 injection drug users, about half of whom had HCV infection, found that a motivational intervention (based on motivational interviewing techniques) was associated with an overall lower likelihood of alcohol use at 6-month followup compared with an educational intervention (OR 0.67, 95% CI 0.46 to 0.97), but there was no effect in the subgroup of HCV-positive patients (OR 0.94, 95% CI 0.64 to 1.4).257 There was also no effect on safer injecting practices or condom use.

A small (n=47) before–after study of heavy drinkers with HCV infection found that 62 percent reported alcohol intake reduced by greater than 50 percent compared to baseline at 8- to 22-month followup after receiving brief outpatient clinic alcohol counseling intervention followed by psychiatric nurse followup, including 36 percent who reported abstinence.258 Another small (n=53) before-after study of heavy drinkers reported alcohol abstinence in 44 percent at the end of a 6-month individualized alcohol counseling intervention.259

## Key Question 7 Do any interventions decrease or increase the vertical transmission of HCV during delivery or in the perinatal period?

- Four observational studies (two good quality) totaling 2,080 mother-infant pairs specifically compared rates of transmission among women who delivered by elective cesarean compared with vaginal or emergent cesarean delivery. The two good-quality studies found no statistically significant difference in risk of vertical transmission of HCV infection (strength of evidence: low).
- Ten of 11 observational studies (one good quality) found no statistically significant difference in risk of vertical transmission of HCV infection following vaginal compared with cesarean (not specified if elective or emergent) delivery (strength of evidence: moderate).
- Three observational studies (two good quality) found inconsistent evidence on the association between internal fetal monitoring and the risk of vertical transmission of HCV infection (strength of evidence: insufficient).
- Two studies (one good quality) found an association between prolonged labor after membrane rupture and risk of vertical transmission of HCV infection. The good-quality study reported membrane rupture >6 hours associated with an adjusted OR of 9.3 for vertical transmission (95% CI 1.5 to 180) (strength of evidence: low).
- Fourteen observational studies (two good quality) consistently found no association between breastfeeding and risk of vertical transmission of HCV infection (strength of evidence: moderate).

### Mode of Delivery

Fourteen observational studies (reported in 16 publications) with a range of 56 to 1034 mother-infant pairs evaluated the association between mode of delivery and vertical transmission of HCV (Tables 10 and 11, Evidence Table 10, Appendix G).51, 52, 260–273 Two reports from the European Pediatric Hepatitis C Network evaluated overlapping patient populations260, 261 and two studies evaluated nonoverlapping (different time periods of enrollment) patient populations in Dublin, Ireland.264, 266 Nine studies were conducted in Europe,51, 260, 261 262, 264–266, 268, 270, 272, 273 two in Australia,263, 269 two in Japan,267, 271 and one in the United States52. Two studies were good quality52, 260, 261, four studies were fair quality51, 264, 266, 268, and the remainder were poor quality (Evidence Table 11, Appendix G). Only four studies performed statistical analysis on potential confounders;51, 52, 260,261, 264 no study reported baseline characteristics according to mode of delivery or matched women on key potential confounders.

Table 10 Hepatitis C virus transmission by mode of delivery: Elective cesarean compared with emergent cesarean or vaginal delivery

Author, Year Quality | N | Elective Cesarean | Vaginal/Emergent Cesarean | Comments/Results^d^ (95% CI)
Gibb, 2000 Fair264 | 424^b^ | 0/31 (0%) | 29/393 (7.4%) | OR 0 (0 to 0.87), p=0.04, adjusted for HIV status and breastfeeding
Mast, 2005^52^ Good | 181^a^ | 0/12 (0%) | 7/169 (4.1%) | RR 0.87 (0.05 to 14)
McMenamin, 2008^266^ Fair | 441^c^ | 1/33 (3.0%) | 17/408 (4.2%) | RR 0.73 (0.09 to 5.30)
EPHN (Tovo), 2005^260^ Good | 1,034^a^ | NR | NR | OR 1.57 (0.88 to 2.83), p=0.13, unadjusted OR 1.59 (0.88 to 2.86), p=0.13 adjusted for sex, mode of delivery, prematurity, and breastfeeding
Total | 2,080

OR = odds ratio; RR = relative risk

a 0% HIV coinfected.

b 5% HIV coinfected.

c 5.9% HIV coinfected.

d Unadjusted unless otherwise indicated.

Table 11 Hepatitis C virus transmission by mode of delivery: Cesarean (elective or emergent) compared with vaginal delivery

Author, Year Quality | N | Cesarean | Vaginal | Comments/Results^d^ (95% CI)
Ceci, 2001^51^ Fair | 78^a^ | No association (data NR) | No association (data NR) | NR
Conte, 2000^262^ Poor | 365^b^ | 1/106 (0.9%) | 7/259 (2.7%) | RR 0.35 (0.04 to 2.80)
Garland, 1998^263^ Poor | 83^a^ | 0/22 (0%) | 3/61 (4.9%) | RR not calculated
La Torre, 1998^265^ Poor | 80^a^ | 1/14 (7%) | 1/66 (1.5%) | RR 4.71 (0.31 to 70.94)
Okamoto, 1999^267^ Poor | 59^a^ | 0/18 (0%), 0/10 (0%) in women with high viral load | 7/41 (17%), 7/16 (44%) in women with high viral load | RR not calculated, p=0.089, p=0.023 in women with high viral load
EPHN (Pembrey), 2001^261^ Good | 884^a^ | 15/218 (6.9%) | 39/666 (5.9%) | OR 1.17 (0.59 to 2.31), adjusted for breastfeeding, maternal age at delivery, center category
Resti, 1998^268^ Fair | 275^a^ | 4/62 (6.5%) | 9/213 (4.2%) | RR 1.53 (0.48 to 4.79)
Spencer, 1997^269^ Poor | 63^a^ | 1/7 (14%) | 5/55 (9.1%) | RR 1.57 (0.21 to 11.6)
Syriopoulou, 2005^270^ Poor | 56^c^ | 0/17 (0%) | 2/39 (5.1%) | RR, not calculated, p=0.34
Tajiri, 2001^271^ Poor | 114^a^ | 1/24 (4.2%) | 8/90 (8.8%) | RR 0.46 (0.61 to 3.53)
Zanetti, 1998^273^ and 1999^272^ Poor | 251^a^ | 1/58 (1.7%) | 7/193 (3.6%) | RR 0.48 (0.06 to 3.79)
Total | 2,308

NR = not reported; OR = odds ratio; RR = relative risk

a 0% HIV coinfected.

b 4% HIV coinfected.

c 2% HIV coinfected.

d Unadjusted unless otherwise indicated.

Four studies,52, 260, 264, 266 totaling 2,080 mother-infant pairs (two good quality52, 260) compared the risk of transmission following elective cesarean delivery prior to the onset of labor with risk of transmission in women who went into labor and delivered vaginally or by emergency cesarean (Table 10). Three studies52, 264, 266 reported trends towards higher transmission following vaginal or emergent cesarean delivery, but the difference was only statistically significant in one fair-quality study.264 It reported no cases of transmission following elective cesarean, compared with 7.4 percent following vaginal or emergency cesarean delivery (adjusted OR 0, 95% CI 0 to 0.87).264 One good quality-study reported a rate of vertical transmission of 4.1 percent (7/169) following vaginal or emergent cesarean, compared with no cases following 12 elective cesarean births (RR 0.87, 95% CI 0.05 to 14).52 The other good-quality study, which also evaluated the largest sample (1,034 HCV-positive, HIV-negative mother-infant pairs, or larger than the other three added together), reported the opposite trend, towards increased risk of vertical transmission following elective cesarean compared with vaginal or emergency cesarean (adjusted OR 1.6, 95% CI 0.88 to 2.9).260

Eleven studies totaling 2,308 mother-infant pairs compared the risk of vertical transmission following vaginal with cesarean deliveries, without specifying whether the cesarean delivery was elective or emergent (Table 11).51, 261–264, 266, 268–273 Ten of the 11 studies (one good quality261) found no association between mode of delivery and risk of HCV transmission.51, 261–263, 265, 268–273 The exception was one small (n=59) Japanese prospective cohort study (poor quality) in which there was a trend towards increased risk of vertical transmission following vaginal compared with cesarean delivery (17 vs. 0 percent, p=0.09), with a statistically significant difference in the subgroup of mothers with a high viral load (≥2.5 × 10^6^ copies/mL).267

### Labor Management

#### Rupture of Membranes

One good-quality study52 and one fair-quality study,269 (total 245 mother-infant pairs) found more prolonged rupture of membranes associated with higher risk of transmission (Table 12). The good-quality study reported greater risk of vertical transmission in women with membrane rupture longer than 6 hours (OR 9.3, 95% CI 1.5 to 180).52 The poor-quality study reported longer average duration of membrane rupture in women who transmitted the virus to the infant compared with those who didn’t (28 vs. 16 hours, p=0.03).269

Table 12 Labor management: Transmission by duration of membrane rupture

Author, Year Quality | N | Duration of Membrane Rupture | Comments/Results (95% CI)
Mast, 2005^52^ Good | 182^a^ | <1 vs. 1–5 vs. 6–12 vs. ≥13: 0/53 vs. 1/59 (1.7%) vs. 4/40 (10%) vs. 2/30 (6.7%), p=0.02 | Membrane rupture >6 hours OR, 9.3 (1.5 to 179.7), adjusted for maternal demographic characteristics, HCV RNA level, fetal monitoring, history of IVDU, and cigarette smoking during pregnancy.
Spencer, 1997^269^ Poor | 63^a^ | Mean hours (± SD), transmitted vs. not transmitted: 28±10 vs. 16±4, p=0.03 | All mothers were viremic.
Total | 245

CI = confidence interval; IVDU = intravenous drug use; HCV = hepatitis C virus; OR = odds ratio

a 0% HIV coinfected.

#### Fetal Monitoring

Three studies (two good quality52, 261 and one poor quality266) reported conflicting findings regarding the association between use of fetal monitoring and risk of vertical transmission (Table 13). One of the good-quality studies (n=181)52 found a greater risk of vertical transmission associated with internal fetal monitoring (adjusted OR 6.7, 95% CI 1.1 to 36) but the other (n=724)261 found no association. The study266 rated poor quality also found no association between fetal monitoring and risk of vertical transmission, but only tested 11 of 23 infants who had scalp electrodes during delivery, none of whom were found to be HCV-positive.

Table 13 Labor management: Transmission by fetal monitoring

Author, Year Quality | N | Fetal Monitoring During Delivery | Comments/Results^c^ (95% CI)
Mast, 2005^52^ Good | 181^a^ | Internal vs. external: 3/16 (18.8%) vs. 4/165 (2.4%), | RR 7.7 (1.9 to 31.6), p=0.02, unadjusted Internal fetal monitoring, OR 6.7 (1.1 to 35.9), adjusted for maternal demographic characteristics, HCV RNA level, history of IVDU, and cigarette smoking during pregnancy.
McMenamin, 2008^266^ Fair | 23^b^ | Infant HCV RNA+: 0/11 (0%) Infant not tested for HCV: 12 | RR not calculated
European Paediatric Hepatitis C Virus Network (Pembrey), 2001^261^ Good | 724^a^ | Yes vs. no: 11/93 (11.8%) vs. 58/631 (9.2%) | RR 1.24 (95% CI 0.70 to 2.20)
Total | 928

CI = confidence interval; IVDU = intravenous drug use; HCV = hepatitis C virus; OR = odds ratio; RR = relative risk

a 0% HIV coinfected.

b 5.9% HIV coinfected in overall sample of 441.

c Unadjusted unless otherwise indicated.

### Breastfeeding

Fourteen cohort studies totaling 2,971 mother-infant pairs found no association between breastfeeding and increased risk of HCV infection in infants of HCV-infected mothers (Table 14, Evidence Table 10, Appendix G).52, 260–265, 268–279 The majority of studies followed HCV-positive mothers and their infants prospectively and observed the infants for at least 1 year. Sample sizes ranged from fewer than 50^275, 276, 278^ to more than 1,000 mother-infant pairs260. Two of the studies were rated good quality,52, 260 two were fair quality,264, 268 and 10 were poor quality.262, 265, 269–273, 275, 276, 278, 279

Table 14 Transmission by type of infant feeding

Author, Year Quality | N | Breast Fed | Formula Fed | Comments/Results^e^ (95% CI)
Conte, 2000^262^ Poor | 370^b^ | 2/90 (2.2%) | 6/280 (2.1%) | RR 1.02 (.305 to 3.45)
Gibb, 2000^264^ Fair | 414^c^ | 7.7% (2.2 to 17.8) | 6.7% (3.7 to 10.6) | OR 1.52 (0.35 to 5.12), adjusted for HIV status and mode of delivery
La Torre, 1998^265^ Poor | 80^a^ | 0/10 (0%) | 2/46 (4.3%) | RR not calculated.
Lin, 1995^275^ Poor | 15^a^ | 0/11 (0%) | 0/4 (0%) | RR not calculated
Mast, 2005^52^ Good | 182^a^ | 2/62 (3.2%) | 5/120 (4.2%) | RR 0.8 (0.2 to 3.9)
Moriya, 1995^279^ Poor | 74^a^ | Not applicable (case control design) | Not applicable (case control design) | 5/6 infected (83%) vs. 54/68 uninfected (79%) were breast fed; OR 1.3 (0.14 to 12.0)
Pipan, 1996^276^ Poor | 25^a^ | 0/6 (0%) | 0/19 (0%) | RR not calculated
Resti, 1998^268^ Fair | 275^a^ | 6/87(6.9%) | 7/188(3.7%) | RR 1.85 (0.64 to 5.35), p=0.36
Spencer, 1997^269^ Poor | 63^a^ | 2/33 (6.0%) | 4/30 (13%) | RR 0.45 (0.09 to 2.31) Viral RNA detected in breast milk: 0/38 (0%)
Syriopoulou, 2005^270^ Poor | 56^d^ | 0/15 (0%) | 2/41 (4.9%) | RR not calculated, p=0.38
Tajiri, 2001^271^ Poor | 114^a^ | 9/98 (9.2%) | 0/16 (0%) | RR not calculated, p=0.24
Tanzi, 1997^278^ Poor | 18^a^ | 0% | 0% | RR undefined
EPHN (Tovo), 2005^260^ Good | 1034^a^ | Not reported | Not reported | OR 0.88 (0.48 to 1.61), unadjusted OR 0.92 (0.50 to 1.70), adjusted for sex, prematurity, and mode of delivery
Zanetti, 1998^273^ and 1999^272^ Poor | 251^a^ | 3/127 (2.4%) | 5/124 (4.0%) | RR 0.59 (0.14 to 2.40)
Total | 2,971

HCV = hepatitis C virus; OR = odds ratio; RR = relative risk

a 0% HIV coinfected.

b 4% HIV coinfected.

c 5% HIV coinfected.

d 2% HIV coinfected.

e Unadjusted unless otherwise indicated.

Methodological shortcomings in the poor-quality studies included failure to perform statistical adjustment on potential confounders and insufficient information to determine comparability of groups at baseline stratified by breastfeeding status.

The finding of no significant association between breastfeeding and risk of transmission was consistent across studies, regardless of sample size, adjustment for confounders, or overall quality.