# Introduction

Hepatitis C virus (HCV) is a single-stranded, positive-sense RNA virus of the family Flaviviridae. HCV is the most common chronic blood borne pathogen in the United States. The prevalence of anti-HCV antibody in the United States is estimated at 1.6 percent.1 Approximately 78 percent of those who test positive for anti-HCV antibody have the HCV detectable in the blood (viremia), indicating chronic infection;1 those with anti-HCV antibody but no viremia are considered to have cleared the infection. About two-thirds of patients with HCV infection were born between 1945 and 1964, with the highest prevalence (4.3 percent) in people 40 to 49 years of age in 1999–2002.^1^ The prevalence of chronic HCV infection is thought to have peaked in 2001 at 3.6 million people.2 The yearly incidence of HCV infection averaged more than 200,000 cases per year in the 1980s, but by 2001 had declined to around 25,000 cases per year.3 The Centers for Disease Control and Prevention (CDC) estimated 16,000 new cases of HCV infection in 2009.^4^

HCV infection is a leading cause of complications from chronic liver disease and was associated with an estimated 15,000 deaths in the United States in 2007.^5^ One study estimated that the total number of patients with cirrhosis will peak at 1.0 million in 2020, though rates of hepatic decompensation and liver cancer are expected to continue to rise for another 10 to 13 years, given the long lag time between infection and development of cirrhosis and other complications.2 HCV-related end-stage liver disease is the most common indication for liver transplantation among American adults, accounting for more than 30 percent of cases, with a 5-fold increase in the number of patients with HCV who underwent liver transplantation between 1990 and 2000.^6, 7^ Studies suggest that about half of the recently observed increase in incidence of hepatocellular carcinoma is related to acquisition of HCV infection 2–4 decades earlier.8 HCV infection without cirrhosis may be associated with symptoms such as fatigue and worse quality of life compared with the general population.9–13

HCV is primarily acquired via percutaneous exposures to infected blood. The strongest risk factor for HCV infection is injection drug use. The prevalence of HCV infection in injection drug users varies widely depending on age, duration of injection drug use, and other factors (such as availability and use of needle exchange programs).14 Prevalences range from less than 50 percent in more recent studies of younger injection drug users to over 90 percent in past studies of older injection drug users.15–21 About 60 percent of new infections occur in individuals who report injecting drugs within the last 6 months.3 Although large population-based studies15, 16, 22 report independent associations between HCV infection and some high-risk sexual behaviors (multiple sexual partners, unprotected sex, and/or sex with a person infected with HCV infection or using injection drugs), the efficiency of transmission via sexual contact appears to be low, and high-risk sexual behaviors may be a marker for undisclosed drug use or other risk factors. Transfusions prior to 1990 are a risk factor for HCV infection but are no longer an important source of infection due to the implementation of effective screening programs for donated blood.23, 24 Evidence on tattoos as a risk factor for HCV infection is mixed.25–30 Data on other percutaneous exposures and their association with HCV infection risk are limited, and their relative importance may vary depending on geographic locale and other factors.

The natural course of chronic HCV infection varies. Many patients with chronic HCV infection have only mild liver disease even after decades of infection or never develop histologic evidence of liver disease.31 In other patients, inflammation and fibrosis of the liver may progress to cirrhosis, which can lead to end-stage liver disease or hepatocellular carcinoma. Once cirrhosis develops, patients have a much higher risk of death and some may benefit from liver transplantation. Well-established predictors of advanced fibrosis in those with chronic HCV infection include older age at infection, longer duration of infection, male sex, concomitant HIV or hepatitis B virus (HBV) infection, and greater alcohol use.31–33 Other factors that may be associated with increased risk of fibrosis include insulin resistance, hepatic steatosis, higher viral load, and the presence of certain HLA class II polymorphisms.

Estimating the proportion of patients in the general population with HCV infection who progress to cirrhosis is difficult because the time of acquisition is often unclear and important endpoints often do not occur until after decades of infection.34 For example, six retrospective cohort studies of HCV-infected adults with known time of infection (based on a known exposure, often to contaminated blood products during young adulthood) reported cirrhosis in 0^35^ to 10 percent36 of patients after at least 10 years of followup.13, 35–40 Overall, studies of community cohorts estimate cirrhosis in an average of 7 percent of people after 20 years of HCV infection, with rates averaging about twice as high in clinical and referral cohorts.33, 41 Studies with longer followup suggest that progression to cirrhosis may accelerate after 20 years of chronic infection.39

Screening for HCV infection in asymptomatic adults who have no history of liver disease or known liver function test abnormalities may identify infected patients at earlier stages of disease before they develop serious or irreversible liver damage. A high proportion of people with chronic HCV infection are thought to be unaware of their status. One study of young injection drug users in the United States found that 72 percent were unaware of their HCV-positive status.42 Patients with chronic HCV infection may be eligible for antiviral treatments, which have become increasingly effective in achieving long-term eradication of HCV from the blood. In addition, knowledge of or counseling regarding HCV infection might help prevent transmission by decreasing high-risk injection drug use and other risky behaviors or identify those who might benefit from hepatitis A or B vaccinations, alcohol cessation counseling, or other interventions.

Recommendations on HCV screening vary (Table 1). In 2004, the United States Preventive Services Task Force (USPSTF) recommended against screening for HCV infection in adults not at increased risk of infection (D recommendation) and found insufficient evidence to recommend for or against screening in adults at high-risk of infection (I recommendation).43 The 2004 evidence review commissioned by the USPSTF to inform its recommendations found that screening is accurate in identifying people with HCV infection and that antiviral treatments improved intermediate outcomes such as viremia.44 The D recommendation in low-risk individuals was based on evidence indicating a relatively low prevalence of HCV infection, natural history studies showing that most patients with chronic HCV infection do not develop major long-term negative health outcomes (such as death, cirrhosis, or need for liver transplantation), lack of direct evidence showing that screening or antiviral treatments improves important health outcomes, and potential harms of screening including those related to unnecessary treatments and labeling. Although the USPSTF concluded that screening high-risk populations would be a more efficient strategy than screening average-risk populations and would lead to improvements in intermediate outcomes (based on sustained virologic response rates), it found insufficient evidence on the effects of screening or antiviral treatments on health outcomes to determine the balance of benefits and harms to screening.43

Table 1 Current hepatitis C virus infection screening recommendations

Organization | Recommended | Uncertain Need | Not Recommended
American Academy of Pediatrics Hepatitis C Infection, Committee on Infectious Diseases (1998) | Children with risk factors Children born to HCV infected mothers | Not stated | Routine testing of pregnant women
American Association for the Study of Liver Diseases American Association for the Study of Liver Diseases Practice Guidelines (2009) | History of any IV drug use People with conditions associated with a high prevalence of HCV infection including:; - HIV infection; - Hemophilia who received clotting factor concentrates prior to 1987; - History of having been on hemodialysis; - Unexplained abnormal aminotransferase levels; - Prior recipients of transfusions or organ transplants prior to July 1992 including:; ○ recipients of blood from a donor who later tested positive for HCV infection; ○ recipients of transfusion of blood or blood products; ○ recipients of an organ transplant; - Children born to HCV-infected mothers; - Health care, emergency medical and public safety workers after a needle stick injury or mucosal exposure to HCV-positive blood; - Current sexual partners of HCV-infected people; A liver biopsy should be considered in patients with chronic hepatitis C infection if the patient and health care provider wish information regarding fibrosis stage for prognostic purposes or to make a decision regarding treatment (Class IIa, Level B) | Liver biopsy may be unnecessary in infected people with Genotypes 2 and 3 due to high rates of SVR with treatment Uncertain need for liver biopsy in Genotype 1:; - 50% response to treatment in Caucasians; - 30% response in African Americans; Uncertain need for liver biopsy in Genotypes 4–6 due to low prevalence | Routine testing for anti-HCV at birth of children born to HCV-infected mothers due to high rate of positive antibody via passive transfer from the mother. Testing for anti-HCV may be performed at 18 months of age or older
American College of Obstetricians and Gynecologists American College of Obstetricians and Gynecologists practice bulletin; no. 86 (2007) | Screening of at-risk pregnant women for HCV infection Considerations for amniocentesis, route of delivery and breastfeeding in women infected with hepatitis | Not stated | Routine screening considered but not recommended
American College of Preventive Medicine Practice policy statement (2005) | - Current and former IV drug users or sex with an IV drug user; - Transfusion or organ transplant recipients prior to 1992; - Clotting factor recipient prior to 1987; - Hemodialysis patients; - Individuals with signs and symptoms of liver disease | Insufficient evidence for or against universal screening | Not stated
American Gastroenterological Association Statement on the Management of Hepatitis C (2006) | - Current and former IV drug users; - Clotting factor recipient prior to 1987; - Individuals with signs and symptoms of liver disease; - Frequent percutaneous exposures; - Immigrants from countries with a high prevalence of HCV infections | Not stated | Routine screening of all asymptomatic adults, who have a low prior probability of HCV infection
Centers for Disease Control and Prevention Recommendations for prevention and control of HCV infection and HCV related chronic disease (1998) Hepatitis C virus testing of persons born during 1945 to 1965 (2012) | - Transfusion or organ transplant recipients prior to 1992; - Occupational exposure to HCV positive blood; - Health care professionals exposed to HCV infected blood; - Signs or symptoms of liver disease; - Children born to HCV infected mothers; - Persons born during 1945 to 1965 | Recipients of transplanted tissue Intranasal cocaine and other noninjection drug users People with a history of tattooing or body piercing People with a history of multiple sex partners or sexually transmitted diseases Long-term steady sex partners of HCV positive people | Healthcare and public safety workers Pregnant women Household (nonsexual) contacts of HCV positive people General population
United States Preventive Services Task Force Recommendation Statement (2004) | None | Patients with specific risk factors | Patients with no specific risk factors for HCV infection and no symptoms of liver disease
Veterans Affairs Hepatitis C Resource Center Program Topic Review: Screening Veterans for Hepatitis C Infection (Accessed 2011) | Individuals who request screening Individuals with one or more of the following risk factors:; - Current and former IV drug users; - Transfusion or organ transplant recipients prior to 1992; - Hemodialysis patients; - Vietnam-era Veteran, defined by dates of service from 1964 through 1975; - Health care professionals exposed to HCV infected blood; - Tattoos or body-piercings obtained in nonregulated settings; - Intranasal drug users who have shared paraphernalia; - Sex partner of an HCV carrier; - 10 or more lifetime sexual partners; - HIV infected individuals; - History of hemophilia and/or clotting factor recipient prior to 1987; - Individuals with signs and symptoms of liver disease; - Alcoholic hepatitis; - Diagnosis (DSM-IV) of alcohol abuse or dependence; - Children born to HCV-infected mothers | Not stated | Not stated

HCV = hepatitis C virus; IV = intravenous

Unlike the USPSTF, other groups (including the American Association for the Study of Liver Disease, the Infectious Diseases Society of America, and the American College of Gastroenterology) recommend screening in higher risk patients.45–47 These recommendations are based on the higher prevalence of HCV infection in higher-risk populations, acceptance of the link between improved intermediate outcomes following antiviral treatments and improved clinical outcomes, and presumed public health benefits related to the potential for reduced risky behaviors and transmission. The CDC recently recommended the screening of high-risk patients as well as age-cohort based HCV screening of all people born between 1945 and 1965^48^

Mother-to-child (vertical) transmission is believed to be the main route of HCV infection acquisition in children.49 Estimates of vertical transmission range from 3 to 10 percent.49–53 The risk of transmission is highest among women with a high viral load at the time of delivery49–53 and among women coinfected with HIV.52, 54 Routine prenatal screening for HCV infection is not currently recommended by the CDC.55 In 2007, the American College of Obstetricians and Gynecologists (ACOG) recommended offering HCV screening to at-risk pregnant women.56 The 2004 USPSTF recommendations did not address screening for HCV during pregnancy. While antiviral therapies are contraindicated in pregnancy due to teratogenic risks, identification of HCV infection during pregnancy could facilitate decisionmaking around the use of interventions during labor and delivery or in the perinatal period to prevent mother-to-child transmission.57

The purpose of this report is to review the evidence on screening for chronic HCV infection in asymptomatic adults without known liver enzyme abnormalities. The Agency for Healthcare Research and Quality (AHRQ), which commissioned this review, also commissioned a separate but complementary review on effectiveness of antiviral treatments, including newer regimens, which is critical for fully understanding benefits and harms of screening.58 Together, these reviews will be used by the USPSTF to update its recommendations on HCV screening. This review focuses on research gaps identified in the 2004 USPSTF review and new studies published since that review. In addition, unlike the 2004 USPSTF review, which focused on nonpregnant adults, it also evaluates evidence on prenatal HCV screening.

## Scope and Key Questions

The analytic framework and Key Questions used to guide this report are shown below (Figure 1). The analytic framework shows the target populations, interventions, and intermediate and health outcome measures we examined. We defined universal screening to mean that everyone was tested, regardless of symptoms or risk factors. We defined targeted screening to mean only those who met specific criteria were tested.

Figure 1 Analytic framework: Screening for hepatitis C virus infection in adults

HCV = hepatitis C virus; QOL = quality of life; SVR = sustained virologic response

Note: Portions in grey refer to Key Questions addressed in a separate review on antiviral treatments.58

^a^ Nonpregnant and pregnant adults without abnormal lab values. Excluding people with HIV, transplant recipients, and patients with renal failure.

^b^ HCV antibody testing with confirmatory HCV RNA testing as indicated.

^c^ Interventions that may affect vertical transmission of HCV, such as cesarean section, amniocentesis, fetal monitoring, or others.

^d^ Refers to eligibility for antiviral treatment based on viral and host factors.

This figure depicts the analytic framework that outlines the population, interventions and outcomes considered in the review. The above figure is a modified version of a larger framework depicting the impact of both screening and treatment for Hepatitis C in adults. This figure focuses on the screening portion of the framework. The population includes asymptomatic adults and pregnant women. The interventions include screening for HCV infection risk factors, screening for HCV antibody, diagnostic tests for work-up of treatable disease, pregnancy interventions, counseling against risky behaviors and immunization for other hepatitis infections. Outcomes include mortality, morbidity, quality of life and HCV transmission as well as harms of screening and/or workup.

### Key Question 1

a. Does screening for HCV infection in nonpregnant adults without known abnormal liver enzymes reduce mortality and morbidity due to HCV infection, affect quality of life, or reduce incidence of HCV infection?
b. Does screening for HCV infection during pregnancy reduce vertical transmission of HCV or improve mortality or morbidity for the mother or child?

### Key Question 2

a. What is the effectiveness of different risk- or prevalence-based methods for screening for HCV infection on clinical outcomes?
b. What is the sensitivity and number needed to screen to identify one case of HCV infection of different risk- or prevalence-based methods for screening for HCV infection?

### Key Question 3

What are the harms associated with screening for HCV infection, including adverse effects such as anxiety, labeling, and impact on relationships?

### Key Question 4

a. What are the comparative effectiveness and comparative diagnostic accuracy of various tests and strategies for the workup to guide treatment decisions in patients who are HCV positive?
b. What proportion of patients with screen-detected HCV infection receives treatment?

### Key Question 5

What are the harms associated with the workup for guiding treatment decisions?

### Key Question 6

a. How effective is counseling or immunization of patients with HCV infection at improving health outcomes or reducing the spread of HCV?
b. Does becoming aware of positive HCV infection status decrease high-risk behaviors?
c. How effective is counseling or immunization of patients with HCV infection at improving intermediate outcomes, including change in high-risk behaviors?

### Key Question 7

Do any interventions decrease or increase the risk of vertical transmission of HCV during delivery or in the perinatal period?

The overarching Key Questions (1a and 1b) in the analytic framework focus on direct evidence that screening for HCV infection improves important health outcomes compared with not screening. When such direct evidence is sparse or unavailable, indirect evidence can be used to assess the effects of screening on health outcomes. Therefore, the remainder of the analytic framework evaluates the chain of indirect evidence needed to link screening for HCV infection with improvements in important health outcomes. Links in the chain of indirect evidence include the performance of the screening test or testing strategy for identifying individuals with HCV infection, the clinical utility and diagnostic accuracy of the workup used to guide treatment decisions, and the effectiveness of treatments in those identified as infected with HCV infection, as well as any harms from the screening test and subsequent diagnostic tests and treatments. We did not re-review the accuracy of HCV antibody testing, which the prior USPSTF review found to be highly accurate. The proportion of patients with HCV infection that receives antiviral treatment is important for understanding potential benefits of screening, as not all patients will receive (and potentially benefit from) treatment. Critical gaps in any of the links of the indirect chain of evidence can make it impossible to reliably estimate benefits and harms of screening.