# Peer Reviewers

Adelita G. Cantu, Ph.D., R.N.

Assistant Professor

Family and Community Health Systems

University of Texas Health Science Center at San Antonio

San Antonio, TX

Brian Edlin, M.D., F.I.D.S.A.

Division of Infectious Disease

SUNY Downstate Medical Center

Brooklyn, NY

Linda Kinsinger, M.D., M.P.H.

Chief Consultant for Preventive Medicine

Department of Veterans Affairs, Center for Health Promotion/Disease Prevention

San Diego, CA

David Ross, M.D., Ph.D.

Director

Department of Veterans Affairs, Office of Clinical Public Health Programs

Washington DC

Bruce A. Runyon, M.D.

Loma Linda University Medical Center

Division of Gastroenterology and Hepatology

Loma Linda, CA

Stephen Stewart, Ph.D.

Consultant Hepatologist

Mater Misericordiae University Hospital

Centre for Liver Disease

Dublin, Ireland

Donna E. Sweet, M.D.

Director of Internal Medicine Education-St. Francis Campus

University of Kansas Medical School

Wichita, KS