# Technical Expert Panel

Miriam Alter, Ph.D., M.P.H.

Professor, Infectious Disease Epidemiology

Department of Internal Medicine

Division of Infectious Disease

University of Texas

Austin, TX

Kirsten Bibbins-Domingo, Ph.D., M.D., M.A.S.

U.S. Preventive Services Task Force

Associate Professor

Department of Medicine and Epidemiology & Biostatistics

University of California, San Francisco

San Francisco, CA

Adelita G. Cantu, Ph.D., R.N.

Assistant Professor

Family and Community Health Systems

University of Texas Health Science Center at San Antonio

San Antonio, TX

Brian Edlin, M.D., F.I.D.S.A.

Division of Infectious Disease

SUNY Downstate Medical Center

Brooklyn, NY

W. Ray Kim, M.D.

Division of Gastroenterology and Hepatology

Mayo Medical School

Rochester, MN

Steven Pearson, M.D., M.Sc., F.R.C.P.

Director

Institute for Clinical & Economic Review Department of Population Medicine

Harvard Medical School

Boston, MA

Bruce A. Runyon, M.D.

Loma Linda University Medical Center

Division of Gastroenterology and Hepatology

Loma Linda, CA

Thomas Shehab, M.D.

Huron Gastroenterology

Center for Digestive Care

St. Joseph Mercy Hospital

Ann Arbor, MI

Bryce Smith, Ph.D.

Centers for Disease Control and Prevention

Division of Viral Hepatitis

Atlanta, GA

Donna E. Sweet, M.D.

Director of Internal Medicine Education-St. Francis Campus

University of Kansas Medical School

Wichita, KS

John Ward, M.D., M.P.H.

Director, Viral Hepatitis Division

Centers for Disease Control and Prevention

Atlanta, GA

Kimberly Workowski, M.D.

Associate Professor of Medicine

The Emory Clinic

Emory University

Atlanta, GA