# Discussion

Key Findings and Strength of Evidence Table 15 summarize the findings of this review, including strength of evidence grades. Details about factors assessed to determine the overall strength of evidence for each body of evidence are shown in Appendix F. As in the 2004 USPSTF review,44 we found no direct evidence on benefits of screening for hepatitis C virus (HCV) infection compared with no screening in asymptomatic adults with no liver enzyme abnormalities. Although direct harms of screening appear minimal (since it is a simple blood test), other harms such as labeling, anxiety, and stigmatization remain poorly studied, though reported in some qualitative and other studies.280–282

Table 15 Summary of evidence on comparative benefits and harms of screening for hepatitis C virus infection

Key Question | Strength of Evidence | Summary
Key Question 1a. Does screening for HCV infection in nonpregnant adults without known abnormal liver enzymes reduce mortality and morbidity due to HCV infection, affect quality of life, or reduce incidence of HCV infection? | Insufficient | No studies.
Key Question 1b. Does screening for HCV infection during pregnancy reduce vertical transmission of HCV or improve mortality or morbidity for the mother or child? | Insufficient | No studies.
Key Question 2a. What is the effectiveness of different risk- or prevalence-based methods for screening for HCV infection on clinical outcomes? | Insufficient | No studies.
Key Question 2b. What is the sensitivity and number needed to screen to identify one case of HCV infection of different risk- or prevalence-based methods for screening for HCV infection? | Low | Five studies found that screening strategies targeting multiple risk factors were associated with sensitivities of over 90% and numbers needed to screen to identify one case of HCV infection of less than 20. More narrowly targeted screening strategies were associated with numbers needed to screen of less than two, but with the trade-off of missing up to two-thirds of infected patients. All studies were retrospective and had methodological shortcomings.
Key Question 3. What are the harms associated with screening for HCV infection, including adverse effects such as anxiety, labeling, and impact on relationships? | Insufficient | Five studies of patients diagnosed with HCV infection suggested potential negative psychological and social effects, but are difficult to interpret due to small sample sizes and methodological shortcomings, including no unscreened comparison group.
Key Question 4a. What is the Comparative Effectiveness and Comparative Diagnostic Accuracy of Various Tests and Strategies for the Workup to Guide Treatment Decisions in Patients who are HCV Positive?
Clinical Outcomes | Insufficient | One retrospective cohort study (n=156) of patients who received interferon plus ribavirin therapy found no difference in rates of sustained virologic rates between patients who did not undergo biopsy prior to treatment compared with matched patients who did undergo biopsy.
Diagnostic accuracy: Platelet counts vs. liver biopsy | Low | For fibrosis (defined as METAVIR F2-F4, Ishak 3–6, or equivalent), the median AUROC was 0.71 (range 0.38 to 0.94) in 5 studies. For cirrhosis (defined as METAVIR F4, Ishak 5–6, or equivalent), the AUROC was 0.89 (range 0.64 to 0.99) in five studies.
Diagnostic accuracy: Age-platelet index vs. liver biopsy | Moderate | For fibrosis, the median AUROC was 0.69 (range 0.64 to 0.77) in four studies. For cirrhosis, the median AUROC was 0.89 (range 0.67 to 0.91) in four studies.
Diagnostic accuracy: Aspartate aminotransferase-platelet ratio index (APRI) vs. liver biopsy | High | For fibrosis, the median AUROC was 0.76 (range 0.58 to 0.95) in 44 samples reported in 42 studies. For cirrhosis, the median AUROC was 0.85 (range 0.61 to 0.92) in 32 studies.
Diagnostic accuracy: Aspartate aminotransferase-alanine aminotransferase ratio (AST/ALT ratio, or AAR) vs. liver biopsy | High | For fibrosis, the median AUROC was 0.59 (range 0.50 to 0.82) in nine studies. For cirrhosis, the median AUROC was 0.66 (range 0.52 to 0.91) in eleven studies.
Diagnostic accuracy: Cirrhosis Discriminant Score (CDS, also Bonacini Index) vs. liver biopsy | Moderate | For cirrhosis, the median AUROC was 0.77 (range 0.70 to 0.91) in six studies. Although the CDS was developed to identify cirrhosis, three studies reported a median AUROC of 0.67 (range of 0.64 to 0.71) for fibrosis.
Diagnostic accuracy: Enhanced Liver Fibrosis Index (ELF) or Simplified Enhanced Liver Fibrosis Index (Simplified ELF) vs. liver biopsy | Moderate | For fibrosis, the median AUROC was 0.81 (range 0.72 to 0.87) in seven samples reported in five studies. For cirrhosis, the median AUROC was 0.88 (range 0.78 to 0.91) in six samples reported in three studies.
Diagnostic accuracy: FIB-4 vs. liver biopsy | Moderate | For severe fibrosis (defined as METAVIR F3–F4, Ishak 4–6, or equivalent), the median AUROC was 0.86 (range 0.73 to 0.90) in four studies. For cirrhosis, the median AUROC was 0.87 (range 0.83 to 0.92) in six studies.
Diagnostic accuracy: FibroIndex vs. liver biopsy | Moderate | For fibrosis, the median AUROC was 0.71 (range 0.58 to 0.86) in five samples reported in four studies. For cirrhosis, the AUROCs were 0.86 and 0.92 in two studies.
Diagnostic accuracy: Fibrometer vs. liver biopsy | Moderate | For fibrosis, the median AUROC was 0.82 (range 0.78 to 0.85) in eight samples reported in seven studies. For cirrhosis, the median AUROC was 0.91 (range 0.89 to 0.94) in five studies.
Diagnostic accuracy: FibroSpect II vs. liver biopsy | Low | For fibrosis, the median AUROC was 0.86 (range 0.82 to 0.90) in four studies. No study evaluated the diagnostic accuracy of FibroSpect II for cirrhosis.
Diagnostic accuracy: Fibrotest vs. liver biopsy | High | For fibrosis, the median AUROC for was 0.79 (range 0.70 to 0.89) in 21 samples reported in twenty studies. For cirrhosis, the median AUROC was 0.86 (range 0.71 to 0.92) in eleven studies.
Diagnostic accuracy: Forns’ Index vs. liver biopsy | High | For fibrosis, the median AUROC was 0.75 (range 0.60 to 0.86) in sixteen samples reported in fifteen studies. For cirrhosis, the median AUROC was 0.88 (range 0.85 to 0.91) in six studies.
Diagnostic accuracy: Hepascore vs. liver biopsy | High | For fibrosis, the median AUROC was 0.79 (range 0.69 to 0.82) in nine studies. For cirrhosis, the median AUROC was 0.89 (range 0.88 to 0.94) in eight samples reported in seven studies.
Diagnostic accuracy: Lok Index vs. liver biopsy | Moderate | For cirrhosis, the median AUROC was 0.80 (range 0.61 to 0.91) in eight samples reported in six studies. One study reported an AUROC of 0.69 (95% CI 0.69 to 0.74). No study reported the AUROC for the Lok Index for fibrosis.
Diagnostic accuracy: Pohl Index vs. liver biopsy | Low | For severe fibrosis (METAVIR F3–F4, Ishak 3–6, or equivalent), one study reported an AUROC of 0.53 (95% CI 0.51 to 0.56). For cirrhosis, the AUROC was 0.64 and 0.66 in two studies.
APRI vs. Fibrotest | Moderate | Sixteen studies (some of which evaluated overlapping populations) consistently found no differences between the APRI and Fibrotest based on the AUROC.
AST/ALT ratio vs. other indices | Moderate | Twelve of fourteen studies found the AST/ALT ratio associated with a lower AUROC compared with various other indices.
Key Question 4b. What proportion of patients with screen-detected HCV infection receives treatment? | Moderate | Three longitudinal studies reported that 15% to 33% of patients with screen-detected chronic HCV infection received treatment.
Key Question 5. What are the harms associated with the workup for guiding treatment decisions? | Moderate | One study (n=2,740) of patients with chronic HCV infection and compensated cirrhosis with an Ishak fibrosis score of ≥3 reported serious adverse events in 1.1% of patients, including 0.6% serious bleeds and 0.3% severe pain, with no deaths. Five large (n=1,398 to 61,184) interventions series published since 2004 of patients undergoing percutaneous liver biopsy for a variety of reasons reported peri-procedural mortality in <0.2% and serious complications in 0.3% to 1.0%.
Key Question 6a. How Effective is Counseling or Immunization of Patients With HCV Infection at Improving Health Outcomes or Reducing the Spread of HCV?
Clinical outcomes or spread of disease: counseling | Insufficient | One randomized trial found a self-management program associated with slight improvements in SF-36 vitality scores compared with provision of educational materials after 6 weeks, but there were no effects on other measures of generic or HCV-related quality of life.
Clinical outcomes: Immunization | Insufficient | No studies.
Key Question 6b. Does becoming aware of positive HCV infection status decrease high-risk behaviors? | Low | Three retrospective studies reported substantial reductions in alcohol use following diagnosis of HCV infection, but two prospective studies found no evidence of sustained reductions in high-risk behaviors (alcohol use or injection drug use behaviors) following diagnosis. Results from two cross-sectional studies were mixed.
Key Question 6c. How Effective is Counseling or Immunization of Patients With HCV Infection at Improving Intermediate Outcomes, Including Change in High Risk Behaviors?
High-risk behaviors: counseling | Insufficient | Two randomized trials reported somewhat mixed results regarding effects of counseling interventions based on behavioral principles compared with simple educational interventions, though one trial that trained patients to serve as peer mentors reported sustained absolute decreases of about 15% in the proportion engaging in risky injection drug behaviors. Two before-after studies of HCV-infected heavy drinkers following found 36% to 44% reported abstinence 6 to 22 months after a counseling intervention.
Intermediate outcomes: immunization | Insufficient | No studies.
Key Question 7. Do Any Interventions Decrease or Increase the Vertical Transmission of HCV During Delivery or in the Perinatal Period?
Vertical transmission: Elective cesarean vs. vaginal delivery | Low | Two good-quality studies found no statistically significant difference in risk of vertical transmission of HCV infection between elective cesarean and vaginal delivery, but trends were in opposite directions.
Vertical transmission: Any cesarean vs. vaginal delivery | Moderate | Ten of 11 observational studies (one good quality) found no statistically significant difference in risk of vertical transmission of HCV infection following vaginal compared with cesarean (not specified if elective or emergent) delivery.
Vertical transmission: Internal fetal monitoring vs. no internal fetal monitoring | Insufficient | Three observational studies (two good quality) found inconsistent evidence on the association between internal fetal monitoring and the risk of vertical transmission of HCV infection (no association in 2 studies) and OR 6.7 (95% CI 1.1 to 36) in the third study.
Vertical transmission: Prolonged rupture of membranes vs. less prolonged rupture of membranes | Low | Two studies (one good quality) found an association between prolonged labor after membrane rupture and risk of vertical transmission of HCV infection. In the good-quality study, membrane rupture >6 hours was associated with an adjusted OR of 9.3 (95% CI 1.5 to 180) for vertical transmission.
Vertical transmission: Breastfeeding vs. no breastfeeding | Moderate | Fourteen studies consistently found no significant association between breastfeeding and risk of transmission.

AAR = aspartate aminotransferase-alanine aminotransferase ratio; APRI = aspartate aminotransferase platelet ratio index; AUROC = area under the receiver operating characteristic curve; CI = confidence interval; CDS = Cirrhosis Discriminant Score; ELF = Enhanced Liver Fibrosis Index; HCV = hepatitis C virus; OR = odds ratio

Retrospective studies found that screening strategies targeting multiple risk factors were associated with sensitivities of over 90 percent and numbers needed to screen to identify one case of HCV infection of less than 20.^80–83^ More narrowly targeted alternative screening strategies were associated with numbers needed to screen of less than two, but missed up to two-thirds of infected patients. No study prospectively compared different screening strategies or assessed effects of alternative screening strategies on outcomes. Epidemiologic data indicates that about two-thirds of people with chronic HCV infection were born between 1945 and 1965, suggesting that testing of all people in this birth-cohort could be an efficient strategy. However, the only published report on birth cohort screening is a cost-effectiveness modeling study which did not meet inclusion criteria because it did not assess clinical data.21

In the absence of direct evidence on screening, understanding the accuracy of the screening test as well as benefits and harms of subsequent workup and treatments in patients found to be HCV-positive can provide an indirect chain of evidence regarding potential benefits of screening. HCV antibody testing with subsequent polymerase chain reaction (PCR) testing for circulating virus was found to be accurate for identifying patients with HCV infection in a previous systematic review44 and diagnostic accuracy was not re-reviewed for this report. Regarding the workup in patients found to be HCV-positive, a number of blood indices were associated with an area under the receiver operating characteristic curve (AUROC) of 0.75 to 0.86 for fibrosis (METAVIR F2-F4, Ishak 3–6, or equivalent) and 0.80 to 0.91 for cirrhosis (METAVIR F4, Ishak 5–6, or equivalent) (generally considered “good” to “very good” diagnostic accuracy).71, 72 Only one study90 evaluated the clinical impact of no biopsy prior to antiviral treatment, showing no differences compared with patients who underwent biopsy prior to treatment. Harms of biopsy appeared to be small, with a risk of death of <0.2 percent and serious complications (primarily bleeding and severe pain) in about 1 percent.233, 235–239 However, estimating harms of screening associated with liver biopsy is a challenge. Although clinical practice has evolved toward less routine use of biopsy prior to antiviral therapy, we found no studies reporting current estimates of the proportion of patients who undergo biopsy prior to treatment.

Some evidence published since the 2004 review suggests that patients who become aware of being HCV positive may reduce risky behaviors,42, 88, 253–255 but prospective studies suggest that such behavior changes may not be sustained.252, 254 Evidence on effective methods of counseling to reduce risky behaviors remains sparse, though one randomized trial showed an intervention based on behavioral principles was effective at reducing risky injection drug use behaviors.256 We did not review evidence on the general effectiveness of counseling and risk prevention interventions in non-HCV infected people. Whether such evidence can be extrapolated to patients with HCV infection requires assumptions regarding applicability. No study evaluated effects of immunizations for hepatitis A virus (HAV) or hepatitis B virus (HBV) infection on clinical outcomes or effects of counseling or awareness of HCV status on transmission risk.

Much of the benefits from screening are likely to occur as a result of antiviral treatments, which have become increasingly effective at achieving a sustained virologic response (SVR) (a strong predictor of long-term virologic response).283 Antiviral treatments, including recently approved new regimens, and the association between SVR and improvement in clinical outcomes (a key evidence gap in the 2004 USPSTF review)44 will be addressed in a separate review. In screened populations, benefits of antiviral treatments will depend in part on the proportion of patients who actually receive treatment. Three studies of screen-detected patients found that 15 to 33 percent of screen-detected patients with chronic HCV infection received antiviral treatment.230–232 However, interpreting these findings is a challenge, as the proportion of patients who receive treatment is likely to vary depending on the population studied and criteria used to determine treatment eligibility, which continue to evolve and differ across settings.

No study compared effects of screening with not screening pregnant women. Cohort studies report conflicting information regarding intrapartum management including effects of mode of delivery on transmission risk. Two studies52, 269 that looked at rupture of membranes, which is most commonly experienced by women intending vaginal delivery, reported increased risk of HCV transmission with more prolonged duration of ruptured membranes. Based on those findings, it might be expected that elective cesarean delivery, in which women undergo planned cesarean (typically prior to labor or rupture of membranes) should be associated with decreased risk of vertical transmission; however, studies reported conflicting information, with the largest single study260 reporting a nonstatistically significant higher trend towards increased transmission following elective cesarean compared with vaginal delivery. Possible explanations include threshold effects (in terms of duration of prolonged rupture of membranes) or influence of viral load or other potential modifying factors in women with ruptured membranes. Studies consistently found no association between breastfeeding and transmission risk.

## Findings in Relationship to What Is Already Known

Like an earlier evidence review on HCV screening conducted for the USPSTF,284 we found no direct evidence on clinical benefits associated with screening compared with no screening. As in that review, we found that screening strategies targeted at people with a history of intravenous drug use are associated with small numbers needed to screen to identify one case of HCV infection, but miss a significant proportion of people screened.

The USPSTF review found HCV screening tests to be accurate and we did not re-review diagnostic accuracy. Consistent with other reviews,285–290 we found that noninvasive tests have fair to good accuracy for diagnosing fibrosis and good to excellent accuracy for diagnosing cirrhosis compared to liver biopsy. Estimates of serious harms associated with liver biopsy are also consistent with estimates from the prior USPSTF review.

Evidence showing that knowledge of HCV status or interventions in people with HCV infection is effective at reducing transmission or high-risk behaviors for transmission remains limited. Studies reporting rates of antiviral treatment in screen-detected patients with HCV infection were all been published after the USPSTF review,284 which included studies of referral populations, rather than cohorts of patients identified through screening. The studies of referral populations reported somewhat higher rates of treatment (30–40 percent) compared to the studies of screen-detected patients (15–33 percent) in our review.

The prior USPSTF evidence review did not address prenatal screening for HCV screening. However, our findings were similar to a guideline from the American Congress of Obstetricians and Gynecologists, which concluded that there are no known effective preventive measures for reducing the risk of mother-to-child transmission of HCV infection.56 Like our review, ACOG found limited evidence suggesting a possible association between prolonged rupture of membrane after labor and use of internal fetal monitoring and increased risk of vertical transmission.

## Applicability

Several issues may limit applicability of our findings to screening settings likely to be encountered in clinical practice. Most of the studies80–84 evaluating the sensitivity and yield of different screening strategies (Key Question 2b) were conducted in higher prevalence settings, potentially limiting applicability to average- or low-risk populations.

Few studies evaluating harms of liver biopsy were conducted specifically in populations of patients with HCV infection, and none specifically evaluated a screen-identified cohort. The applicability of estimates of serious harms such as bleeding from such studies to a screen-detected population would depend on the presence and severity of liver disease and other comorbidities in the people who underwent biopsy. For example, patients with end-stage liver disease or undergoing biopsy for hepatocellular carcinoma are likely to be at increased risk for bleeding following liver biopsy compared to asymptomatic patient identified through screening.

Studies reporting rates of antiviral treatment in cohorts of patients with screen-detected HCV infection are also difficult to interpret, as the proportion of patients who receive treatment is likely to vary depending on the population studied and criteria used to determine treatment eligibility, which continue to evolve and differ across settings. In addition, two of the studies were conducted in Veterans Affairs (VA) settings230, 232 and the third231 in people with a history of intravenous drug use (IVDU), and may not accurately reflect treatment patterns in other settings.

Although none of the studies assessing diagnostic accuracy of noninvasive tests compared to liver biopsy were conducted in screen-detected patients, studies generally enrolled a broad spectrum of patients who varied in severity of fibrosis and other markers of HCV infection severity. Therefore, estimates of diagnostic accuracy are likely to be applicable to patients identified by screening.

We did not include evidence on the general effectiveness of interventions to reduce alcohol use or risky injection drug use behaviors, as the applicability of such studies to patients specifically with HCV infection is uncertain. Our findings are not applicable to patients with HIV infection, end-stage renal disease, or following transplant, as these populations were excluded from the review.

Similarly, our findings on the association between labor and delivery management practices and breastfeeding on risk of vertical transmission are not applicable to women with concomitant HIV infection. Risk of mother-to-child transmission of HCV appears to be higher in women with concomitant HIV infection compared to those without HIV infection. Specific interventions already recommended to prevent vertical transmission of HIV infection include antiretroviral therapy, avoidance of breastfeeding, and elective cesarean in selected patients.291

## Implications for Clinical and Policy Decisionmaking

Our review has some important potential implications for clinical and policy decisionmaking. Because of the lack of direct evidence showing clinical benefits associated with HCV screening, decisions regarding screening must necessarily be made on the basis of the indirect chain of evidence. Evidence clearly supports that HCV antibody tests are accurate for identifying HCV infection, but that strategies targeted at clinical risk factors misses a substantial proportion of infected patients, in part due to undisclosed or unknown risks. Regardless of the screening strategy applied, for screening to be effective, identification of people with HCV infection must lead to subsequent interventions that improve clinical outcomes. Given the lack of evidence showing beneficial effects of screening and subsequent interventions on transmission risk or on intermediate outcomes such as risky behaviors, screening decisions are likely to be critically dependent on the effectiveness of antiviral treatments, which is covered in a separate review.58 Therefore, we recommend that decisions about screening should only be made after also considering such the evidence on screening and treatment in totality.

In the prenatal setting, no intervention has been clearly demonstrated to reduce the risk of vertical transmission of HCV infection. Nonetheless, until more evidence is available, if a woman with HCV attempts vaginal delivery, clinicians may consider limiting the duration of ruptured membranes to less than 6 hours given some evidence of an association between prolonged rupture of membranes and increased risk of vertical transmission.291

Clinicians and policymakers may consider modeling studies to help estimate potential benefits and harms of screening. We did not include such studies, whose usefulness will depend on the veracity of the model and the reliability of various input parameters.

## Limitations of the Comparative Effectiveness Review Process

We excluded non-English language articles, which could result in language bias, though we identified no non-English language studies that would have met inclusion criteria. We included cohort studies on the association between labor and delivery practices or breastfeeding and vertical transmission. Such studies are more susceptible to bias and confounding than well-conducted randomized trials. We therefore focused on results from studies that performed adjustment and were otherwise assessed as being at lower risk of bias. For Key Questions related to effects of knowledge of HCV status or counseling on risky behaviors, we included weaker study designs such as before-after studies and cross-sectional studies, due to lack of evidence from studies with stronger designs. We were unable to formally assess for publication bias due to small numbers of studies, methodological shortcomings, and differences across studies in designs, measured outcomes, and other factors. We did not attempt to pool results for any Key Questions due to differences across studies in populations, interventions, and outcomes assessed. Finally, we did not evaluate evidence on potential barriers to screening and how they might affect estimates of benefits and harms.

## Limitations of the Evidence Base

The evidence base on HCV screening had a number of important limitations. No direct evidence comparing clinical outcomes in patients screened with those not screened, or clinical outcomes associated with different HCV screening strategies, is available. Studies on the sensitivity and yield of different screening strategies were primarily conducted in higher-prevalence populations.80–83 Only one small observational study evaluated clinical outcomes in people who underwent liver biopsy compared to no liver biopsy prior to antiviral treatment.90 The only studies reporting rates of antiviral treatment in cohorts of patients with screen-identified HCV infection were conducted in VA settings or in a population of IVDUs and may be of limited applicability in other settings.230–232 Few studies evaluated the effectiveness of interventions for reducing alcohol use or risky injection drug use behaviors in people specifically with HCV infection. In pregnant women, although studies have evaluated the association between prolonged rupture of membranes and internal fetal monitoring and risk of vertical transmission, no study has evaluated whether interventions to reduce their occurrence are associated with decreased risk.

## Research Gaps

Significant research gaps continue to limit full understanding of the benefits and harms of screening for HCV infection. Studies that compare clinical outcomes in patients screened and not screened for HCV infection would provide the most direct evidence, but would require large sample sizes and long duration of followup. However, studies would not necessarily need to be prospective, as well-conducted retrospective studies could also be informative. In addition, in lieu of direct evidence on effects of screening on clinical outcomes, studies that prospectively evaluate the accuracy and efficiency of alternative screening strategies (such as the CDC birth-cohort approach of screening all adults born between 1945 and 1965)48 would help fill important research gaps and provide some evidence to help guide strategies for targeted screening. No studies have adequately assessed the harmful impacts due to anxiety, labeling, or relationships with family and sexual partners that may result from screening for HCV infection in these patients and whether these harmful impacts can be minimized by appropriate counseling. If screening is effective, research on methods for addressing potential barriers to screening (such as use of rapid point-of-care tests) will be needed to help define optimal screening strategies.

Another important research gap is that although many studies have assessed the diagnostic accuracy of noninvasive tests compared to liver biopsy, there is insufficient evidence to determine effects of foregoing liver biopsy on clinical outcomes. Although liver biopsy is still regarded as the most accurate method for assessing the histologic stage of HCV infection, it is an invasive test with some risk for serious harms, making workup strategies that make use of noninvasive tests with high diagnostic accuracy a potential alternative. Studies that evaluate the outcomes of patients who receive treatment without liver biopsies would be helpful in determining whether all or selected patients should undergo pretreatment biopsy.

Another important research gap is that even though screening for chronic HCV infection may have importance not only in terms of individual clinical outcomes, but also as a public health measure, there is insufficient evidence to determine effects of screening on risk of transmission. In addition, screening might also help identify patients who would benefit from counseling about alcohol use or hepatitis A and B vaccinations, but there is insufficient evidence to determine effects of these interventions. Studies demonstrating important individual or public health benefits from counseling, immunizations, and following a diagnosis of HCV in asymptomatic patients would help strengthen the case for screening

In pregnant women, although limited evidence suggests an association between prolonged rupture of membranes and vertical transmission of HCV infection, more studies are needed to understand the strength of the association and whether interventions targeted at avoiding prolonged rupture of membranes are effective at reducing risk of transmission.

## Conclusions

Although screening can accurately identify adults with chronic HCV infection, more research is needed to understand the effects of different screening strategies on clinical outcomes. Evidence on effects of knowledge of HCV status and counseling and immunizations in patients diagnosed with HCV infection remains sparse, and more research is needed to understand effective interventions for preventing vertical transmission. A complete assessment of benefits and harms of screening requires consideration of the effectiveness of antiviral regimens, which are the subject of a complementary review.

## Supplemental Tables

Supplemental Table 1 Key Question 4a: Diagnostic accuracy individual tests

Supplemental Table 2 Key Question 4a: Diagnostic accuracy indices

Supplemental Table 3 Key Question 4a: Diagnostic accuracy direct comparisons (based on areas under the receiver operating characteristic curve)