# Excluded Studies

Afdhal, Nunes. Evaluation of liver fibrosis: a concise review. Am J Gastro. 2004;99(6):1160-1174. Exclusion reason - no original data. [pmid: 15180741].
Aitken, et al. Does information about IDUs’ injecting networks predict exposure to the hepatitis C virus?. Hepatitis Monthly. 2009;9(1):17-23. Exclusion reason - not relevant.
Al-Faleh, et al. Treatment of chronic hepatitis C genotype IV with interferon-ribavirin combination in Saudi Arabia: a multicentre study. Journal of Viral Hepatitis. 2000;7(4):287-91. Exclusion reason - wrong outcomes. [pmid: 10886538].
Alice Unah. When liver stiffness is not so straight forward and Fibroscan not so simple. J Gastroenterol Hepatol. 2009;24(6):934-936. Exclusion reason - no original data. [pmid: 19638074].
Al Knawy B, Shiffman M. Percutaneous liver biopsy in clinical practice. Liver Int. 2007;27(9):1166-73. Exclusion reason - not relevant. [pmid: 17919227].
Anderson, et al. Evaluation of a general practice based hepatitis C virus screening intervention. Scott Med J. Aug. 2009;54(3):3-7. Exclusion reason - wrong outcomes. [pmid: 19728405].
Atwell TD, Smith RL, Hesley GK, et al. Incidence of bleeding after 15,181 percutaneous biopsies and the role of aspirin. Am J Roentgenol. 2010;194(3):784-9. Exclusion reason - not relevant. [pmid: 20173160].
Barbaro, et al. Hepatic glutathione deficiency in chronic hepatitis C: quantitative evaluation in patients who are HIV positive and HIV negative and correlations with plasmatic and lymphocytic concentrations and with the activity of the liver disease. American Journal of Gastroenterology. 1996;91(12):2569-73. Exclusion reason - wrong population. [pmid: 8946988].
Bedossa, Carrat. Liver biopsy: the best, not the gold standard. Journal of Hepatology. 2009;50(1):1-3. Exclusion reason - no original data. [pmid: 19017551].
Bialek SR, Terrault NA. The changing epidemiology and natural history of hepatitis C virus infection. Clin Liver Dis. 2006;10(4):697-715. Exclusion reason - not relevant. [pmid: 17164113].
Bini, et al. Prospective multicenter study of eligibility for antiviral therapy among 4,084 U.S. veterans with chronic hepatitis C virus infection. Am J Gastroenterol. 2005;100(8):1772-1779. Exclusion reason - wrong population. [pmid: 16086714].
Borsoi Viana MS, Takei K, Collarile Yamaguti DC, et al. Use of AST platelet ratio index (APRI Score) as an alternative to liver biopsy for treatment indication in chronic hepatitis C. Ann Hepatol. 2009;8(1):26-31. Exclusion reason - not relevant. [pmid: 19221530].
Brener, Treloar. Alcohol and other drug treatment experiences of hepatitis C-positive and negative clients: implications for hepatitis C treatment. Australian Health Review. 2009;33(1):100-106. Exclusion reason - wrong study design. [pmid: 19203339].
Bruggmann, et al. Treatment outcome in relation to alcohol consumption during hepatitis C therapy: An analysis of the Swiss Hepatitis C Cohort Study. Drug and Alcohol Dependence. 2010;110(1–2):167-171. Exclusion reason - wrong population. [pmid: 20334985].
Burt, et al. Serosorting for hepatitis C status in the sharing of injection equipment among Seattle area injection drug users. Drug and Alcohol Dependence. 2009;105(3):215-220. Exclusion reason - wrong population. [pmid: 19720473].
Butt, et al. Reasons for non-treatment of hepatitis C in veterans in care. Journal of Viral Hepatitis. 2005;12(1):81-85. Exclusion reason - not relevant. [pmid: 15655052].
Caldwell S, Northup PG. Bleeding Complication with Liver Biopsy: Is it Predictable?. Clin Gastroenterol Hepatol. 2010;8(10):826-9. Exclusion reason - not relevant. [pmid: 20601136].
Calès, et al. Evaluation and improvement of a reliable diagnosis of cirrhosis by blood tests. Gastroenterologie Clinique et Biologique. 2008;32(12):1050-1060. Exclusion reason - no original data. [pmid: 19019606].
Cales, et al. A novel panel of blood markers to assess the degree of liver fibrosis. Hepatology. 2005;42(6):1373-1381. Exclusion reason - wrong population. [pmid: 16317693].
Cardoso AC, Carvalho-Filho RJ, Marcellin P. Transient elastography in chronic viral hepatitis: a critical appraisal. Gut. Jun. 2011;60(6):759-64. Exclusion reason - not relevant. [pmid: 21450696].
Carey E, Carey WD. Noninvasive tests for liver disease, fibrosis, and cirrhosis: Is liver biopsy obsolete?. Cleve Clin J Med. 2010;77(8):519-27. Exclusion reason - not relevant. [pmid: 20682514].
Castera, et al. Non-invasive evaluation of liver fibrosis using transient elastography. J Hepatol. 2008;48(5):835-847. Exclusion reason - wrong intervention. [pmid: 18334275].
Chan, et al. Changing paradigm in the management of hepatocellular carcinoma improves the survival benefit of early detection by screening. Annals of Surgery. 2008;247(4):666-673. Exclusion reason - wrong population. [pmid: 18362630].
Cheung, et al. Galectin-3-binding protein: a serological and histological assessment in accordance with hepatitis C-related liver fibrosis. European Journal of Gastroenterology & Hepatology. 2010;22(9):1066-1073. [doi: 10.1097/MEG.0b013e328337d602]. Exclusion reason - wrong outcomes. [pmid: 20186066].
Cheung, et al. Effectiveness of a screening program for hepatitis C. Digestive Diseases & Sciences. May. 2006;51(5):976-81. Exclusion reason - wrong outcomes. [pmid: 16642419].
Conrad SGL, Cooksley WGE, Dunne MP, Macdonald GA. Living with chronic hepatitis C infection means ‘you just haven’t got a normal life any more’. Chronic Illn. 2006;2(2):121-31. Exclusion reason - not relevant. [pmid: 17175655].
Cox, et al. Access to sterile injecting equipment is more important than awareness of HCV status for injection risk behaviors among drug users. Substance Use and Misuse. 2009;44(4):548-568. Exclusion reason - wrong study design. [pmid: 19242863].
Crofts, et al. Epidemiology of hepatitis C virus infection among injecting drug users in Australia. Journal of Epidemiology and Community Health. December. 1. 1997. 1997;51(6):692-697. Exclusion reason - wrong outcomes. [pmid: 9519134].
Croquet, et al. Prothrombin index is an indirect marker of severe liver fibrosis. European Journal of Gastroenterology & Hepatology. 2002;14(10):1133-1141. Exclusion reason - wrong population. [pmid: 12362105].
Cullen, et al. Management of hepatitis C among drug users attending general practice in Ireland: Baseline data from the dublin area Hepatitis C in general practice initiative. European Journal of General Practice. 2007;13(1):5-12. Exclusion reason - wrong study design. [pmid: 17366287].
Cullen, et al. Hepatitis C infection among injecting drug users in general practice: A cluster randomised controlled trial of clinical guidelines’ implementation. Br J Gen Pract. 2006;56(532):848-856. Exclusion reason - wrong outcomes. [pmid: 17132352].
Dal Molin G, D’Agaro P, Ansaldi F, et al. Mother-to-infant transmission of hepatitis C virus: rate of infection and assessment of viral load and IgM anti-HCV as risk factors. Journal of medical virology. 2002;67(i9n, 7705876):137-42. Exclusion reason - not relevant. [pmid: 11992574].
De Lédinghen, et al. Diagnosis of hepatic fibrosis and cirrhosis by transient elastography in HIV/hepatitis C virus-coinfected patients. J Acquir Immune Defic Syndr. 2006;41(2):175-179. Exclusion reason - wrong intervention. [pmid: 16394849].
De Lédinghen, et al. Liver Stiffness Measurement in Children Using FibroScan: Feasibility Study and Comparison With Fibrotest, Aspartate Transaminase to Platelets Ratio Index, and Liver Biopsy. Journal of Pediatric Gastroenterology and Nutrition. 2007;45(4):443-450. [doi: 10.1097/MPG.0b013e31812e56ff]. Exclusion reason - wrong population. [pmid: 18030211].
Defossez, et al. Evaluation of the French national plan to promote screening and early management of viral hepatitis C, between 1997 and 2003: a comparative cross-sectional study in Poitou-Charentes region. European Journal of Gastroenterology & Hepatology. May. 2008;20(5):367-72. Exclusion reason - wrong population. [pmid: 18403936].
Delarocque-Astagneau, et al. The impact of the prevention programme of hepatitis C over more than a decade: the French experience. Journal of Viral Hepatitis. Jun. 2010;17(6):435-43. Exclusion reason - wrong study design. [pmid: 19780936].
Deuffic-Burban, et al. Impact of pegylated interferon and ribavirin on morbidity and mortality in patients with chronic hepatitis C and normal aminotransferases in France. Hepatology. 2009;50(5):1351-1359. Exclusion reason - not relevant. [pmid: 19676130].
Dieperink E, Ho SB, Heit S, et al. Significant reductions in drinking following brief alcohol treatment provided in a hepatitis C clinic. Psychosomatics. 2010;51(2):149-56. Exclusion reason - not relevant. [pmid: 20332290].
Doehring, et al. Screening for IL28B gene variants identifies predictors of hepatitis C therapy success. Antiviral Therapy. 2010;15(8):1099-1106. Exclusion reason - not relevant. [pmid: 21149916].
Drainoni M. Effectiveness of a Risk Screener in Identifying Hepatitis C Virus in Primary Care. Exclusion reason - unable to find.
El-Serag. Hepatocellular carcinoma. CORD Conference Proceedings. 2011;365(12):1118-27. Exclusion reason - not relevant. [pmid: 21992124].
El-Serag HB. Hepatocellular carcinoma: recent trends in the United States. Gastroenterology. 2004;127(5 Suppl 1):S27-34. Exclusion reason - not relevant. [pmid: 15508094].
England K, Pembrey L, Tovo PA, et al. Excluding hepatitis C virus (HCV) infection by serology in young infants of HCV-infected mothers. Acta Paediatrica International Journal of Paediatrics. 2005;94(4):444-50. Exclusion reason - not relevant. [pmid: 16092459].
England K, Thorne C, Newell ML. Vertically acquired paediatric coinfection with HIV and hepatitis C virus. Lancet Infect Dis. 2006;6(2):83-90. Exclusion reason - not relevant. [pmid: 16439328].
Fabris P, Tositti G, Giordani MT, et al. Assessing patients’ understanding of hepatitis C virus infection and its impact on their lifestyle. Ailment Pharmacol Ther. 2006;23(8):1161-70. Exclusion reason - not relevant. [pmid: 16611277].
Follett, et al. HCV confirmatory testing of blood donors. Lancet. 1991;338(8773):1024. Exclusion reason - wrong intervention. [pmid: 1681334].
Foucher, et al. Diagnosis of cirrhosis by transient elastography (FibroScan): a prospective study. Gut. 2006;55(3):403-8. Exclusion reason - wrong intervention. [pmid: 16020491].
Fried. Pegylated interferon in combination with ribavirin: efficacy and safety results from a phase III randomized actively controlled multicenter study. [abstract]. Gastroenterology. 2001;120(Suppl):A-55. Exclusion reason - not relevant.
Fukuhara, et al. Variants in IL28B in liver recipients and donors correlate with response to peg-interferon and ribavirin therapy for recurrent hepatitis C. Gastroenterology. 2010;139(5):1577-1585. e3. Exclusion reason - not relevant. [pmid: 20708617].
Ganne-Carrié, et al. Accuracy of liver stiffness measurement for the diagnosis of cirrhosis in patients with chronic liver diseases. Hepatology. 2006;44(6):1511-1517. Exclusion reason - wrong intervention. [pmid: 17133503].
Garfein, et al. A peer-education intervention to reduce injection risk behaviors for HIV and hepatitis C virus infection in young injection drug users. AIDS. Sep. 12. 2007;21(14):1923-32. Exclusion reason - wrong population. [pmid: 17721100].
Gebo, et al. Role of liver biopsy in management of chronic hepatitis C: A systematic review. Hepatology. 2002;36:S161-172. [doi: 10.1002/hep.1840360721]. Exclusion reason - wrong study design. [pmid: 12407590].
Giacchino R, Tasso L, Timitilli A, et al. Vertical transmission of hepatitis C virus infection: usefulness of viremia detection in HIV-seronegative hepatitis C virus-seropositive mothers. The Journal of pediatrics. 1998;132(jlz, 0375410):167-9. Exclusion reason - not relevant. [pmid: 9470023].
Gidding. Predictors of deferral of treatment for hepatitis C infection in Australian clinics. Medical Journal of Australia. 2011;194(8):398-402. Exclusion reason - wrong outcomes. [pmid: 21495939].
Goldberg, Seth. Hepatitis C services and individuals with serious mental illness. Community Mental Health Journal. 2008;44(5):381-384. Exclusion reason - not relevant. [pmid: 18465227].
Goldstein, et al. Serum alpha-fetoprotein levels in patients with chronic hepatitis C. Relationships with serum alanine aminotransferase values, histologic activity index, and hepatocyte MIB-1 scores. A J Clin Pathol. 1999;111(6):811-6. Exclusion reason - wrong population. [pmid: 10361518].
Granovsky MO, Minkoff HL, Tess BH, et al. Hepatitis C virus infection in the mothers and infants cohort study. Pediatrics. 1998;102(oxv, 0376422):355-9. Exclusion reason - not relevant. [pmid: 9685438].
Grebely, et al. Factors associated with uptake of treatment for recent hepatitis C virus infection in a predominantly injecting drug user cohort: The ATAHC study. Drug and Alcohol Dependence. 2010;107(2–3):244-249. Exclusion reason - not relevant. [pmid: 19926405].
Groessl, et al. Development of the Hepatitis C Self-Management Program. Patient Education and Counseling. 2011;83(2):252-255. Exclusion reason - not relevant. [pmid: 20638216].
Hagan, et al. Reduced risk of hepatitis B and hepatitis C among injection drug users in the Tacoma syringe exchange program. Am J Public Health. November. 1. 1995. 1995;85(11):1531-1537. Exclusion reason - not relevant. [pmid: 7485666].
Hahn, et al. Hepatitis C virus risk behaviors within the partnerships of young injecting drug users. Addiction. 2010;105(7):1254-1264. Exclusion reason - not relevant. [pmid: 20491725].
Hahn, et al. Potential impact of vaccination on the hepatitis C virus epidemic in injection drug users. Epidemics. 2009;1(1):47-57. Exclusion reason - wrong study design. [pmid: 20445816].
Hagan H, Campbell J, Thiede H, et al. Self-reported hepatitis C virus antibody status and risk behavior in young injectors. Public Health Rep. 2006;121(6):710-9. Exclusion reason - not relevant. [pmid: 17278406].
Hagan H, Pouget ER, Des Jarlais DC, et al. Meta-regression of hepatitis C virus infection in relation to time since onset of illicit drug injection: the influence of time and place. CORD Conference Proceedings. 2008;168(10):1099-109. Exclusion reason - not relevant. [pmid: 18849303].
Hare, et al. Comparison of characteristics of treated and non-treated patients with Hepatitis C infection. Pharmacoepidemiology and Drug Safety. 2006;15(2):71-76. Exclusion reason - wrong outcomes. [pmid: 16136612].
Harris. Pleasure and Guilt: Alcohol Use and Hepatitis C. Qualitative Health Research. 2010. April. 19. 2010. Exclusion reason - wrong study design. [pmid: 20404360].
Hepburn, et al. The accuracy of the report of hepatic steatosis on ultrasonography in patients infected with hepatitis C in a clinical setting: A retrospective observational study. BMC Gastroenterology. 2005;5:14. Exclusion reason - not relevant. [pmid: 15829009].
Hoffmann, et al. Sarcoidosis associated with interferon-alpha therapy for chronic hepatitis C. Journal of Hepatology. 1998;28(6):1058-63. Exclusion reason - wrong outcomes. [pmid: 9672184].
Holmberg S, Ly KN, Xing J, et al. The growing burden of mortality associated with viral hepatitis in the United States, 1999–2007. [abstract #243]. Hepatology. 48. 2011;54(4 suppl):3A. Exclusion reason - not relevant. [pmid: 21710471].
Huang JF, Hsieh MY, Dai CY, et al. The incidence and risks of liver biopsy in non-cirrhotic patients: An evaluation of 3806 biopsies. Gut. 2007;56(5):736-7. Exclusion reason - not relevant. [pmid: 17440193].
Hung, et al. Long-term effect of interferon alpha-2b plus ribavirin therapy on incidence of hepatocellular carcinoma in patients with hepatitis C virus-related cirrhosis. Journal of Viral Hepatitis. 2006;13(6):409-414. Exclusion reason - not relevant. [pmid: 16842444].
Hwang, et al. Hepatitis B and hepatitis C prevalence and treatment referral among Asian Americans undergoing community-based hepatitis screening. American Journal of Public Health. Apr. 1. Suppl 1. 2010;100:S118-24. Exclusion reason - not relevant. [pmid: 20147697].
Ilan Y. Review article: the assessment of liver function using breath tests. Aliment Pharmacol Ther. 2007;26(10):1293-302. Exclusion reason - not relevant. [pmid: 17868431].
Kalambokis G, Manousou P, Vibhakorn S, et al. Transjugular liver biopsy--indications, adequacy, quality of specimens, and complications--a systematic review. J Hepatol. 2007;47(2):284-94. Exclusion reason - not relevant. [pmid: 17561303].
Kamal, et al. Peginterferon alfa-2b therapy in acute hepatitis C: Impact of onset of therapy on sustained virologic response. Gastroenterology. 2006;130(3):632-638. Exclusion reason - wrong population. [pmid: 16530503].
Kapadia, et al. Design and feasibility of a randomized behavioral intervention to reduce distributive injection risk and improve health-care access among hepatitis C virus positive injection drug users: The Study to Reduce Intravenous Exposures (STRIVE). Journal of Urban Health. 2007;84(1):99-115. Exclusion reason - not relevant. [pmid: 17200799].
Kilbourne, et al. Guideline-concordant hepatitis C virus testing and notification among patients with and without mental disorders. General Hospital Psychiatry. Nov–Dec. 2008;30(6):495-500. Exclusion reason - wrong intervention. [pmid: 19061674].
Kim, et al. Blood cell, liver function, and response changes by PEG-interferon-(alpha)2b plus ribavirin with polaprezinc therapy in patients with chronic hepatitis C. Hepatology International. 2008;2(1):111-115. Exclusion reason - not relevant. [pmid: 19669286].
King, et al. Assessment and proposal of a new combination of screening criteria for hepatitis C in France. Eur J Public Health. Oct. 2009;19(5):527-33. Exclusion reason - wrong outcomes. [pmid: 19667051].
Kramer, et al. Importance of Patient, Provider, and Facility Predictors of Hepatitis C Virus Treatment in Veterans: A National Study. Am J Gastroenterol. 2011;106(3). Exclusion reason - wrong population. [pmid: 21063393].
Kraus, et al. Psychiatric side effects of pegylated interferon alfa-2b as compared to conventional interferon alfa-2b in patients with chronic hepatitis C. World Journal of Gastroenterology. 2005;11(12):1769-1774. Exclusion reason - not relevant. [pmid: 15793861].
Kumar, et al. Influence of quasispecies on virological responses and disease severity in patients with chronic hepatitis C. World Journal of Gastroenterology. 2008;14(5):701-708. Exclusion reason - not relevant. [pmid: 18205258].
Kwiatkowski CF, Fortuin Corsi K, Booth RE. The association between knowledge of hepatitis C virus status and risk behaviors in injection drug users. Addiction. 2002;97(10):1289-94. Exclusion reason - not relevant. [pmid: 12359033].
Lebray, et al. Liver stiffness is an unreliable marker of liver fibrosis in patients with cardiac insufficiency. Hepatology. 2008;48(6):2089. Exclusion reason - not relevant. [pmid: 19003902].
Lee SR, Kardos KW, Schiff E, et al. Evaluation of a new, rapid test for detecting HCV infection, suitable for use with blood or oral fluid. J Virol Methods. 2010;172(1–2):27-31. Exclusion reason - not relevant. [pmid: 21182871].
Lee SR, Yearwood GD, Guillon GB, et al. Evaluation of a rapid, point-of-care test device for the diagnosis of hepatitis C infection. CORD Conference Proceedings. 2010;48(1):15-7. Exclusion reason - not relevant. [pmid: 20362493].
Leroy. Other non-invasive markers of liver fibrosis. Clin Res Hepatol Gastroenterol. 2008;32(6 Suppl 1):52-57. Exclusion reason - no original data. [pmid: 18973846].
Lin, et al. Performance of the aspartate aminotransferase-to-platelet ratio index for the staging of hepatitis C-related fibrosis: An updated meta-analysis. Hepatology. 2011;53(3):726-736. Exclusion reason - wrong study design. [pmid: 21319189].
Lindenburg, et al. Hepatitis C testing and treatment among active drug users in Amsterdam: Results from the DUTCH-C project. Eur J Gastroenterol Hepatol. 2011;23(1):23-31. Exclusion reason - not relevant. [pmid: 21042221].
Lorenzo-Zúniga, et al. Serum Concentrations of Insulin-Like Growth Factor-I (IGF-I) as a Marker of Liver Fibrosis in Patients With Chronic Hepatitis C. Digestive Diseases and Sciences. 2007;52(11):3245-3250. Exclusion reason - wrong outcomes. [pmid: 17410466].
Lucidarme, et al. Factors of accuracy of transient elastography (fibroscan) for the diagnosis of liver fibrosis in chronic hepatitis C. Hepatology. 2009;49(4):1083-1089. Exclusion reason - wrong intervention. [pmid: 19140221].
Lurie, et al. Medex Test, a Novel Modality for Liver Disease Diagnosis: A Pilot Study. Journal of Clinical Gastroenterology. 2007;41(7):700-705. [doi: 10.1097/01.mcg.0000225641.83275.6a]. Exclusion reason - wrong population. [pmid: 17667055].
Maclean, Fox. Universal hepatitis C screening in genitourinary medicine. International Journal of STD & AIDS. Jul. 2010;21(7):504-5. Exclusion reason - wrong study design. [pmid: 20852201].
Malik, et al. A prospective study of change in visual function in patients treated with pegylated interferon alpha for hepatitis C in the UK. British Journal of Ophthalmology. 2008;92(2):256-258. Exclusion reason - not relevant. [pmid: 17962387].
Manolakopoulos S, Triantos C, Bethanis S, et al. Ultrasound-guided liver biopsy in real life: comparison of same-day prebiopsy versus real-time ultrasound approach. J Gastroenterol Hepatol. 2007;22(9):1490-3. Exclusion reason - not relevant. [pmid: 17573828].
Maor, et al. Improving estimation of liver fibrosis using combination and newer noninvasive biomarker scoring systems in hepatitis C-infected haemophilia patients. Haemophilia. 2007;13(6):722-729. Exclusion reason - wrong population. [pmid: 17973848].
Mapagu, et al. Screening for hepatitis C in sexual health clinic attendees. Sexual Health. Mar. 2008;5(1):73-6. Exclusion reason - wrong study design. [pmid: 18361858].
Martin, et al. Optimal Control of Hepatitis C Antiviral Treatment Programme Delivery for Prevention amongst a Population of Injecting Drug Users. PLoS ONE. 2011;6(8):e22309. Exclusion reason - not relevant. [pmid: 21853030].
Martin, et al. Can antiviral therapy for hepatitis C reduce the prevalence of HCV among injecting drug user populations? A modeling analysis of its prevention utility. J Hepatol. 2011;54(6):1137-1144. Exclusion reason - not relevant. [pmid: 21145810].
Martin, et al. The cost-effectiveness of HCV antiviral treatment for injecting drug user populations. Hepatology. 2011;55(1). Exclusion reason - not relevant. [pmid: 21898506].
Martinez, et al. Noninvasive assessment of liver fibrosis. Hepatology. 2011;53(1):325-35. Exclusion reason - wrong study design. [pmid: 21254180].
Matser, et al. The effect of hepatitis C treatment and HIV coinfection on the disease burden of hepatitis C among injecting drug users in Amsterdam. Addiction. 2011. no-no. Exclusion reason - not relevant. [pmid: 21919987].
Meffre, et al. Prevalence of hepatitis B and hepatitis C virus infections in france in 2004: Social factors are important predictors after adjusting for known risk factors. Journal of Medical Virology. 2010;82(4):546-555. Exclusion reason - not relevant. [pmid: 20166185].
Mehta, et al. Exceeding the limits of liver histology markers. Journal of Hepatology. 2009;50(1):36-41. Exclusion reason - wrong outcomes. [pmid: 19012989].
Melia, et al. Analysis of reasons for treatment ineligibility in the IDEAL study: African Americans (AA) vs non-African Americans (non-AA). Hepatology. 2009;50:702A-703A. Exclusion reason - not relevant.
MMWR. Prevalence of Selected Risk Behaviors and Chronic Diseases --- Behavioral Risk Factor Surveillance System (BRFSS), 39 Steps Communities, United States, 2005. Surveillance Summaries: Morbidity and Mortality Weekly Report (MMWR). 2008:1-20. Exclusion reason - not relevant.
Monnet, et al. Targeted hepatitis C screening: How to reach high risk populations? Lesson learnt from a campaign in a rural area [5]. Gastroenterologie Clinique et Biologique. 2004;28(8–9):817-819. Exclusion reason - not relevant. [pmid: 15646548].
Morisco, et al. Retrospective, observational, multicentre study on an Italian population affected by chronic hepatitis C who failed to clear HCV-RNA after the combined therapy (PEG-IFN and ribavirin): NADIR study. Journal of Viral Hepatitis. 2010;17(6):427-434. Exclusion reason - not relevant. [pmid: 19780939].
Myers, et al. Serum biochemical markers accurately predict liver fibrosis in HIV and hepatitis C virus-coinfected patients. AIDS. 2003;17:1-5. [doi: 10.1097/00002030–200303280-00010]. Exclusion reason - wrong population. [pmid: 12478064].
Myers RP, Fong A, Shaheen AA. Utilization rates, complications and costs of percutaneous liver biopsy: a population-based study including 4275 biopsies. Liver Int. 2008;28(5):705-12. Exclusion reason - not relevant. [pmid: 18433397].
Nalpas, et al. Hepatitis C viremia and anti-HCV antibodies in alcoholics. Journal of Hepatology. 1992;14(2–3):381-384. Exclusion reason - wrong outcomes. [pmid: 1380027].
Narasimhan, et al. Treatment rates in patients with chronic hepatitis C after liver biopsy. Journal of Viral Hepatitis. 2006;13(11):783-786. Exclusion reason - wrong population. [pmid: 17052279].
Nash, et al. Hepatocellular carcinoma in patients with chronic hepatitis C virus infection without cirrhosis. World Journal of Gastroenterology. 2010;16(32):4061-4065. Exclusion reason - wrong study design. [pmid: 20731020].
Nalpas B, Martin S, Fontaine H, et al. Impact of medical recommendations on alcohol consumption in HCV positive patients. J Hepatol. 2001;35(2):312-3. Exclusion reason - not relevant. [pmid: 11580161].
National Center for HIV/AIDS VH, STD & TB Prevention. Disease Burden from Viral Hepatitis A, B, and C in the United States [pdf]. Center for Disease Control. 2011. http://www.cdc.gov/hepatitis/pdfs/disease_burden.pdf. Accessed on October 27 2011. Exclusion reason - not relevant.
National Guideline C. Viral hepatitis in pregnancy. Rockville MD. Agency for Healthcare Research and Quality (AHRQ). 2011. http://www.guideline.gov. Accessed on 10/28/2011. Exclusion reason - not relevant.
Ndako, et al. Occurrence of antibodies against hepatitis C virus (HCV) among alcoholics. African Journal of Biotechnology. 2010;9(52):8908-8912. Exclusion reason - wrong study design.
Neumeister, et al. Hepatitis-C prevalence in an urban native-American clinic: a prospective screening study. Journal of the National Medical Association. Apr. 2007;99(4):389-92. Exclusion reason - wrong study design. [pmid: 17444428].
Nguyen, Talwalkar. Noninvasive assessment of liver fibrosis. Hepatology. 2011;53(6):2107-2110. Exclusion reason - no original data. [pmid: 21547935].
Nguyen, et al. Role of ethnicity in risk for hepatocellular carcinoma in patients with chronic hepatitis C and cirrhosis. Clinical Gastroenterology and Hepatology. 2004;2(9):820-824. Exclusion reason - wrong population. [pmid: 15354283].
Nguyen, et al. Risk factors, genotype 6 prevalence, and clinical characteristics of chronic hepatitis C in Southeast Asian Americans. Hepatology International. 2010;4(2):523-529. Exclusion reason - not relevant. [pmid: 20827411].
Nguyen, et al. Recruitment and follow-up of injecting drug users in the setting of early hepatitis C treatment: Insights from the ATAHC study. International Journal of Drug Policy. 2007;18(5):447-451. Exclusion reason - not relevant. [pmid: 17854736].
Norden, et al. Knowledge of status and assessment of personal health consequences with hepatitis C are not enough to change risk behaviour among injecting drug users in Stockholm County, Sweden. Scandinavian Journal of Infectious Diseases. 2009;41(10):727-734. Exclusion reason - wrong population. [pmid: 19688640].
Ompad DC, Fuller CM, Vlahov D, et al. Lack of behavior change after disclosure of hepatitis C virus infection among young injection drug users in Baltimore, Maryland. Clin Infect Dis. Oct. 1. 2002;35(7):783-8. Exclusion reason - not relevant. [pmid: 12228813].
Page, et al. Acute hepatitis C virus infection in young adult injection drug users: a prospective study of incident infection, resolution, and reinfection. Journal of Infectious Diseases. 2009;200(8):1216-1226. Exclusion reason - not relevant. [pmid: 19764883].
Page-Shafer, et al. Testing strategy to identify cases of acute hepatitis C virus (HCV) infection and to project HCV incidence rates. Journal of Clinical Microbiology. 2008;46(2):499-506. Exclusion reason - not relevant. [pmid: 18032621].
Page-Shafer, et al. Hepatitis C virus infection in young, low-income women: The role of sexually transmitted infection as a potential cofactor for HCV infection. American Journal of Public Health. 2002;92(4):670-676. Exclusion reason - not relevant. [pmid: 11919070].
Paradisi, et al. Safety of etanercept in patients with psoriasis and hepatitis C virus assessed by liver histopathology: Preliminary data. Journal of the American Academy of Dermatology. 2010;62(6):1067-1069. e2. Exclusion reason - not relevant. [pmid: 20466184].
Parkes, et al. Performance of serum marker panels for liver fibrosis in chronic hepatitis C. Journal of Hepatology. 2006;44(3):462-474. Exclusion reason - wrong study design. [pmid: 16427156].
Parvez, Anwar. Diagnostic value of alpha-fetoprotein in liver cancer. Medical Forum Monthly. 2002;13(1):19-21. Exclusion reason - not relevant.
Paternoster, et al. Pregnancy in women infected with the hepatitis C virus. Acta Biomed Ateneo Parmense. Suppl 1. 2000;71:553-7. Exclusion reason - not relevant. [pmid: 11424805].
Paul, et al. Incidence of hepatocellular carcinoma among Indian patients with cirrhosis of liver: An experience from a tertiary care center in northern India. Indian Journal of Gastroenterology. 2007;26(6):274-278. Exclusion reason - not relevant. [pmid: 18431010].
Paul V. Strategies for prevention of viral hepatitis in the United States. International Hepatology Communications. 1996;5(1):3-9. Exclusion reason - no original data.
Paydas, et al. Anti-HCV and HCV-RNA prevalence and clinical correlations in cases with non-Hodgkin’s lymphoma. American Journal of Hematology. 2003;74(2):89-93. Exclusion reason - not relevant. [pmid: 14508793].
Peixoto, et al. Executive functions in chronic hepatitis C virus-infected patients. Advances in Clinical and Experimental Medicine. 2008;17(1):53-60. Exclusion reason - not relevant.
Peixoto, et al. Vertical transmission of hepatitis C virus in a hospital in Southern Brazil. Arquivos de Gastroenterologia. 2004;41(2):84-87. Exclusion reason - wrong population. [pmid: 15543379].
Pekow, et al. Hepatic steatosis is associated with increased frequency of hepatocellular carcinoma in patients with hepatitis C-related cirrhosis. Cancer. 2007;109(12):2490-2496. Exclusion reason - not relevant. [pmid: 17487861].
Pellicano, et al. Interferon (beta)-1a alone or in combination with ribavirin: A randomized trial to compare efficacy and safety in chronic hepatitis C. World Journal of Gastroenterology. 2005;11(29):4484-4489. Exclusion reason - not relevant. [pmid: 16052676].
Pennesi, et al. Sero-placentar viremia and mother-to-infant transmission of the hepatitis C virus. Giornale Italiano di Ostetricia e Ginecologia. 2005;27(3):73-76. Exclusion reason - not relevant.
Pérez, et al. The prevalence of antibodies against hepatitis B abs c virus in odontology students. Prevalencia de anticuerpos contra los virus de hepatitis B y C en estudiantes de odontología. 2002;32(1):21-23. Exclusion reason - not relevant. [pmid: 12136687].
Pergam, et al. Pregnancy complications associated with hepatitis C: data from a 2003–2005 Washington state birth cohort. American Journal of Obstetrics and Gynecology. 2008;199(1). Exclusion reason - not relevant. [pmid: 18486089].
Peters, Rockstroh. Biomarkers of fibrosis and impaired liver function in chronic hepatitis C: how well do they predict clinical outcomes?. Current Opinion in HIV and AIDS. 2010;5(6):517-523. [doi: 10.1097/COH.0b013e32833e3ee6]. Exclusion reason - wrong outcomes. [pmid: 20978395].
Peterson, et al. Effect of tumour necrosis factor (alpha) antagonists on serum transaminases and viraemia in patients with rheumatoid arthritis and chronic hepatitis C infection. Annals of the Rheumatic Diseases. 2003;62(11):1078-1082. Exclusion reason - not relevant. [pmid: 14583571].
Petre, et al. Increased prevalence of reduced estimated glomerular filtration rate in chronic Hepatitis C patients. Digestive Diseases and Sciences. 2010;55(5):1450-1457. Exclusion reason - not relevant. [pmid: 20300844].
Phukan, et al. Magnitude of hepatitis C virus infection in upper Assam [3]. Indian Journal of Gastroenterology. 2003;22(1):34. Exclusion reason - not relevant. [pmid: 12617459].
Pirillo, et al. Seroprevalence of hepatitis B and C viruses among HIV-infected pregnant women in Uganda and Rwanda. Journal of Medical Virology. Dec. 2007;79(12):1797-801. Exclusion reason - wrong study design. [pmid: 17935164].
Polesel, et al. The impact of obesity and diabetes mellitus on the risk of hepatocellular carcinoma. Annals of Oncology. 2009;20(2):353-357. Exclusion reason - not relevant. [pmid: 18723550].
Polis, et al. Impact of maternal HIV coinfection on the vertical transmission of hepatitis C virus: a meta-analysis. Clinical infectious diseases : an official publication of the Infectious Diseases Society of America. 2007;44(a4j, 9203213):1123-31. Exclusion reason - not relevant. [pmid: 17366462].
Polymerou, et al. Evaluation of three immunoassays for hepatitis C virus antibody detection. Clinical Microbiology and Infection. 2010;16:S697. Exclusion reason - not relevant.
Polywka, et al. Accuracy of HCV-RNA PCR tests for diagnosis or exclusion of vertically acquired HCV infection. Journal of Medical Virology. 2006;78(2):305-310. Exclusion reason - wrong population. [pmid: 16372293].
Polywka, et al. The vertical transmission of the hepatitis C virus - Low risk of HCV transmission by breast feeding. Medizinische Welt. 2000;51(11):337-340. Exclusion reason - not relevant.
Polywka, et al. Low risk of vertical transmission of hepatitis C virus by breast milk. Clin Infect Dis. 1999;29(5):1327-1329. Exclusion reason - not relevant. [pmid: 10524987].
Polywka S, Feucht H, Zollner B, et al. Hepatitis C virus infection in pregnancy and the risk of mother-to-child transmission. Eur J Clin Microbiol Infect Dis. Feb. 1997;16(2):121-4. Exclusion reason - not relevant. [pmid: 9105838].
Portolani, et al. Intrahepatic cholangiocarcinoma and combined hepatocellular-cholangiocarcinoma: A Western experience. Annals of Surgical Oncology. 2008;15(7):1880-1890. Exclusion reason - not relevant. [pmid: 18443881].
Poujol-Robert, et al. Association between ABO blood group and fibrosis severity in chronic hepatitis C infection. Digestive Diseases and Sciences. 2006;51(9):1633-1636. Exclusion reason - not relevant. [pmid: 16927132].
Poynard, et al. Overview of the diagnostic value of biochemical markers of liver fibrosis (FibroTest, HCV-Fibrosure) and necrosis (ActiTest) in patients with chronic hepatitis C. Comp Hepatol. 2004;3:8. [doi: 10.1186/1476-5926-3-8]. Exclusion reason - wrong study design. [pmid: 15387887].
Poynard, et al. A comparison of fibrosis progression in chronic liver diseases. Journal of Hepatology. 2003;38(3):257-265. Exclusion reason - not relevant. [pmid: 12586290].
Poynard, et al. Meta-analyses of FibroTest diagnostic value in chronic liver disease. BMC Gastroenterology. 2007;7(1):40. [doi: 10.1186/1471-230X-7-40]. Exclusion reason - wrong study design. [pmid: 17937811].
Poynard, et al. Prospective Analysis of Discordant Results between Biochemical Markers and Biopsy in Patients with Chronic Hepatitis C. Clin Chem. August. 1. 2004. 2004;50(8):1344-1355. Exclusion reason - wrong outcomes. [pmid: 15192028].
Proeschold-Bell, et al. An integrated alcohol abuse and medical treatment model for patients with hepatitis C. Dig Dis Sci. 2011. Exclusion reason - not relevant. [pmid: 22134784].
Proude. Alcohol Reduction for People with Hepatitis C. Discipline of Addiction Medicine. 2009:1-16. Exclusion reason - no original data.
Quaglio, et al. Prevalence and risk factors for viral hepatitis in the Kosovarian population: Implications for health policy. Journal of Medical Virology. 2008;80(5):833-840. Exclusion reason - not relevant. [pmid: 18360897].
Quinti, et al. European surveillance of immunoglobulin safety - Results of initial survey of 1243 patients with primary immunodeficiencies in 16 countries. Clinical Immunology. 2002;104(3):231-236. Exclusion reason - not relevant. [pmid: 12217332].
Quiroga, et al. Identification of serologically silent occult hepatitis C virus infection by detecting immunoglobulin G antibody to a dominant HCV core peptide epitope. Journal of Hepatology. 2009;50(2):256-263. Exclusion reason - not relevant. [pmid: 19070391].
Randhawa, Cashman. Screening for hepatitis C in adults. American Family Physician. 2005;71(5):955-956. Exclusion reason - not relevant. [pmid: 15768624].
Ransy, et al. Maternal immunity and mother-to-child transmission of HCV and HIV-1: Challenges and recent advances. Medecine/ Sciences. 2007;23(11):991-996. Exclusion reason - not relevant. [pmid: 18021713].
Reesink, et al. Mother-to-infant transmission and hepatitis C virus. Lancet. 1990;335(8699):1216-1217. Exclusion reason - not relevant. [pmid: 1971054].
Rhodes, et al. Hepatitis C and its risk management among drug injectors in London: renewing harm reduction in the context of uncertainty. Addiction. May. 2004;99(5):621-33. Exclusion reason - wrong study design. [pmid: 15078237].
Rich, et al. A Syringe Prescription Program to Prevent Infectious Disease and Improve Health of Injection Drug Users. Journal of Urban Health. 2004;81(1):122-134. Exclusion reason - not relevant. [pmid: 15047791].
Rifai, et al. Hepatitis C screening and treatment outcomes in patients with substance use/dependence disorders. Psychosomatics. Mar–Apr. 2006;47(2):112-21. Exclusion reason - wrong population. [pmid: 16508022].
Roberts, Yeung. Maternal-infant transmission of hepatitis C virus infection. Hepatology. 2002;36(51):S106-113. Exclusion reason - not relevant. [pmid: 12407583].
Roblin D, Bryce DBDS, Cindy MCMW, et al. HCV screening practices and prevalence in an MCO, 2000–2007. American Journal of Managed Care. CORD Conference Proceedings. 2011;17(8):548-55. Exclusion reason - not relevant. [pmid: 21851142].
Rockey, Bissell. Noninvasive measures of liver fibrosis. Hepatol. 2006;43(2 Suppl 1):S113-120. Exclusion reason - no original data. [pmid: 16447288].
Rodger AJ, Jolley D, Thompson SC, et al. The impact of diagnosis of hepatitis C virus on quality of life. Hepatology. Nov. 1999;30(5):1299-301. [pmid: 10534353].
Rogers, et al. Hepatitis c as a risk factor for renal cell carcinoma. Journal of Urology. 2009;181(4):112-113. Exclusion reason - not relevant.
Romero Requejo, et al. Perinatal transmission of hepatitis C virus. Journal of Maternal-Fetal and Neonatal Medicine. 2010;23:392. Exclusion reason - not relevant.
Rosenberg. Other non-invasive markers of liver fibrosis. Clin Res Hepatol Gastroenterol. 2008;32(6 Suppl 1):52-57. Exclusion reason - no original data.
Rosenberg, et al. Serum markers detect the presence of liver fibrosis: A cohort study. Gastroenterology. 2004;127(6):1704-1713. Exclusion reason - wrong population. [pmid: 15578508].
Rouse. A significant sex - But not elective Cesarean section - Effect on mother-to-child transmission of hepatitis C virus infection: Commentary. Obstetrical and Gynecological Survey. 2006;61(4):218-219. Exclusion reason - not relevant.
Rowan, et al. Physical and psychosocial contributors to quality of life in veterans with hepatitis C not on antiviral therapy. J Clin Gastroenterol. 2005;39(8):731-736. Exclusion reason - not relevant. [pmid: 16082286].
Roy, et al. Hepatitis C virus incidence among young street-involved IDUs in relation to injection experience. Drug & Alcohol Dependence. Jun. 1. 2009;102(1–3):158-61. Exclusion reason - wrong population. [pmid: 19251382].
Rubio Quevedo, et al. Vertical transmission of hepatitis C virus. Anales Espanoles de Pediatria. Jan. 2001;54(1):27-31. Exclusion reason - not relevant. [pmid: 11181191].
Ruiz Estremera, et al. Study of genetic variation in IL28B and vertical transmission of hepatitis C virus and spontaneous clearance of childhood HCV infection. Journal of Hepatology. 2011;54:S530. Exclusion reason - not relevant.
Ruiz-Extremera, et al. Follow-up of transmission of hepatitis C to babies of human immunodeficiency virus-negative women: The role of breast-feeding in transmission. Pediatric Infectious Disease Journal. 2000;19(6):511-516. Exclusion reason - not relevant. [pmid: 10877164].
Rumi, et al. Hepatitis C reactivation in patients with chronic infection with genotypes 1b and 2c: A retrospective cohort study of 206 untreated patients. Gut. 2005;54(3):402-406. Exclusion reason - not relevant. [pmid: 15710990].
Sabatino. Vertical transmission of hepatitis C virus: An epidemiological study on 2,980 pregnant women in Italy. European Journal of Epidemiology. 1996;12(5):443-447. Exclusion reason - wrong outcomes. [pmid: 8905303].
Saez, et al. Diagnostic and prognostic value of virologic test in vertical transmission of hepatitis C virus infection: Results of a large prospective study in pregnant women. Hepato-Gastroenterology. 2004;51(58):1104-1108. Exclusion reason - not relevant. [pmid: 15239255].
Safir, et al. Maternal hepatitis B virus or hepatitis C virus carrier status as an independent risk factor for adverse perinatal outcome. Liver International. 2010;30(5):765-770. Exclusion reason - wrong outcomes. [pmid: 20214739].
Sagnelli, Pasquale. Vertical and intrafamiliar transmission of HCV. Journal of Preventive Medicine and Hygiene. 1993;34(1–2):97-100. Exclusion reason - not relevant.
Saito HH. Efficacy of non-invasive elastometry on staging of hepatic fibrosis. Hepatol Res. 2004;29(2):97-103. Exclusion reason - wrong intervention. [pmid: 15163431].
Salomon, et al. Cost-effectiveness of Treatment for Chronic Hepatitis C Infection in an Evolving Patient Population. Journal of the American Medical Association. 2003;290(2):228-237. Exclusion reason - not relevant. [pmid: 12851278].
Sandrin, et al. Transient elastography: a new noninvasive method for assessment of hepatic fibrosis. Ultrasound Med Biol. 2003;29(12):1705-1713. Exclusion reason - no original data. [pmid: 14698338].
Sanvisens, et al. Hyaluronic acid, transforming growth factor-beta1 and hepatic fibrosis in patients with chronic hepatitis C virus and human immunodeficiency virus co-infection. J Viral Hepat. 2009;16(7):513-518. Exclusion reason - wrong population. [pmid: 19200132].
Schackman, et al. The cost-effectiveness of elective Cesarean delivery to prevent hepatitis C transmission in HIV-coinfected women. AIDS. 2004;18(aid, 8710219):1827-34. Exclusion reason - not relevant. [pmid: 15316344].
Schöniger-Hekele, Müller. The Combined Elevation of Tumor Markers CA 19–9 and CA 125 in Liver Disease Patients Is Highly Specific for Severe Liver Fibrosis. Digestive Diseases and Sciences. 2006;51(2):338-345. Exclusion reason - wrong population. [pmid: 16534678].
Schwimmer, Balistreri. Transmission, natural history, and treatment of hepatitis C virus infection in the pediatric population. Seminars in Liver Disease. 2000;20(1):37-46. Exclusion reason - wrong intervention. [pmid: 10895430].
Seeff LB, Everson GT, Morgan TR, et al. Complication rate of percutaneous liver biopsies among persons with advanced chronic liver disease in the HALT-C trial. Clin Gastroenterol Hepatol. 2010;8(10):877-83. Exclusion reason - not relevant. [pmid: 20362695].
Seme, et al. Twenty-four mini-pool HCV RNA screening outside a blood transfusion setting: results of a 2-year prospective study. Journal of Virological Methods. Mar. 2007;140(1–2):218-21. Exclusion reason - wrong study design. [pmid: 17157928].
Sène, et al. Biological markers of liver fibrosis and activity as non-invasive alternatives to liver biopsy in patients with chronic hepatitis C and associated mixed cryoglobulinemia vasculitis. Clinical Biochemistry. 2006;39(7):715-721. Exclusion reason - wrong population. [pmid: 16765932].
Shaheen, et al. FibroTest and FibroScan for the Prediction of Hepatitis C-Related Fibrosis: A Systematic Review of Diagnostic Test Accuracy. Am J Gastroenterol. 2007;102(11):2589-2600. Exclusion reason - wrong study design. [pmid: 17850410].
Sharma, Spearman. The Impact of Cesarean Delivery on Transmission of Infectious Agents to the Neonate. Clinics in Perinatology. 2008;35(2):407-420. Exclusion reason - no original data. [pmid: 18456077].
Shebl, et al. Prospective cohort study of mother-to-infant infection and clearance of hepatitis C in rural Egyptian villages. Journal of Medical Virology. 2009;81(6):1024-1031. Exclusion reason - wrong outcomes. [pmid: 19382251].
Shehab, et al. Identification and management of hepatitis C patients in primary care clinics. American Journal of Gastroenterology. 2003;98(3):639-644. Exclusion reason - not relevant. [pmid: 12650800].
Shiah, et al. Phase I and pharmacokinetic study of oral thalidomide in patients with advanced hepatocellular carcinoma. Cancer Chemotherapy and Pharmacology. 2006;58(5):654-664. Exclusion reason - not relevant. [pmid: 16520988].
Shiraki, et al. Maternal-fetal transmission of non-A, non-B viral hepatitis. Nippon rinsho. Japanese journal of clinical medicine. 1988;46(kim, 0420546):2735-43. Exclusion reason - not relevant. [pmid: 3149347].
Shiraki, et al. Non-A, non-B hepatitis in infants and possibilities of maternal infection. Nippon rinsho. Japanese journal of clinical medicine. 1981;39(kim, 0420546):3289-96. Exclusion reason - not relevant. [pmid: 6803028].
Silverman, et al. Detection of hepatitis C virus antibodies and specific hepatitis C virus ribonucleic acid sequences in cord bloods from a heterogeneous prenatal population. American Journal of Obstetrics and Gynecology. 1995;173(5):1396-1400. Exclusion reason - not relevant. [pmid: 7503175].
Simon, Gurakan. Vertical transmission of hepatitis C virus [1]. New England Journal of Medicine. 1994;331(6):399-400. Exclusion reason - not relevant. [pmid: 8028624].
Singal, et al. Use of the AST to platelet ratio index in HCV/HIV co-infected patients. Aliment Pharmacol Ther. 2011;33:566-577. Exclusion reason - wrong population. [pmid: 21205257].
Smith. Comparison of Hepatitis C Virus Infection Screening Strategies: Elevated Alanine Aminotransferase Levels Versus Birth Cohort. AASLD Hepatitis Single Topic Conference. Exclusion reason - unable to find.
Smith, et al. Performance of premarket rapid hepatitis C virus antibody assays in 4 national human immunodeficiency virus behavioral surveillance system sites. Clin Infect Dis. 2011;53(8):780-786. Exclusion reason - not relevant. [pmid: 21921221].
Smith, Sterling. Systematic review: non-invasive methods of fibrosis analysis in chronic hepatitis C. Alimentary Pharmacology & Therapeutics. 2009;30(6):557-576. Exclusion reason - wrong study design. [pmid: 19519733].
Smith B, Jan JD, Amy AJ, et al. Evaluation of three rapid screening assays for detection of antibodies to hepatitis C virus. CORD Conference Proceedings. 2011;204(6):825-31. Exclusion reason - not relevant. [pmid: 21849279].
Snyder, et al. The APRI may be enhanced by the use of the FIBROSpect II in the estimation of fibrosis in chronic hepatitis C. Clinica Chimica Acta. 2007;381(2):119-123. Exclusion reason - not relevant. [pmid: 17442291].
Somsouk, et al. A cost-identification analysis of screening and surveillance of hepatitis C infection in a prospective cohort of dialysis patients. Digestive Diseases and Sciences. 2008;53(4):1093-1099. Exclusion reason - not relevant. [pmid: 17934829].
Søreide. Seroprevalence of bloodborne viruses in Scandinavian trauma victims. Scandinavian Journal of Surgery. 2007;96(1):88. Exclusion reason - not relevant. [pmid: 17461320].
Southern WN, Drainoni ML, Smith BD, et al. Hepatitis C testing practices and prevalence in a high-risk urban ambulatory care setting. J Viral Hepat. 2010. Exclusion reason - no original data.
Soulie. Rationale for a trial of prevention of perinatal transmission of hepatitis C via specific immunoglobulins. Bases decisionnelles d’un essai de prophylaxie de la transmission perinatale de l’hepatite C par immunoglobulines specifiques. 1997;4(bx0, 9423846):213-9. Exclusion reason - not relevant. [pmid: 9162427].
Soza, Lopez-Lastra. Hepatitis C in Chile: burden of the disease. Revista Medica de Chile. Jun. 2006;134(6):777-88. Exclusion reason - wrong study design. [pmid: 17130955].
Stark, et al. Prevalence and determinants of anti-HCV seropositivity and of HCV genotype among intravenous drug users in Berlin. Scandinavian Journal of Infectious Diseases. 1995;27(4):331-7. Exclusion reason - wrong outcomes. [pmid: 8658065].
Stein, et al. Hepatitis C disease among injection drug users: knowledge, perceived risk and willingness to receive treatment. Drug and Alcohol Dependence. 2001;61(3):211-215. Exclusion reason - not relevant. [pmid: 11164684].
Stein, et al. Organic or psychosomatic? Facilitating inquiry with children and parents. Journal of Developmental and Behavioral Pediatrics. 2003;24(5):359-363. Exclusion reason - not relevant. [pmid: 14578697].
Steininger C, Kundi M, Jatzko G, et al. Increased risk of mother-to-infant transmission of hepatitis C virus by intrapartum infantile exposure to maternal blood. The Journal of infectious diseases. 2003;187(ih3, 0413675):345-51. [pmid: 12552417].
Stewart BJ, Mikocka-Walus AA, Harley H, et al. Help-seeking and coping with the psychosocial burden of chronic hepatitis C: A qualitative study of patient, hepatologist, and counsellor perspectives. Int J Nurs Stud. 2011. Dec. 6. Exclusion reason - not relevant. [pmid: 22154094].
Stine JG, Liss G, Lewis JH. The Safety of Same-Day Endoscopy and Percutaneous Liver Biopsy. Dig Dis Sci. 2010;56(4):1201-6. Exclusion reason - not relevant. [pmid: 20857198].
Stoszek, et al. Prevalence of and risk factors for hepatitis C in rural pregnant Egyptian women. Transactions of the Royal Society of Tropical Medicine & Hygiene. Feb. 2006;100(2):102-7. Exclusion reason - wrong outcomes. [pmid: 16289168].
Suárez, et al. Vertical transmission of HCV infection by HIV-negative mothers. [1]. Transmisión vertical de la infección por VHC de madres VIH-negativas. 2004;22(9):555-556. Exclusion reason - not relevant. [pmid: 15511398].
Sulkowski, et al. Peginterferon-alpha-2a (40kD) and ribavirin in patients with chronic hepatitis C: a phase II open-label study. Biodrugs. 2002. 9. 7. 02. 16(2):105-9. Exclusion reason - wrong outcomes. [pmid: 11985484].
Talwalkar. Elastography for Detecting Hepatic Fibrosis: Options and Considerations. Gastroenterology. 2008;135(1):299-302. Exclusion reason - no original data. [pmid: 18555023].
Talwalkar, et al. Ultrasound-Based Transient Elastography for the Detection of Hepatic Fibrosis: Systematic Review and Meta-analysis. Clinical Gastroenterology and Hepatology. 2007;5(10):1214-1220. Exclusion reason - wrong study design. [pmid: 17916549].
Talwalkar, et al. Magnetic resonance imaging of hepatic fibrosis: Emerging clinical applications. Hepatology. 2008;47(1):332-342. Exclusion reason - no original data. [pmid: 18161879].
Tanaka, et al. Epidemiology of hepatitis C virus and hepatocellular carcinoma in Japan. Nippon rinsho. Japanese journal of clinical medicine. Suppl 7. 2004;62(Pt 1):611-614. Exclusion reason - not relevant. [pmid: 15359870].
Taseer, et al. Frequency of anti-HCV, HBsAg and related risk factors in pregnant women at Nishtar Hospital, Multan. Journal of Ayub Medical College, Abbottabad : JAMC. 2010;22(8910750):13-6. Exclusion reason - wrong study design. [pmid: 21409894].
Thomas, et al. Correlates of Hepatitis C Virus Infections among Injection Drug Users. Medicine. 1995;74(4):212-220. Exclusion reason - wrong outcomes. [pmid: 7623656].
Thorpe, et al. Hepatitis C Virus Infection: Prevalence, Risk Factors, and Prevention Opportunities among Young Injection Drug Users in Chicago, 1997–1999. Journal of Infectious Diseases. December. 1. 2000. 2000;182(6):1588-1594. Exclusion reason - not relevant. [pmid: 11069228].
Tibbs. Methods of transmission of hepatitis C. Journal of Viral Hepatitis. 1995;2(3). Exclusion reason - no original data. [pmid: 7493305].
Tovo, et al. Increased risk of maternal-infant hepatitis C virus transmission for women coinfected with human immunodeficiency virus type 1. Clinical Infectious Diseases. 1997;25(5):1121-1124. Exclusion reason - not relevant. [pmid: 9402369].
Tovo, et al. A significant sex - But not elective cesarean section - Effect on mother-to-child transmission of hepatitis C virus infection. Journal of Infectious Diseases. 2005;192(11):1872-1879. Exclusion reason - not relevant. [pmid: 16267757].
Trepka MJ, Zhang G, Leguen F, et al. Benefits and adverse effects of hepatitis C screening: early results of a screening program. J Public Health Manag Pract. May–Jun. 2007;13(3):263-9. Exclusion reason - not relevant. [pmid: 17435493].
Tsiveriotis, et al. Prevalence of HBV, HCV and HIV infections among obstetrics/gynaecology patients. Clinical Microbiology and Infection. 2009;15:S585. Exclusion reason - not relevant.
Tsui, et al. Treatment eligibility and outcomes in elderly patients with chronic hepatitis C: Results from the VA HCV-001 study. Digestive Diseases and Sciences. 2008;53(3):809-814. Exclusion reason - not relevant. [pmid: 17823868].
Tsui JI, Vittinghoff E, Hahn JA, et al. Risk behaviors after hepatitis C virus seroconversion in young injection drug users in San Francisco. Drug Alcohol Depend. 2009;105(1–2):160-3. Exclusion reason - not relevant. [pmid: 19647375].
Tyler Knowledge about hepatitis C virus infection and health care utilization for hepatitis C infection among homeless adults. Vita Thesis (PhD). UCLA. Includes bibliographical references (leaves 113–118). 2009. 2009;(xii, 118 leaves):xii. 118 leaves. Exclusion reason - not relevant.
Uehara, et al. The incidence of vertical transmission of hepatitis C virus. The Tohoku journal of experimental medicine. 1993;171(vtf, 0417355):195-202. Exclusion reason - not relevant. [pmid: 7512756].
Van Den Berg, et al. Never injected, but hepatitis C virus-infected: A study among self-declared never-injecting drug users from the Amsterdam Cohort Studies. Journal of Viral Hepatitis. 2009;16(8):568-577. Exclusion reason - not relevant. [pmid: 19243497].
van der Poorten D, Kwok A, Lam T, et al. Twenty-year audit of percutaneous liver biopsy in a major Australian teaching hospital. Intern Med J. 2006;36(11):692-9. [pmid: 17040353].
Varaut, et al. Diagnostic Accuracy of the Fibrotest in Hemodialysis and Renal Transplant Patients with Chronic Hepatitis C Virus. Transplantation. 2005;80(11):1550-1555. [doi: 10.1097/01.tp.0000183399.85804.02]. Exclusion reason - wrong population. [pmid: 16371924].
Vergniol, et al. Noninvasive tests for fibrosis and liver stiffness predict 5-year outcomes of patients with chronic hepatitis C. Gastroenterology. 2011;140(7):1970-9. 1979.e1. 3. Exclusion reason - wrong outcomes. [pmid: 21376047].
Vicari, et al. Study of mother-to-child transmission of hepatitis C (HCV) and G(GBV-C/HGV) virus infection by polymerase chain reaction (PCR). Trasfusione del Sangue. 1999;44(5):246-253. Exclusion reason - not relevant.
Vidal-Trecan, et al. HCV status knowledge and risk behaviours amongst intravenous drug users. European Journal of Epidemiology. May. 2000;16(5):439-45. Exclusion reason - wrong population. [pmid: 10997831].
Vizzutti, et al. Liver stiffness measurement predicts severe portal hypertension in patients with HCV-related cirrhosis. Hepatology. 2007;45(5):1290-1297. Exclusion reason - not relevant. [pmid: 17464971].
Wahl, et al. Prevalence of antibodies against hepatitis B and C virus among pregnant women and female blood donors in Sweden. Serodiagnosis and Immunotherapy in Infectious Disease. 1994;6(3):127-129. Exclusion reason - not relevant.
West J, Card TR. Reduced mortality rates following elective, percutaneous liver biopsies. Gastroenterology. 2010. 2010;139(4):1230-7. Exclusion reason - not relevant. [pmid: 20547160].
Whiting PF, Rutjes AW, Westwood ME, et al. QUADAS-2: A Revised Tool for the Quality Assessment of Diagnostic Accuracy Studies. Ann Intern Med. 2011;155(8):529-36. Exclusion reason - not relevant. [pmid: 22007046].
Wiese M, Grüngreiff K, Güthoff W, et al. Outcome in a hepatitis C (genotype 1b) single source outbreak in Germany--a 25-year multicenter study. J Hepatol. 2005;43(4):590-8. Exclusion reason - not relevant. [pmid: 16237783].
Wiessing, et al. European monitoring of notifications of hepatitis C virus infection in the general population and among injecting drug users (IDUs) - the need to improve quality and comparability. Euro Surveillance: Bulletin Europeen sur les Maladies Transmissibles = European Communicable Disease Bulletin. 2008;13(21):22. Exclusion reason - wrong study design. [pmid: 18761969].
Williams, et al. Incidence and transmission patterns of acute hepatitis C in the United States, 1982–2006. Archives of Internal Medicine. 2011;171(3):242-248. Exclusion reason - not relevant. [pmid: 21325115].
Wnuk, et al. Prevention of vertical transmission of human immunodeficiency virus (HIV-1) in own material. HIV and AIDS Review. 2006;5(1):30-35. Exclusion reason - wrong population.
Yaari, et al. Detection of HCV salivary antibodies by a simple and rapid test. Journal of Virological Methods. Apr. 2006;133(1):1-5. Exclusion reason - wrong population. [pmid: 16360219].
Yakaryilmaz, et al. Prevalence of occult hepatitis B and hepatitis C virus infections in Turkish hemodialysis patients. Renal Failure. 2006;28(8):729-735. Exclusion reason - wrong population. [pmid: 17162434].
Yamaguchi, et al. HTLV-I, HIV-I, and hepatitis B and C viruses in Western Province, Papua New Guinea: a serological survey. Japanese Journal of Cancer Research. Jul. 1993;84(7):715-9. Exclusion reason - wrong population. [pmid: 7690354].
Yamamoto, et al. Hepatobiliary and pancreatic: Cholangiocellular cancer and hepatitis C. Journal of Gastroenterology and Hepatology. 2003;18(11):1317. Exclusion reason - wrong study design. [pmid: 14535991].
Yanaga, et al. Hepatitis C virus infection among Japanese general surgical patients. World Journal of Surgery. Sep–Oct. 1995;19(5):694-6. discussion 697. Exclusion reason - wrong study design. [pmid: 7571665].
Yanai, et al. Surveillance of infection control procedures in dialysis units in Japan: A preliminary study. Therapeutic Apheresis and Dialysis. 2006;10(1):78-86. Exclusion reason - wrong study design. [pmid: 16556141].
Yanase, et al. The prevalence of HIV, HBV and HCV among Filipino blood donors and overseas work visa applicants. Bulletin of the World Health Organization. Feb. 2007;85(2):131-7. Exclusion reason - wrong population. [pmid: 17308734].
Yang, et al. HIV, syphilis, hepatitis C and risk behaviours among commercial sex male clients in Sichuan province, China. Sexually Transmitted Infections. 2010;86(7):559-564. Exclusion reason - not relevant. [pmid: 20826867].
Yang, et al. Viral hepatitis infections in southern Taiwan: A multicenter community-based study. Kaohsiung Journal of Medical Sciences. 2010;26(9):461-469. Exclusion reason - wrong population. [pmid: 20837342].
Yang, et al. Prevalence and clinical significance of HGV/GBV-C infection in patients with chronic hepatitis B or C. Japanese Journal of Infectious Diseases. Feb. 2006;59(1):25-30. Exclusion reason - wrong population. [pmid: 16495630].
Yang, et al. HCV positivity rate in the seronegative blood donors in China. Biomedicine and Pharmacotherapy. 2009;63(4):319-320. Exclusion reason - wrong population. [pmid: 19246175].
Yano, et al. Clinical features of hepatocellular carcinoma seronegative for both HBsAG and anti-HCV antibody but positive for anti-HBC antibody in Japan. American Journal of Gastroenterology. 2002;97(1):156-161. Exclusion reason - wrong population. [pmid: 11808941].
Yarom, et al. Association between hepatitis C virus infection and oral lichen planus in Israeli patients. Israel Medical Association Journal: Imaj. May. 2007;9(5):370-2. Exclusion reason - wrong population. [pmid: 17591375].
Yawn, et al. Development and maintenance of a community-based hepatitis C registry. Am J Manage Care. Mar. 2002;8(3):253-61. Exclusion reason - not relevant. [pmid: 11915975].
Yazdanpanah, et al. Risk factors for hepatitis C virus transmission to health care workers after occupational exposure: A European case-control study. Revue d’Epidemiologie et de Sante Publique. 2006;54(HS1):1S23-1S31. Exclusion reason - not relevant. [pmid: 17073127].
Yazdanpanah, et al. Risk factors for hepatitis C virus transmission to health care workers after occupational exposure: A European case-control study. Clinical Infectious Diseases. 2005;41(10):1423-1430. Exclusion reason - not relevant. [pmid: 16231252].
Yeung LTF, King SM, Roberts EA. Mother-to-infant transmission of hepatitis C virus. Hepatology. 2001;34(2):223-9. Exclusion reason - not relevant. [pmid: 11481604].
Yildirim, et al. Seroprevalence of hepatitis B and C viruses in the province of Tokat in the Black Sea region of Turkey: A population-based study. Turkish Journal of Gastroenterology. Mar. 2009;20(1):27-30. Exclusion reason - wrong population. [pmid: 19330732].
Yin, et al. Abdominal magnetic resonance elastography. Top Magn Reson Imaging. 2009;20(2):79-87. Exclusion reason - no original data. [pmid: 20010062].
Yoshida, et al. Prevalence of seropositivity for hepatitis C virus in cataract patients and the general population. Journal of Cataract & Refractive Surgery. Oct. 2002;28(10):1789-92. Exclusion reason - wrong population. [pmid: 12388029].
Zakizad, et al. Seroprevalence of hepatitis C infection and associated risk factors among addicted prisoners in Sari-Iran. Pakistan Journal of Biological Sciences. Jul. 15. 2009;12(14):1012-8. Exclusion reason - wrong population. [pmid: 19947179].
Zaller, et al. Risk factors for Hepatitis C virus infection among blood donors in Georgia. European Journal of Epidemiology. 2004;19(6):547-553. Exclusion reason - wrong population. [pmid: 15330127].
Zamani, et al. Prevalence and correlates of hepatitis C virus infection among injecting drug users in Tehran. International Journal of Drug Policy. Oct. 2007;18(5):359-63. Exclusion reason - wrong population. [pmid: 17854723].
Zamani, et al. Prevalence of HIV/HCV/HBV infections and drug-related risk behaviours amongst IDUs recruited through peer-driven sampling in Iran. International Journal of Drug Policy. 2010;21(6):493-500. Exclusion reason - wrong population. [pmid: 20483578].
Zanetti AR, Tanzi E, Newell ML. Mother-to-infant transmission of hepatitis C virus. J Hepatol. Suppl(1). 1999;31:96-100. Exclusion reason - not relevant. [pmid: 10622569].
Zein. Vertical transmission of hepatitis C: To screen or not to screen. Journal of Pediatrics. 1997;130(6):859-861. Exclusion reason - not relevant. [pmid: 9202605].
Zeldis, et al. Seroepidemiology of viral infections among intravenous drug users in northern California. Western Journal of Medicine. Jan. 1992;156(1):30-5. Exclusion reason - not relevant. [pmid: 1310362].
Zeuzem, et al. Risk factors for the transmission of hepatitis C. Journal of Hepatology. 1996;24(2 Suppl):3-10. Exclusion reason - not relevant. [pmid: 8836883].
Zhang, et al. Hepatitis C virus infection, Linxian, China. Emerging Infectious Diseases. Jan. 2005;11(1):17-21. Exclusion reason - wrong population. [pmid: 15705317].
Zhao, et al. Analysis of true voluntary blood donors with anti-HCV prevalence and implications for donor management in Chongqing, China [4]. Transfusion Medicine. 2007;17(3):210-211. Exclusion reason - wrong population. [pmid: 17561867].
Zheng, et al. Liver fibrosis in chronic viral hepatitis: An ultrasonographic study. World Journal of Gastroenterology. 2003;9(11):2484-2489. Exclusion reason - not relevant. [pmid: 14606081].
Zickmund S, Ho EY, Masuda M, et al. “They treated me like a leper”. Stigmatization and the quality of life of patients with hepatitis C. J Gen Intern Med. 2003;18(10):835-44. [pmid: 14521647].
Zumrutdal, et al. Effect of anti-HCV positivity on markers of malnutrition and inflammation in hemodialysis patients. Renal Failure. 2007;29(1):85-90. Exclusion reason - wrong population. [pmid: 17365915].
Zuure, et al. Using mass media and the internet as tools to diagnose hepatitis Cinfections in the general population. American Journal of Preventive Medicine. 2011;40(3):345-352. Exclusion reason - not relevant. [pmid: 21335268].