# Exact Search Strategy

The following databases have been searched for relevant information and an updated search was conducted in May 2012:

Database Searches: Hepatitis C: Screening/Diagnosis, Treatment, and Pregnancy

Name | Date Limits | Platform Provider
Medline | 2002 to May Week 3 2012 | OvidSP
Embase | 2002–2012 | Embase (Elsevier)
Cochrane Library: CDSR, DARE, CCRCT | 2002–2012 | Cochrane Library
Clinical Trials.gov | 2002–2012
Drugs@FDA | 2002–2012
Health Canada Drug Products Database | 2002–2012
European Public Assessment Reports (European Medicine Agency) | 2002–2012
Scopus | 2002–2012 | Scopus
PsycINFO | 2002 to May Week 4 2012 | OvidSP

Hand Search of Journals & Supplements - Topic-Specific Search Terms

Concept | Controlled Vocabulary | Keywords
Hepatitis C | Hepatitis C/ Hepatitis C, Chronic/ Hepacivirus/OR | hcv.mp hepacivirus$.mp
Screening | Exp Mass screening/ Population surveillance/ Sentinel Surveillance/ Seroepidemiologic Studies/ | ((public$ or communit$ or universal$ or widespread or open$ or unrestricted or group$ or adult$) adj3 (screen$ OR test$ or surveillance)) (antibod$ ADJ3 (test$ or screen$ or surveillance))
Diagnosis | Hepatitis C/di, pa, ra, us Immunoenzyme Techniques/Enzyme-Linked Immunosorbent Assay/ Immunoblotting/ Polymerase Chain Reaction/ Reverse Transcriptase Polymerase Chain Reaction/ Liver function tests/ (liver/AND biopsy/) Breath Tests/ Diagnostic Imaging/ Magnetic Resonance Imaging/ EXP Tomography, X-ray Computed/ Alanine Transaminase/ “sensitivity and specificity”/ Limit of Detection/ ROC Curve/ Diagnostic errors/ False Negative Reactions/ False Positive Reactions/ Hepatitis C Antibodies/ Antibodies, viral/ | ELISA EIA recombinant immunoblot assay RIBA PCR RT-PCR transcription-mediated amplification TMA Branched-chain DNA bDNA radioimmunoblot assay HCV-RNA (liver$ ADJ3 biops$) Fibrosis non-invasive blood test$ blood marker$ breath$ test$ transient elastography Fibrometer FibroTest Hepascore MRI alanine aminotransferase ALT misdiagnos$ CT-scan Ultrasound HCV Antibodies anti hcv anti-hcv
Treatment | Antiviral agents/ Interferons/ Interferon-alpha/ Interferon Alfa-2a/ Interferon Alpha-2b/ Exp Polyethylene Glycols/ Ribavirin/ Exp Protease Inhibitors/ | Interferon$ interferon alpha-2a interferon alpha-2b IFNalpha2a IFNalpha2b interferon alpha 2a interferon alpha 2b pegasys Peg-intron peginterferon alpha-2a peginterferon alpha-2b peginterferon alpha 2a peginterferon alpha 2b pegylated interferon$ IFN$ PEG IFN$ Ribavirin RBV protease inhibitor$ polymerase inhibit$ HCV protease$ Telaprevir boceprevir
Harms - treatment | AE.fs MO.fs PO.fs TO.fs CT.fs AE=adverse effects CT=contraindications MO=mortality PO=poisoning TO=toxicity | Unsafe Safety harm$ complication$ poison$ risk$ side-effect$ side effect$ (undesirable ADJ1 effect$) (treatment ADJ1 emergent) tolerab$ toxic$ adrs (adverse ADJ2 (effect or effects or reaction or reactions or event or events or outcome or outcomes)) (undesirable ADJ1 effect$) (treatment ADJ1 emergent) tolerab$ toxic$ adrs (adverse ADJ2 (effect or effects or reaction or reactions or event or events or outcome or outcomes))
Harms - screening | AE.fs CT.fs AE=adverse effects CT=contraindications | Unsafe Safety Harm Harm complication$ risk$ side-effect$ (undesirable ADJ1 effect$) (treatment ADJ1 emergent) tolerab$ adrs (adverse ADJ2 (effect or effects or reaction or reactions or event or events or outcome or outcomes)) Anxiety anxious$ label$ impact$
Pregnancy | Pregnancy/ Pregnancy Complications, Infectious/ Pregnancy Complications/ Exp Delivery, Obstetric/ Maternal Exposure/ Fetus/ Infant, Newborn/ Infant/ Prenatal Diagnosis/ Neonatal Screening/ Prenatal Care/ Infectious Disease Transmission, Vertical/ Milk, Human/ Breast Feeding/ Postpartum Period/ | gravid$ pregnan$ prenatal perinatal antenatal parturiency partuition gestat$ childbirth child birth reproduct$ birth$ childbearing child-bearing
High Risk Groups | Substance-abuse, Intravenous/ Needle Sharing/ Opioid-Related Disorders/ Unsafe Sex/ Sexual Behavior/ HIV/ HIV Infections/ | high risk high-risk drug$ abuse$
Counseling Immunizations | Counseling/ Sex Counseling/ Health Education/ Patient Education as Topic/ Psychotherapy/ Behavior Therapy/ Cognitive Therapy/ Immunization/ Immunotherapy/ Psychotherapy, Brief/ Socioenvironmental Therapy/

Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) 1947 to June Week 2 2011, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations June 17, 2011

Date Searched: 06/20/2011

1 | Hepatitis C/ or Hepatitis C, Chronic/ or Hepacivirus/ or Hepatitis C.mp. or hepacivirus$.mp. or HCV.mp. | 54983
2 | Mass Screening/ or Population Surveillance/ or Sentinel Surveillance/ or Seroepidemiologic Studies/ or Prenatal Diagnosis/ or Neonatal Screening/ or Infectious Disease Transmission, Vertical/ or Disease Transmission, Infectious/ or tm.fs. or transmi$.ti,ab. or ((public$ or communit$ or universal$ or widespread or open$ or unrestricted or group$ or adult$ or adolescen$ or antibod$) adj3 (screen$ or test$ or surveillance)).ti,ab. | 555260
3 | Pregnancy/ or Pregnancy Complications, Infectious/ or Pregnancy Complications/ or exp Delivery, Obstetric/ or Maternal-Fetal Exchange/ or Fetal Monitoring/ or Labor, Induced/ or Fetus/ or Infant, Newborn/ or Infant/ or Prenatal Care/ or Milk, Human/ or Breast Feeding/ or Postpartum Period/ or exp cesarean section/ or exp obstetric labor/ or amniocentesis/ or chorionic villi/ | 1401109
4 | 1 and 2 and 3 | 1247
5 | remove duplicates from 4 | 1234

Medline Update Search Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) 1946 to October Week 3 2011, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations October 31, 2011

Date Searched: 05/31/2012

1 | Hepatitis C/ or Hepatitis C, Chronic/ or Hepacivirus/ or Hepatitis C.mp. or hepacivirus$.mp. or HCV.mp. | 58120
2 | Mass Screening/ or Population Surveillance/ or Sentinel Surveillance/ or Seroepidemiologic Studies/ or Prenatal Diagnosis/ or Neonatal Screening/ or Infectious Disease Transmission, Vertical/ or Disease Transmission, Infectious/ or tm.fs. or transmi$.ti,ab. or ((public$ or communit$ or universal$ or widespread or open$ or unrestricted or group$ or adult$ or adolescen$ or antibod$) adj3 (screen$ or test$ or surveillance)).ti,ab. | 576254
3 | Pregnancy/ or Pregnancy Complications, Infectious/ or Pregnancy Complications/ or exp Delivery, Obstetric/ or Maternal-Fetal Exchange/ or Fetal Monitoring/ or Labor, Induced/ or Fetus/ or Infant, Newborn/ or Infant/ or Prenatal Care/ or Milk, Human/ or Breast Feeding/ or Postpartum Period/ or exp cesarean section/ or exp obstetric labor/ or amniocentesis/ or chorionic villi/ | 1436320
4 | 1 and 2 and 3 | 1291
5 | remove duplicates from 4 | 1250