# Acknowledgments

We thank our colleagues at the Oregon Evidence-based Practice Center, Robin Paynter, M.L.I.S., and Rose Campbell, M.L.I.S., for conducting the literature searches, and Leah Williams, B.S., Ed Reid, M.A., Alexander Ginsburg, M.A., M.C.R.P., Maya Rowland, M.P.H., and Elaine Graham, M.L.S. for editorial support. We also acknowledge Christina Bougatsos, M.P.H., Ian Blazina, M.P.H., Tracy Dana, M.L.S., and Jessica Griffin, M.S., for assistance with data extraction and evidence table editing. We appreciate and acknowledge the contributions of AHRQ Task Order Officer Christine Chang, M.D., M.P.H., and USPSTF Medical Officer Iris Mabry-Hernandez, M.D., M.P.H. We also thank the Key Informants, members of the Technical Expert Panel, and Peer Reviewers.