# Abbreviations and Acronyms

ACOG: American College of Obstetricians and Gynecologists
AHRQ: Agency for Healthcare Research and Quality
ALT: Alanine aminotransferase
APRI: Aspirate Aminotransferase-Platelet Ratio Index
AST: Aspirate aminotransferase
AUROC: Area under the receiver operating characteristic curve
CDC: Centers for Disease Control and Prevention
CDS: Cirrhosis Discriminant Score
CER: Comparative effectiveness review
CHIP: Children’s Health Insurance Program
CI: Confidence interval
ELF: European Liver Fibrosis Index
ELISA: Enzyme-linked immunoassay
EPC: Evidence-based Practice Center
GGT: Gamma-glutamyl transferase
HAV: Hepatitis A virus
HBV: Hepatitis B virus
HCV: Hepatitis C virus
IVDU: Intravenous drug use
PCR: Polymerase chain reaction
PICOTS: Populations, Interventions, Comparators, Outcomes, Timing and Setting
RIBA: Recombinant immunoblot assay
Simplified ELF: Enhanced Liver Fibrosis Index
SVR: Sustained virologic response
TEP: Technical Expert Panel
TIMP: Tissue inhibitor of metalloproteinase
USPSTF: United States Preventive Services Task Force