# Technical Expert Panel

James Donohue, M.D.

Professor of Medicine

University of North Carolina at Chapel Hill

Chapel Hill, NC

Donna Hamel, R.R.T., R.C.P., C.C.R.P.

Clinical Research Coordinator

Duke University

Durham, NC

Nicholas Hill, M.D.

Professor of Medicine

Tufts University

Boston, MA

Philip Marcus, M.D., M.P.H.

Associate Professor

New York College of Osteopathic Medicine

Old Westbury, NY

James Rollins, M.D., M.S.H.A. Ph.D.

Director, Division of Items and Devices

Centers for Medicare and Medicaid Services

Baltimore, MD

Jeffrey Sankoff, M.D.C.M.

Assistant Professor

University of Colorado Denver

Denver, CO

Eric Siegal, M.D., S.F.H.M.

Assistant Professor of Medicine

University of Wisconsin

Madison, WI

Guy Soo Hoo, M.D., M.P.H.

Clinical Professor of Medicine

University of California, Los Angeles

Los Angeles, CA

Kevin Thorpe, M.Math.

Assistant Professor

University of Toronto

Toronto, Ontario, Canada

John Whitney, M.D.

Clinical Assistant Professor

Albany Medical College

Albany, NY