# Results

## Introduction

In what follows, we begin by presenting the results of our literature searches. We then provide a brief description of the included studies. The remainder of the chapter is organized by Key Question (KQ). Under each KQ, we begin by listing the key points of the findings, followed by a brief description of included studies, followed by a more detailed synthesis of the evidence. The detailed syntheses are organized by major outcome: mortality, rates of intubation or reintubation, myocardial infarction, hospital-acquired pneumonia, length of stay, and other clinical outcomes. We conducted quantitative analyses (i.e., meta-analyses) where possible, as described in the Methods chapter. Results of these analyses are presented graphically in the form of forest plots, and in tabular format.

A list of abbreviations and acronyms used in this chapter is provided at the end of the report.

## Results of Literature Searches

Figure 2 depicts the flow of articles through the literature search and screening process. Searches of PubMed^®^, Embase^®^, and the Cochrane Database of Systematic Reviews yielded 3848 citations, 23 of which were duplicate citations. Manual searching identified 56 additional citations, for a total of 3881 citations. After applying inclusion/exclusion criteria at the title-and-abstract level, 205 full-text articles were retrieved and screened. Of these, 134 were excluded at the full-text screening stage, leaving 71 articles (representing 69 unique studies) for data abstraction. As indicated in Figure 2, many articles/studies were relevant to more than one KQ. The two information request strategies described in the Methods chapter (contacts to device manufacturers and the U.S. Food and Drug Administration) did not result in any additional data for consideration.

Figure 2 Literature flow diagram

^a^Some studies/articles were included for more than one KQ, so that numbers given in this box total to more than 71 articles/69 studies.

Abbreviations: ED = emergency department; KQ = Key Question; RCT = randomized controlled trial

This figure depicts the flow of articles through the literature search and screening process. Searches of PubMed®, Embase®, and the Cochrane Database of Systematic Reviews yielded 3,848 citations, 23 of which were duplicate citations. Manual searching identified 56 additional citations, for a total of 3,881 citations. After applying inclusion/exclusion criteria at the title-and-abstract level, 205 full-text articles were retrieved and screened. Of these, 134 were excluded at the full-text screening stage, leaving 71 articles (representing 69 unique studies) for data abstraction. Many included articles/studies were relevant to more than one KQ. Totals included for each KQ were: 51 articles (49 studies) for KQ 1; 13 articles (12 studies) for KQ 2; 12 articles (12 studies) for KQ 3; and 45 articles (43 studies) for KQ 4.

Appendix E provides a detailed listing of included articles. Appendix F provides a complete list of articles excluded at the full-text screening stage, with reasons for exclusion.

## Description of Included Studies

Overall, we included 69 studies, some of which were relevant to more than one KQ: 49 studies were relevant to KQ 1, 12 to KQ 2, and 12 to KQ 3. Studies were conducted in Europe (61%); Asia (19%); the United States or Canada (12%); and South America, Australia, Africa, or multiple continents (8%). One-third of studies enrolled patients with acute cardiogenic pulmonary edema (ACPE) and another one-third patients with acute respiratory failure due to chronic obstructive pulmonary disease (COPD). Noninvasive positive-pressure ventilation (NPPV) was evaluated infrequently in patients with asthma (5%) and in patients with acute respiratory failure in the postoperative (3%) or post-transplant setting (3%).

Figure 3 maps the direct comparisons between treatments evaluated in this report. The most common comparisons were between bilevel positive airway pressure (BPAP) and supportive care (49% of comparisons), followed by continuous positive airway pressure (CPAP) versus supportive care (17%) and BPAP versus CPAP (16%). Relatively few studies compared any mode of NPPV with invasive ventilation or to conventional weaning (both 7%).

Figure 3 Treatment comparisons evaluated

Abbreviations: Abbreviations: BPAP = bilevel positive airway pressure; CPAP = continuous positive airway pressure; NPPV = noninvasive positive-pressure ventilation

This figure shows the number of direct comparisons between treatments evaluated in this report. The most common comparisons were between BPAP and supportive care (37 comparisons [50% of the total number of comparisons evaluated]), followed by CPAP versus supportive care (13 comparisons [18%]) and BPAP versus CPAP (11 comparisons [15%]). Relatively few studies compared any mode of NPPV with invasive ventilation or with conventional weaning (5 comparisons [7%] each).

Of the 69 studies, 30 (43%) were judged to be of good quality, 31 (45%) of fair quality, and 8 (12%) of poor quality. Considering individual components of study design and conduct, strengths were comparable groups at baseline, good followup, and valid outcome measures. However, only about 50 percent of studies reported power or sample size calculations and clear procedures for random assignment and allocation concealment. Outcomes were not assessed by an observer blind to treatment allocation, but for some outcomes (e.g., death), lack of blinding is unlikely to bias results. One-quarter of studies were supported at least in part by industry; in another 50 percent, conflict of interest was not explicitly addressed.

Further details are provided in the relevant KQ results sections, below, and in Appendix G, which reports details of the characteristics of each included study, including geographical location, clinical setting, study population, intervention(s), comparator(s), and quality rating.

As described in the Methods chapter, we searched ClinicalTrials.gov to identify completed but unpublished studies as a mechanism for ascertaining publication bias. Our search yielded 125 citations. A single reviewer identified 34 of these as potentially relevant; 15 of these had been completed at least 1 year prior to our search of the published literature. Of these 15, 12 were not relevant to our KQs, and the remaining 3 were published and are among our included studies. Of the 17 studies not completed at least 1 year prior to our search of the published literature, 11 were relevant to one or more of our KQs. Eight of these 11 are ongoing (4 applicable to KQ 1; 4 applicable to KQ 3), 1 was terminated early due to mortality benefit, 1 was withdrawn prior to enrollment, and 1 has an indeterminate status. In summary, our search of ClinicalTrials.gov did not find evidence for completed but unpublished studies relevant to our KQs.

## Key Question 1 NPPV Versus Supportive Care or Invasive Ventilation

KQ 1: Is noninvasive positive-pressure ventilation (NPPV) associated with less morbidity (including from intubation), lower mortality, fewer adverse events, or lower medical utilization when compared with supportive medical therapy or invasive ventilation:

a. In adults with chronic obstructive pulmonary disease (COPD) and acute respiratory failure?
b. In adults with acute cardiogenic pulmonary edema (ACPE)?
c. In adults with acute respiratory failure due to other causes including: pneumonia, asthma, obesity-hypoventilation syndrome, and interstitial lung disease?
d. In adults with acute respiratory failure in selective settings including: postoperative setting and post-transplant setting?

### Key Points

- In patients treated for acute respiratory failure, current evidence supports a reduction in mortality when NPPV plus supportive care is used versus supportive care alone. This evidence is strongest for patients with COPD and ACPE, but limited evidence supports an effect in the postoperative and post-transplant settings.
- In patients treated for acute respiratory failure, current evidence supports a reduction in intubation rates when NPPV plus supportive care is used versus supportive care alone. This evidence is strongest for patients with COPD, but also supports an effect in patients with ACPE and in the postoperative and post-transplant settings.
- In patients treated for acute respiratory failure, current evidence supports a reduction in hospital-acquired pneumonia when NPPV plus supportive care is used versus supportive care alone. This evidence is strongest for patients with COPD.
- The evidence does not support an increase in rate of myocardial infarction related to NPPV.
- Evidence for treatment effects of NPPV in acute respiratory failure is sparse in many other etiologic subgroups, including acute respiratory distress syndrome (ARDS) and asthma.
- Effects of NPPV on medical utilization are uncertain.
- Outcomes for psychological response, functional status, or health-related quality of life were not reported. Duration of mechanical ventilation was reported infrequently.

### Description of Included Studies

Forty-nine studies involving 4,527 patients met our inclusion criteria.57-105 Study characteristics are summarized in Table 4. Six studies were conducted in the United States or Canada.74,77,79,81,84,94 Of the 49 studies, 22 (45%) were of good methodological quality,57-59,62-65,67,68,71-73,77,79,87,89,92,94,95,100,104,105 21 (43%) were of fair quality,61,66,70,74-76,78,80-85,88,90,91,93,96-99 and 6 (12%) were of poor quality.60,69,86,101-103 Poor-quality studies tended to be older, smaller, single-center studies with limited reported data. In most instances, the funding source was not reported or was unclear.

Table 4 Study characteristics for comparisons of NPPV versus supportive care or invasive ventilation

Characteristic | NPPV Vs. Supportive Care | NPPV Vs. Invasive Ventilation
Mean age of sample: Median (range) | 68.4 (33.3 to 84.0) | 67.4 (54.5 to 71.9)
Sex: N (%)
Male | 1837 (45%) | 234 (58%)
Female | 1715 (42%) | 112 (28%)
Not reported | 570 (13%) | 59 (15%)
Race: N (%)
African-American | 30 (< 1%) | 0
White | 75 (2%) | 0
Other | 17 (< 1%) | 0
Not reported | 4000 (97%) | 405 (100%)
Morbidity index: Median (range)
APACHE II | 18.0 (10.7 to 20.5); 15 studies | 24.5 (23.5 to 24.5); 3 studies
SAPS | 24.3 (12.0 to 43.5); 12 studies | 12.4 (NR); 1 study
Not reported | 17 studies | 0 studies
Setting: No. of studies (N)
ICU | 18 (994) | 5 (405)
ED | 10 (1616) | 0
Postoperative | 2 (257) | 0
Mixed/Other | 14 (1255) | 0
NPPV modality: No. of studies (N)
BPAP | 28 (1893) | 5 (405)
CPAP | 9 (725) | 0
Mixed/Other | 7 (1504) | 0
Diagnoses: No. of studies (N)
COPD | 15 (1228) | 3 (277)
ACPE | 14 (1926) | 0
Asthma | 3 (121) | 0
Postoperative | 2 (257) | 0
Post-transplant | 3 (178) | 0
ARDS | 1 (40) | 0
Mixed^a^ | 6 (372) | 2 (128)
Geographical region: No. of studies (N)
U.S.A./Canada | 6 (244) | 0
Europe | 24 (2863) | 5 (405)
South America | 2 (209) | 0
Asia | 10 (750) | 0
Multiple continents | 1 (123) | 0
Other/NR | 1 (33) | 0
Funding source: No. of studies (N)^b^
Government | 8 (1784) | 3 (292)
Industry | 3 (243) | 0
Professional society/Foundation | 3 (138) | 0
Not reported/Unclear | 30 (1957) | 2 (113)
Study quality: No. of studies (N)
Good | 21 (2958) | 1 (64)
Fair | 17 (961) | 4 (341)
Poor | 6 (203) | 0

a ”Mixed” diagnosis refers to studies where fewer than 70% of patients had a single etiology for acute respiratory failure.

b Some studies had multiple funding sources; therefore, totals may not sum to the total number of studies.

Abbreviations: ACPE = acute cardiogenic pulmonary edema; APACHE II = Acute Physiology And Chronic Health Evaluation II; ARDS = acute respiratory distress syndrome; COPD = chronic obstructive pulmonary disease; ED = emergency department; ICU = intensive care unit; N = number of participants; NPPV = non-invasive positive-pressure ventilation; NR = not reported; SAPS = Simplified Acute Physiology Score

Regarding the effects of NPPV, 43 studies reported mortality,57-62,64,65,67-71,73,75-81,83-87,89-105 39 studies reported intubation rates,57,59-65,67-71,73,74,77-87,89-91,94,95,99-101,103,104, 93,105 7 studies reported myocardial infarction,62,67,71,81,87,94,100 and 8 studies reported rates of hospital-acquired pneumonia.57,62,70,73,77,89,94,96 No studies reported effects on health-related quality of life or anxiety associated with NPPV use. Most studies enrolled patients with COPD or ACPE who were older adults, although the range of mean ages was broad (33.3 to 84.0). The proportion of females included ranged from 9–79 percent.

Of the 49 studies, 40 compared NPPV plus supportive medical therapy with supportive medical therapy alone, 5 compared NPPV with invasive ventilation,58,66,75,76,98 and 4 were 3-arm trials comparing CPAP, BPAP, and supportive care.67,71,86,99 BPAP was the most common modality used and, when described, was applied with an inspiratory pressure ranging from 6 to 20 cm H2O. CPAP was provided across a range of 2 to 12.5 cm H2O. NPPV was delivered by a helmet interface in one study, through mixed approaches in three, by nasal mask in nine, and by full mask in the remainder of studies. Only three studies71,72,105 described training or provider experience and these studies reported substantial training or high levels of experience with NPPV among providers, and 12 described the type of provider adjusting NPPV; these providers included generalist and critical care trained physicians, nurses, and respiratory therapists.

### Detailed Synthesis

#### Mortality

##### Overview

A total of 43 studies reported the effects of NPPV on mortality and were included in our analyses; 39 compared NPPV with usual supportive care,57,59-62,64,65,67-71,73,77-81,83-87,89-97,99-105 and 4 compared NPPV with invasive ventilation.58,75,76,98 The majority of studies were relatively small in size, with only 9 having ≥ 100 subjects;64,68,70,71,76,83,87,89,99,100 one study71 accounted for almost 25 percent of the total number of patients. Most studies enrolled patients with ACPE or COPD; few studies enrolled patients with asthma, interstitial lung disease, ARDS, or who were post-transplant or postoperative. One study enrolled adults older than age 75 with acute respiratory failure, most of whom had underlying COPD and a “do not intubate” order.104 Approximately two-thirds of the studies reported a morbidity index (Acute Physiology And Chronic Health Evaluation II [APACHE II] or Simplified Acute Physiology Score [SAPS]) that relies primarily on physiological measures. The median predicted mortality for enrolled patients was approximately 12 to 29 percent depending on the measure used.

##### NPPV Versus Supportive Care

Mortality rates ranged from 0 to 33 percent for NPPV and 0 to 80 percent for usual supportive care. Overall, there was a lower risk of mortality when NPPV was employed in addition to usual supportive care (Figure 4). Effects were consistent across studies (Q = 44.1, df = 37, p = 0.20, I^2^ = 16%); funnel plots and test statistics did not suggest publication bias (Appendix D). Because the study by Gray et al.71 contributed a large proportion of subjects, we conducted an influence analysis, recomputing the summary OR after removing one study at a time. No single study affected the pooled OR by more than 5 percent. An exploratory mixed-effects subgroup analysis across study quality and diagnosis also suggested a relatively consistent mortality benefit (Table 5). This effect was most pronounced in the postoperative or post-transplant settings, but CIs overlapped (p = 0.50 for differences in treatment effect by diagnostic group), and confounding factors (factors other than the subgroups being compared, such as comorbid medical conditions) varied across studies and could have affected these results; therefore, results from the subgroup analyses should be interpreted cautiously. The single good-quality trial examining NPPV in older adults, many with “do not intubate” orders, showed lower mortality rates.104 We also conducted an exploratory analysis to determine if there were time trends in the effects of NPPV. Using the year of publication as a proxy for when the study was completed, we found a smaller treatment effect for more recent studies (p = 0.006).

Figure 4 Random-effects analysis of data on mortality—NPPV versus supportive care

Note: “Mixed” diagnosis refers to studies where fewer than 70% of patients had a single etiology for acute respiratory failure.

The study by Barbe et al.60 had zero events in each treatment arm and is not displayed in the forest plot.

Abbreviations: ACPE = acute cardiogenic pulmonary edema; ARDS = acute respiratory distress syndrome; CI = confidence interval; COPD = chronic obstructive pulmonary disease; NPPV = noninvasive positive-pressure ventilation

This figure displays a forest plot of the 39 studies reporting analyzable data on mortality rates in patients receiving NPPV vs. supportive care. The summary odds ratio (OR) was 0.56 (95% CI, 0.44 to 0.72). Effects were consistent across studies (Q = 44.1, df = 37, p = 0.20; I-squared = 16%). These results show a statistically significantly lower risk of mortality with NPPV than with supportive care.

Table 5 Results of meta-analysis of data on mortality for NPPV versus supportive care

Subgroup Category | Subgroup | No. of Studies (N) | Summary OR (95% CI) | Tests for Heterogeneity
All participants | NA | 39 (4111) | 0.56 (0.44 to 0.72) | p = 0.20, I^2^ = 16%
Study quality^a^ | Good | 19 (3085) | 0.59 (0.42 to 0.85) | p = 0.07, I^2^ = 34%
Study quality^a^ | Fair | 14 (827) | 0.50 (0.34 to 0.72) | p = 0.54, I^2^ = 0%
Study quality^a^ | Poor | 6 (199) | 0.46 (0.17 to 1.31) | p = 0.59, I^2^ = 0%
Diagnosis^b^ | ACPE | 13 (1778) | 0.60 (0.41 to 0.88) | p = 0.31, I^2^ = 14%
Diagnosis^b^ | ARDS | 1 (40) | 0.14 (0.01 to 1.33) | NA
Diagnosis^b^ | COPD | 13 (1425) | 0.54 (0.33 to 0.90) | p = 0.32, I^2^ = 12%
Diagnosis^b^ | Mixed^c^ | 7 (433) | 0.71 (0.39 to 1.29) | p = 0.16, I^2^ = 21%
Diagnosis^b^ | Postoperative | 2 (257) | 0.21 (0.06 to 0.80) | p = 0.75, I^2^ = 0%
Diagnosis^b^ | Post-transplant | 3 (178) | 0.50 (0.23 to 1.09) | p = 0.24, I^2^ = 31%

a p = 0.77 for differences in treatment effect by study quality.

b p = 0.50 for differences in treatment effect by diagnosis.

c ”Mixed” diagnosis refers to studies where fewer than 70% of patients had a single etiology for acute respiratory failure.

Abbreviations: ACPE = acute cardiogenic pulmonary edema; ARDS = acute respiratory distress syndrome; CI = confidence interval; COPD = chronic obstructive pulmonary disease; N = number of participants; NA = not applicable; NPPV = noninvasive positive-pressure ventilation; OR = odds ratio

Effects on longer term mortality were reported at 30–120 days in four studies.59,65,70,71 NPPV was associated with a nonstatistically significant reduction in mortality (summary OR 0.58; 95% CI, 0.31 to 1.06; Q = 6.1, df = 3, p = 0.11, I^2^ = 51%).

##### NPPV Versus Invasive Ventilation

Four studies compared NPPV with invasive ventilation and reported effects on mortality.58,75,76,98 Etiology of acute respiratory failure was COPD (two studies) and mixed (two studies). One study was of good quality;58 the others were of fair quality. The mortality rate for invasive ventilation ranged from 6 to 47 percent. Overall, there was no difference in mortality when NPPV was employed versus invasive ventilation (summary OR 0.61; 95% CI, 0.33 to 1.12; Figure 5). Effects were consistent across studies (Q = 0.65, df = 3, p = 0.89, I^2^ = 0%). However, the CI for the summary estimate was wide, and the numbers of patients randomized and events (61 deaths) were small. There were insufficient numbers of studies to perform subgroup analyses.

Figure 5 Random-effects analysis of data on mortality—NPPV versus invasive ventilation

Note: “Mixed” diagnosis refers to studies where fewer than 70% of patients had a single etiology for acute respiratory failure.

Abbreviations: CI = confidence interval; COPD = chronic obstructive pulmonary disease; IVS = invasive ventilator support; NPPV = noninvasive positive-pressure ventilation

This figure displays a forest plot of the four studies reporting data on mortality rates in patients receiving NPPV vs. invasive ventilation. The summary OR was 0.61 (95% CI, 0.33 to 1.12). Effects were consistent across studies (Q = 0.65, df = 3, p = 0.89; I-squared = 0%). These results show no statistically significant difference between NPPV and invasive ventilation for this outcome.

#### Intubation

##### Overview

We identified 39 studies reporting on the relative effects of NPPV versus supportive care on intubation rates;57,59-65,67-71,73,74,77-87,89-91,93-96,99-101,103-105 this outcome was not relevant for studies comparing NPPV with invasive ventilation.

##### NPPV Versus Supportive Care

Intubation rates ranged from 0 to 62 percent for NPPV and 3–77 percent for supportive care. Overall, there was a lower risk of intubation for patients when NPPV was employed in addition to supportive care (summary OR 0.31; 95% CI, 0.24 to 0.41; Figure 6). Tests for heterogeneity showed moderate variability in treatment effects across studies (Q = 59.2, df = 37, p = 0.01, I^2^ = 37%). An exploratory mixed-effects subgroup analysis across study quality and diagnosis showed a relatively stable effect across these subgroups (Table 6), but did not fully explain the observed heterogeneity. In addition, a funnel plot suggested possible publication bias (Appendix D). However, a significant treatment effect remained after adjusting for publication bias (adjusted OR = 0.45; 95% CI, 0.33 to 0.61). As with the analysis for effects on mortality, we conducted an influence analysis to evaluate the influence of single studies on the summary OR. Removing studies sequentially from the analysis did not have a significant impact on the summary OR.

Figure 6 Random-effects analysis of data on intubation rates—NPPV versus supportive care

Note: “Mixed” diagnosis refers to studies where fewer than 70% of patients had a single etiology for acute respiratory failure.

The study by Barbe et al.60 had zero events in each treatment arm and is not displayed in the forest plot.

Abbreviations: ACPE = acute cardiogenic pulmonary edema; ARDS = acute respiratory distress syndrome; CI = confidence interval; COPD = chronic obstructive pulmonary disease; NPPV = noninvasive positive-pressure ventilation

This figure displays a forest plot of the 39 studies reporting analyzable data on intubation rates in patients receiving NPPV vs. supportive care. The summary OR was 0.31 (95% CI, 0.24 to 0.41). Tests for heterogeneity showed moderate variability in treatment effects across studies (Q = 59.2, df = 37, p = 0.01; I-squared = 37%). These results show a statistically significantly lower risk of intubation with NPPV than with supportive care.

Table 6 Results of meta-analysis of data on intubation for NPPV versus supportive care

Subgroup Category | Subgroup | No. of Studies (N) | Summary OR (95% CI) | Tests for Heterogeneity
All participants | NA | 39 (3792) | 0.31 (0.24 to 0.41) | p = 0.01, I^2^ = 37%
Study quality^a^ | Good | 19 (2778) | 0.35 (0.23 to 0.53) | p < 0.001, I^2^ = 60%
Study quality^a^ | Fair | 15 (875) | 0.26 (0.18 to 0.38) | p = 0.75, I^2^ = 0%
Study quality^a^ | Poor | 5 (139) | 0.29 (0.10 to 0.85) | p = 0.94, I^2^ = 0%
Diagnosis^b^ | ACPE | 14 (1813) | 0.36 (0.21 to 0.64) | p = 0.02, I^2^ = 50%
Diagnosis^b^ | ARDS | 1 (40) | 0.14 (0.01 to 1.33) | NA
Diagnosis^b^ | Asthma | 1 (35) | 0.39 (0.03 to 4.74) | NA
Diagnosis^b^ | COPD | 12 (1117) | 0.22 (0.14 to 0.35) | p = 0.16, I^2^ = 30%
Diagnosis^b^ | Mixed^c^ | 6 (352) | 0.47 (0.30 to 0.73) | p = 0.34, I^2^ = 12%
Diagnosis^b^ | Postoperative | 2 (257) | 0.20 (0.07 to 0.58) | p = 0.39, I^2^ = 0%
Diagnosis^b^ | Post-transplant | 3 (178) | 0.27 (0.11 to 0.61) | p = 0.25, I^2^ = 27%

a p = 0.63 for differences in treatment effect by study quality.

b p = 0.32 for differences in treatment effect by diagnosis.

c ”Mixed” diagnosis refers to studies where fewer than 70% of patients had a single etiology for acute respiratory failure.

Abbreviations: ACPE = acute cardiogenic pulmonary edema; ARDS = acute respiratory distress syndrome; CI = confidence interval; COPD = chronic obstructive pulmonary disease; N = number of participants; NA = not applicable; NPPV = noninvasive positive-pressure ventilation; OR = odds ratio

#### Myocardial Infarction

##### Overview

We identified seven studies reporting on the relative effects of NPPV versus supportive care on myocardial infarction rates.62,67,71,81,87,94,100 Etiologies of acute respiratory failure were ACPE (four studies), COPD (two studies), and mixed etiologies (one study). Six of these were judged to be of good quality. Two studies (one good and one fair quality) reported this outcome for NPPV compared with invasive ventilation.58,75 Given little variability in study quality, we did not complete subgroup analyses by quality.

##### NPPV Versus Supportive Care

Rates of myocardial infarction ranged from 2–30 percent for NPPV and from 0 to 30 percent for supportive care. Overall, there was no difference in the rate of myocardial infarction when NPPV was employed in addition to supportive care (Figure 7). There was no significant variability in treatment effects across studies (Q = 2.45, df = 6, p = 0.87, I^2^ = 0%). An exploratory mixed-effects subgroup analysis across diagnosis also suggested no difference in the rate of myocardial infarction related to NPPV; there was no significant difference in treatment effects across these subgroups (Q = 0.32, df = 2, p = 0.85; Table 7).

Figure 7 Random-effects analysis of data on myocardial infarction rates—NPPV versus supportive care

Note: “Mixed” diagnosis refers to studies where fewer than 70% of patients had a single etiology for acute respiratory failure.

Abbreviations: ACPE = acute cardiogenic pulmonary edema; CI = confidence interval; COPD = chronic obstructive pulmonary disease; NPPV = noninvasive positive-pressure ventilation

This figure displays a forest plot of the seven studies reporting data on myocardial infarction rates in patients receiving NPPV vs.supportive care. The summary OR was 1.11 (95% CI, 0.85 to 1.44). Effects were consistent across studies (Q = 2.45, df = 6, p = 0.87; I-squared = 0%). These results show no statistically significant difference between NPPV and supportive care for this outcome.

Table 7 Results of meta-analysis of data on myocardial infarction for NPPV versus supportive care

Subgroup Category | Subgroup | No. of Studies | Summary OR (95% CI) | Tests for Heterogeneity
All participants | NA | 7 | 1.11 (0.85 to 1.44) | p = 0.87, I^2^ = 0%
Diagnosis^a^ | ACPE | 4 | 1.10 (0.83 to 1.45) | p = 0.62, I^2^ = 0%
Diagnosis^a^ | COPD | 2 | 0.81 (0.14 to 4.68) | p = 0.54, I^2^ = 0%
Diagnosis^a^ | Mixed^b^ | 1 | 1.45 (0.43 to 4.82) | NA

a p = 0.85 for differences in treatment effect by diagnosis.

b ”Mixed” diagnosis refers to studies where fewer than 70% of patients had a single etiology for acute respiratory failure.

Abbreviations: ACPE = acute cardiogenic pulmonary edema; CI = confidence interval; COPD = chronic obstructive pulmonary disease; NA = not applicable; NPPV = noninvasive positive-pressure ventilation; OR = odds ratio

##### NPPV Versus Invasive Ventilation

Only two studies comparing NPPV with invasive ventilation reported rates of myocardial infarction.58,75 In each study, fewer patients in the NPPV-treated groups (1 of 31 and 2 of 32) had myocardial infarctions compared with invasive ventilation (2 of 33 and 4 of 32).

#### Hospital-Acquired Pneumonia

##### Overview

We identified nine studies reporting on the relative effects of NPPV versus supportive care on hospital-acquired pneumonia.57,62,70,73,77,89,94,96,105 Seven of these were judged to be of good quality. Four studies compared NPPV with invasive ventilation for this outcome.58,66,75,76

##### NPPV Versus Supportive Care

Rates of hospital-acquired pneumonia ranged from 0–10 percent for NPPV and from 7 to 24 percent for supportive care. Hospital-acquired pneumonia is defined as pneumonia that develops more than 48 hours after hospitalization but that was not incubating at the time of admission. Overall, there was a lower risk of pneumonia when NPPV was employed in addition to usual supportive care (Figure 8). There was no significant variability in treatment effects across studies (Q = 1.09, df = 8, p = 0.99, I^2^ = 0%). An exploratory mixed-effects subgroup analysis across study quality and diagnosis showed a consistent effect across these subgroups (Table 8). An influence analysis showed no significant change in the summary odds ratio by omitting any single study.

Figure 8 Random-effects analysis of data on hospital-acquired pneumonia rates—NPPV versus supportive care

Note: “Mixed” diagnosis refers to studies where fewer than 70% of patients had a single etiology for acute respiratory failure.

Abbreviations: ARDS = acute respiratory distress syndrome; CI = confidence interval; COPD = chronic obstructive pulmonary disease; NPPV = noninvasive positive-pressure ventilation.

This figure displays a forest plot of the nine studies reporting data on hospital-acquired pneumonia rates in patients receiving NPPV vs.supportive care. The summary OR was 0.27 (95% CI, 0.15 to 0.49). Effects were consistent across studies (Q = 1.09, df = 8, p = 0.99; I-squared = 0%). These results show a statistically significantly lower risk of hospital-acquired pneumonia with NPPV than with supportive care.

Table 8 Results of meta-analysis of data on hospital-acquired pneumonia for NPPV versus supportive care

Subgroup Category | Subgroup | No. of Studies | Summary OR (95% CI) | Tests for Heterogeneity
All participants | NA | 9 | 0.27 (0.15 to 0.49) | p = 0.99, I^2^ = 0%
Study quality^a^ | Good | 7 | 0.25 (0.12 to 0.53) | p = 0.99, I^2^ = 0%
Study quality^a^ | Fair | 2 | 0.30 (0.11 to 0.87) | p = 0.52, I^2^ = 0%
Diagnosis^b^ | ARDS | 1 | 0.29 (0.01 to 7.47) | NA
Diagnosis^b^ | COPD | 3 | 0.21 (0.06 to 0.77) | p = 0.92, I^2^ = 0%
Diagnosis^b^ | Mixed^c^ | 2 | 0.31 (0.11 to 0.85) | p = 0.71, I^2^ = 0%
Diagnosis^b^ | Postoperative | 1 | 0.18 (0.04 to 0.85) | NA
Diagnosis^b^ | Post-transplant | 2 | 0.35 (0.10 to 1.20) | p = 0.71, I^2^ = 0%

a p = 0.78 for differences in treatment effect by study quality.

b p = 0.96 for differences in treatment effect by diagnosis.

c ”Mixed” diagnosis refers to studies where fewer than 70% of patients had a single etiology for acute respiratory failure.

Abbreviations: ARDS = acute respiratory distress syndrome; CI = confidence interval; COPD = chronic obstructive pulmonary disease; NA = not applicable; NPPV = noninvasive positive-pressure ventilation; OR = odds ratio

##### NPPV Versus Invasive Ventilation

Four studies reported the relative effects of NPPV versus invasive ventilation on hospital-acquired pneumonia. Overall, there was a markedly lower risk of pneumonia with NPPV (summary OR 0.15; 95% CI, 0.08 to 0.30; Figure 9). There was no significant variability in treatment effects across studies (Q = 2.19, df = 3, p = 0.53, I^2^ = 0%).

Figure 9 Random-effects analysis of data on hospital-acquired pneumonia rates—NPPV versus invasive ventilation

Note: “Mixed” diagnosis refers to studies where fewer than 70% of patients had a single etiology for acute respiratory failure.

Abbreviations: CI = confidence interval; COPD = chronic obstructive pulmonary disease; IVS = invasive ventilator support; NPPV = noninvasive positive-pressure ventilation

This figure displays a forest plot of the four studies reporting data on hospital-acquired pneumonia rates in patients receiving NPPV vs. invasive ventilation. The summary OR was 0.15 (95% CI, 0.08 to 0.30). Effects were consistent across studies (Q = 2.19, df = 3, p = 0.53; I-squared = 0%). These results show a statistically significantly lower risk of hospital-acquired pneumonia with NPPV than with invasive ventilation.

#### Length of Stay

##### NPPV Versus Supportive Care

Twenty-nine studies reported effects on hospital length of stay. Of these, we focused our analysis on the 11 studies with larger sample sizes.63,64,70,71,80,83,87,89,100,102,104 Mean length of stay varied substantially across studies, from 8.5 to 20.7 days for NPPV-treated patients and from 5.1 to 26.8 days for patients receiving supportive care. None of the 11 studies showed a statistically significant difference in length of stay. Two studies reported subgroup analyses on the hospital survivors; neither found a statistically significant effect on length of stay in the survivor and nonsurvivor subgroups.

ICU length of stay was reported in 14 studies. We focused our analyses on the five largest of these.65,70,72,83,89 Mean ICU length of stay range from 1.4 to 10 days in NPPV-treated patients and from 2.6–24 days in patients receiving supportive care. Of the five studies, two found a statistically significant reduction in length of stay with NPPV versus supportive care.65,72

Several issues limit these findings. Length-of-stay data typically have a skewed distribution, making statistical tests that assume normality inappropriate, but such tests were sometimes used in these studies. Second, the results may be biased if NPPV reduces mortality, thus increasing length of stay. Few studies reported subgroup analyses that limited the results to surviving patients. In summary, current evidence does not support shorter hospital length or ICU length of stay with NPPV versus supportive care. However, these results should be interpreted with caution.

##### NPPV Versus Invasive Ventilation

No study reported effects on hospital length of stay. However, five studies reported effects on ICU length of stay.58,66,75,76 Mean ICU length of stay range from 5 to 22 days in NPPV-treated patients and from 9.3 to 21 days in patients receiving invasive ventilation. Of the four studies with larger sample sizes, three found a statistically significant reduction in ICU length of stay.

#### Intolerance and Facial Ulcerations

Ten studies (12 NPPV arms) reported rates of discontinuation due to poor patient tolerability. The median rate of discontinuation was 12.1 percent (range 0–29%). Limiting the analysis to two larger studies, which are more likely to give stable estimates, rates ranged from 3.8–5.2 percent for CPAP71,89 and 8.4 percent for BPAP.71 Rates of facial abrasions or ulcerations were reported in 15 studies and varied widely, ranging from 0 to 47 percent. Variability appears related in part to different definitions for facial injury and in part to differing durations of followup. Two larger studies that reported facial ulcerations reported rates of 20 percent100 and 25.5 percent.70

#### Other Outcomes

Other outcomes were reported infrequently or not at all. No study reported effects on psychological response, functional status, or health-related quality of life for NPPV compared with either supportive care or invasive ventilation. Antonelli et al.58 was the only study to report rates of sinusitis; 0 of 32 for NPPV versus 2 of 32 with invasive ventilation.

For NPPV compared with supportive care, duration of mechanical ventilation was reported in two studies, showing a statistically significant shorter duration in one study65 and no effect in the other.73 Duration of invasive ventilation was reported in two studies comparing NPPV with invasive ventilation, one showing a statistically significant shorter duration,76 with no effect in the other.66 One study reported the rate of ventilator dependence at hospital discharge in the NPPV-treated patients (0 of 23) and those treated with invasive ventilation (1 of 26).66

## Key Question 2 BPAP Versus CPAP

KQ 2. Is NPPV with bilevel positive airway pressure (BPAP), compared with NPPV with continuous positive airway pressure (CPAP), associated with less morbidity, lower mortality, fewer adverse events, or lower medical utilization:

a. In adults with COPD and acute respiratory failure?
b. In adults with ACPE?
c. In adults with acute respiratory failure due to other causes including: pneumonia, asthma, obesity-hypoventilation syndrome, and interstitial lung disease?
d. In adults with acute respiratory failure in selective settings including: postoperative setting and post-transplant setting?

### Key Points

- Twelve RCTs of varied quality showed no statistically significant difference between providing NPPV with BPAP compared with CPAP for the outcomes of:
  ○ Mortality
  ○ Need for endotracheal intubation
  ○ Myocardial infarction
- Current evidence is insufficient to determine if BPAP or CPAP have differential treatment effects for hospital or ICU length of stay, hospital-acquired pneumonia, psychological distress, functional status or health-related quality of life, and mortality rates beyond hospitalization.
- All studies but one included only participants with acute cardiogenic pulmonary edema (ACPE), although indirect comparisons included other diagnoses and supported these findings. This limits the applicability of these findings in patients with other causes of acute respiratory failure, such as COPD, as well as those in postoperative and post-transplant settings.

### Description of Included Studies

A total of 12 studies, all RCTs, were included in our analyses.67,71,86,99,106-113 Important study characteristics are summarized in Table 9. Ten studies enrolled patients from emergency departments,67,71,99,106-109,111-113 one from an unclear setting,86 and one from a high-dependency unit.110 Seven studies were performed in Europe,67,71,106,107,109,110,112 two in Brazil,86,99 one in Tunisia,113 one in Canada,111 and one in Australia.108 Of these, four were of good quality,67,71,109,113 six were of fair quality,99,106-108,110,112 and two were of poor quality.86,111 The funding source was reported in five studies.71,108,110,112,113 Studies enrolled patients between 1994 and 2008. The number of patients included in studies ranged from 26^86^ to 1156,^71^ with a total of 1463 patients. The mean age of study participants ranged from 64–78 years. The proportion of female patients included ranged from 48 to 67 percent. No studies reported the racial demographics of the study participants.

Table 9 Study characteristics for direct comparisons of BPAP with CPAP

Characteristic | Values
Mean age of sample: Median (range) | 76.5 (63.5–77.6)
Sex: N (%)
Male | 561 (38.3%)
Female | 721 (49.3%)
Not reported | 181 (12.4%)
Race: N (%)
Not reported | 1463 (100%)
Setting: No. of studies (N)
ED | 10 (1447)
High-dependency unit | 1 (52)
Not reported | 1 (497)
Diagnoses: No. of studies (N)
ACPE | 12 (1966)
COPD | 1 (21)
Pneumonia | 1 (8)
Asthma | 1 (1)
Geographical region: No. of studies (N)
U.S.A./Canada | 1 (27)
Europe | 7 (1553)
Brazil | 2 (106)
Africa | 1 (200)
Australia/New Zealand | 1 (101)
Funding source: No. of studies (N)
Government | 3 (1378)
Industry | 0
Other | 0
None or not reported | 9 (718)
Study quality: No. of studies (N)
Good | 4 (1409)
Fair | 6 (424)
Poor | 2 (53)

Abbreviations: ACPE = acute cardiogenic pulmonary edema; BPAP = bilevel positive airway pressure; COPD = chronic obstructive pulmonary disease; CPAP = continuous positive airway pressure; ED = emergency department; N = number of participants

Although we aimed to address a variety of populations, all but one study included only patients with ACPE. Of the 101 participants enrolled in the single exceptional study,108 only 30 (30%) did not have pulmonary edema as their admission diagnosis; these included patients with COPD (21%), pneumonia (8%), and asthma (1%). Therefore, no studies included in these analyses addressed obesity hypoventilation syndrome, interstitial lung disease, or the postoperative or post-transplant setting. Six studies reported illness severity based on the APACHE II (median 18.1, range 16.0 to 18.3) or SAPS (median 43.8, range 41.6 to 46.0).

Four studies included three treatment arms (BPAP, CPAP, and supportive care with supplemental oxygen);67,71,86,99 the remainder compared BPAP with CPAP alone. NPPV was delivered by nasal mask in one study,111 and the remainder of studies described the use of a full face mask. In general, information on NPPV settings and protocols was provided. However, only one study provided information on what general type of provider adjusted NPPV.67

### Detailed Synthesis

#### Overview

Our analyses addressed the comparative effect of BPAP versus CPAP using the primary outcomes of mortality, endotracheal intubation rate, and incidence of myocardial infarction. Summary results are provided in Table 10. Overall, no significant variability in treatment effects across studies was detected. Further, funnel plots did not suggest publication bias (Appendix D).

Table 10 Summary of meta-analysis results for BPAP versus CPAP

Outcome | No. of Studies (N) | Summary OR (95% CI) | Tests for Heterogeneity
Mortality | 10 (1338) | 0.89 (0.58 to 1.35) | p = 0.41, I^2^ = 3%
Intubation | 12 (1463) | 0.84 (0.51 to 1.38) | p = 0.65, I^2^ = 0%
Myocardial infarction | 7 (1056) | 0.69 (0.34 to 1.40) | p = 0.09, I^2^ = 46%

Abbreviations: BPAP = bilevel positive airway pressure; CI = confidence interval; CPAP = continuous positive airway pressure; N = number of participants; OR = odds ratio

#### Mortality

In-hospital mortality ranged from 0 to 25 percent for BPAP, 0 to 21 percent for CPAP, and 0 to 30 percent for oxygen alone. Overall, there was no difference in in-hospital mortality between BPAP and CPAP groups in a random-effects model meta-analysis (OR 0.89; 95% CI, 0.58 to 1.35) drawn from a total of 10 studies (Figure 10). Mortality was generally assessed across the duration of hospitalization (9 studies), although one study reported 7-day mortality.71

Figure 10 Random-effects analysis of data on mortality—BPAP versus CPAP

Abbreviations: ACPE = acute cardiogenic pulmonary edema; BPAP = bilevel positive airway pressure; CI = confidence interval; CPAP = continuous positive airway pressure

This figure displays a forest plot of the 10 studies reporting data on mortality rates in patients receiving BPAP vs. CPAP. The summary OR was 0.89 (95% CI, 0.58 to 1.35). Effects were consistent across studies (Q = 9.28, df = 9, p = 0.41; I-squared = 3%). These results show no statistically significant difference between BPAP and CPAP for this outcome.

There are caveats and limitations to consider. One study alone accounted for 58 percent of all patients included in these analyses.71 This study included three treatment arms (BPAP, CPAP, and supplemental oxygen only). Study investigators found that there was no difference in 7-day mortality between oxygen and NPPV (9.8% vs. 9.5%, p = 0.81). Further, in this study there was no significant difference between BPAP and CPAP groups for the combined end point of intubation or death within 7 days (11.1% vs. 11.7%, p = 0.81). Nevertheless, even after removing this study, analyses did not show a clinically or statistically important intervention effect (OR 0.88; 95% CI 0.39 to 1.48). Second, fewer than 2 percent of patients enrolled in these studies carried a primary diagnosis other than ACPE. Based on direct comparisons, no conclusions can be made about the effect of BPAP versus CPAP for those with COPD, pneumonia, asthma, and interstitial lung disease, or for those in postoperative or post-transplant settings. Third, in general, few studies described NPPV protocols in sufficient detail that the interventions could be reproduced. Therefore, both replication of the research and translation of this research into practice are difficult.

We supplemented these analyses with a mixed-treatment effects analysis that included indirect comparisons (e.g., CPAP vs. supportive care). This analysis, which included data from 39 additional studies, found a similar relative mortality for CPAP compared with BPAP (OR 0.96; 95% CI, 0.71 to 1.31) to the analysis of studies including only direct comparisons (0.88; 95% CI, 0.39 to 1.48). Note that the mixed-treatment effects analysis suggests even more similarity in mortality associated with CPAP and BPAP based on an OR nearer to 1 and narrower confidence limits than the analysis of direct comparisons.

#### Intubation

Endotracheal intubation rates ranged from 0 to 29 percent for BPAP, 0 to 33 percent for CPAP, and 2.8 to 42 percent for oxygen alone. Based on analysis of 12 studies, there was no difference in the incidence of endotracheal intubation between BPAP and CPAP groups in a random-effects model meta-analysis (OR 0.84; 95% CI, 0.51 to 1.38; Figure 11). No significant variability in treatment effects across studies was detected (Q = 8.73, df = 11, p = 0.65, I^2^ = 0%). There was also no evidence of publication bias based on a funnel plot (Appendix D). An influence analysis, performed by removing one study at a time and recomputing the summary OR, suggested that the study by Cross and colleagues108 had undue influence of the overall summary estimate. Removing this study lowered the point estimate for treatment effect, although this was not statistically significant (OR 0.74; 95% CI, 0.44 to 1.26).

Figure 11 Random-effects analysis of data on intubation rates—BPAP versus CPAP

Abbreviations: ACPE = acute cardiogenic pulmonary edema; BPAP = bilevel positive airway pressure; CI = confidence interval; COPD = chronic obstructive pulmonary disease; CPAP = continuous positive airway pressure

This figure displays a forest plot of the 12 studies reporting data on intubation rates in patients receiving BPAP vs. CPAP. The summary OR was 0.84 (95% CI, 0.51 to 1.38). Effects were consistent across studies (Q = 8.73, df = 11, p = 0.65; I-squared = 0%). These results show no statistically significant difference between BPAP and CPAP for this outcome.

Limitations of these studies have been described above under “Mortality.”

#### Myocardial Infarction

Seven studies included myocardial infarction as a treatment outcome. All studies were conducted in patients with ACPE. Myocardial infarction rates ranged from 0 to 71 percent for BPAP, 7 to 31 percent for CPAP, and 0 to 30 percent for oxygen alone.

A random-effects model meta-analysis demonstrated no significant difference in the rate of myocardial infarction between BPAP and CPAP groups (OR 0.69; 95% CI, 0.34 to 1.40) (Figure 12). There was moderate heterogeneity in treatment effects across studies (Q = 11.1, df = 6, p = 0.09, I^2^ = 46%).

Figure 12 Random-effects analysis of data on myocardial infarction rates—BPAP versus CPAP

Abbreviations: ACPE = acute cardiogenic pulmonary edema; BPAP = bilevel positive airway pressure; CI = confidence interval; CPAP = continuous positive airway pressure; MI = myocardial infarction

This figure displays a forest plot of the seven studies reporting data on myocardial infarction rates in patients receiving BPAP vs. CPAP. The summary OR was 0.69 (95% CI, 0.34 to 1.40). There was moderate heterogeneity in treatment effects across studies (Q = 11.1, df = 6, p = 0.09; I-squared = 46%). These results show no statistically significant difference between BPAP and CPAP for this outcome.

#### Length of Stay in Hospital and ICU

Six studies reported hospital length of stay as an outcome.99,108-112 Mean length of stay varied substantially across studies, from 4 to 13.6 days in CPAP-treated patients and 5 to 11.3 days for BPAP-treated patients. Of the six studies, only three108,109,112 had a sample size of at least 60 participants (total n = 278), a large enough sample size to show a difference of 1 or more days in length of stay. None showed a statistically significant difference in length of stay by treatment group.

Two studies reported ICU length of stay as an outcome.108,111 Median length of ICU stay was zero days in both arms of one study,108 while mean ICU length of stay was 2.3 and 2.7 days in the CPAP and BPAP arms, respectively, in the other.111 Positive skew in length-of-stay data in both studies suggests that the studies may be more similar than they seem to be. As with the hospital length-of-stay outcome, ICU length of stay was not significantly different between NPPV types in either of the studies. No meta-analysis was undertaken for this outcome.

In summary, current evidence suggests that neither hospital nor ICU length of stay is any different for CPAP versus BPAP.

#### Intolerance and Facial Ulcerations

Four studies reported the rate of intolerance to NPPV as a treatment outcome.67,71,109,111 All used full face masks except for one,111 which used a nasal mask. No intolerance was observed in either CPAP or BPAP in one study109 while the others reported rates of intolerance ranging from 5.2 to 15 percent. None of the between-treatment differences in the rates of intolerance between CPAP and BPAP was statistically significant. Only one study was large enough to have the statistical power to detect a difference in intolerance rates of more than 5 percent,71 and in this study the rates were 5.2 percent for CPAP-treated patients compared with 8.4 percent for BPAP-treated patients, a difference of 3.2 percent which did not reach statistical significance (p = 0.09).

A single study reported the incidence of facial ulcerations in both CPAP and BPAP arms.111 In this study, which used a nasal mask, no facial ulcerations were observed under either treatment; however, because of the relatively small size of this study (n = 26 participants in both treatment arms), the confidence limits for the difference in rates is wide and cannot exclude a clinically important difference in the rate of facial ulcerations between NPPV modalities.

#### Other Outcomes

Other outcomes were reported infrequently or not at all. No study reported effects on psychological response, functional status, health-related quality of life, or sinusitis.

The study by Cross et al.108, a fair-quality study in 101 subjects, was the only study to report the duration of mechanical ventilation. The median duration of mechanical ventilation did not differ significantly between treatment arms (CPAP, median 123 minutes [range 10–338] versus BPAP, median 132 [range 20–550], p = 0.21).

## Key Question 3 Early Extubation to NPPV

KQ3. Is early extubation to NPPV, compared with usual care, associated with less morbidity, lower mortality, fewer adverse events, or lower medical utilization:

- In adults with COPD and acute respiratory failure?
- In adults with ACPE?
- In adults with acute respiratory failure due to other causes including: pneumonia, asthma, obesity-hypoventilation syndrome, and interstitial lung disease?
- In adults with acute respiratory failure in selective settings including: postoperative setting and post-transplant setting?

### Key Points

- In eligible studies, BPAP was the only NPPV modality evaluated; no studies used CPAP.
- In patients with COPD who are intubated for acute respiratory failure, current evidence supports a reduction in mortality and hospital-acquired pneumonia when NPPV is used to facilitate extubation. These benefits were not observed in studies enrolling patients with mixed etiologies of acute respiratory failure.
- In patients intubated for acute respiratory failure and deemed at high risk for extubation failure, current evidence supports a reduction in reintubation rates and hospital-acquired pneumonia when NPPV is used to prevent extubation failure. A mortality benefit in this group was suggested but was not statistically significant.
- In patients who develop recurrent acute respiratory failure, current evidence does not support a reduction in mortality, reintubation rates, or hospital-acquired pneumonia rates for NPPV use compared with supportive care.
- Few studies had adequate sample sizes to address effects on length of stay. Available evidence does not support a reduction in hospital length of stay with BPAP versus usual care, but suggests a possible decrease in ICU length of stay with early extubation to BPAP. BPAP-assisted weaning was associated with shorter duration of invasive ventilation.
- No studies reported data on myocardial infarction, psychological response, functional status, or health-related quality of life.

### Description of Included Studies

Twelve studies, involving 1519 patients met our inclusion criteria.114-125 One study was conducted in Canada,121 and one multicenter study included sites in the United States;115 all others were carried out in Europe or Asia. Of the 12 studies, 6 (50%) were of good methodological quality,115,117,121-124 5 (42%) were of fair quality,114,116,118,119,125 and 1 (8%) was of poor quality.120 Eleven studies reported effects on reintubation, and 11 reported mortality; no study reported myocardial infarction rates.

General study characteristics are summarized by treatment comparison in Table 11. All studies were conducted in ICU settings and used BPAP as the NPPV mode. In all but one study, the type of interface used was a full face mask, with one study including full face as well as nasal mask. BPAP, when described, was applied with an inspiratory pressure ranging from 10–20 cm H2O, but was variably adjusted to tidal volume or respiratory rate. Experience in using NPPV was not often described. One study118 reported a 15-year experience, and one121 described a 1-year experience with the specific intervention device, but none described the specific training or experience of the intervention staff. Composition of the intervention team was described in seven studies and consisted of combinations of critical care trained physicians, respiratory therapists, and nurses.

Table 11 Study characteristics by treatment comparison

Characteristic | Weaning: NPPV Vs. “Usual” Strategy | Preventing Respiratory Failure Postextubation: NPPV Vs. Supportive Care | Treating Respiratory Failure Postextubation: NPPV Vs. Supportive Care
Mean age of sample: Median age (range) | 68.6 (64.2 to 70.7) | 68.5 (54.6 to 72.7) | 64.0 (59.5 to 68.5)
Sex: n (%)
Male | 184 (52%) | 562 (65%) | 127 (42%)
Female | 87 (25%) | 302 (35%) | 94 (31%)
Not reported | 83 (23%) | 0 | 81 (27%)
Race: n (%)
Not reported | 354 (100%) | 864 (100%) | 302 (100%)
Setting: No. of studies (N)
ICU | 5 (354) | 5 (864) | 2 (302)
High-dependency unit | 0 | 0 | 0
NPPV modality: No. of studies (N)
BPAP | 5 (354) | 5 (864) | 2 (302)
CPAP | 0 | 0 | 0
Diagnoses: No. of studies (N)
Mixed^a^ | 3 (214) | 5 (864) | 2 (302)
COPD | 2 (140) | 0 | 0
ACPE | 0 | 0 | 0
Geographical region: No. of studies (N)
U.S.A./Canada | 0 | 0 | 1 (81)
Europe | 4 (264) | 3 (365) | 0
Asia | 1 (90) | 2 (499) | 0
Multiple continents | 0 | 0 | 1 (221)
Funding source:^b^ No. of studies (N)
Government | 1 (138) | 2 (512) | 2 (302)
Industry | 0 (0) | 0 | 1 (81)
Professional society/Foundation | 0 (0) | 2 (268) | 1 (81)
Not reported/Unclear | 4 (216) | 2 (190) | 0
Study quality: No. of studies (N)
Good | 2 (188) | 2 (203) | 2 (302)
Fair | 3 (166) | 2 (568) | 0
Poor | 0 | 1 (93) | 0

a ”Mixed” diagnosis refers to studies where fewer than 70% of patients had a single etiology for acute respiratory failure.

b Some studies had multiple funding sources; therefore totals may not sum to the total number of studies.

Abbreviations: ACPE = acute cardiogenic pulmonary edema; BPAP = bilevel positive airway pressure; COPD = chronic obstructive pulmonary disease; CPAP = continuous positive airways pressure; ICU = intensive care unit; N = number of participants; NPPV = noninvasive positive-pressure ventilation

Study participants were predominately older adults, with more men than women. Ethnicity was not reported in any of the studies. When examining etiologies for respiratory failure, there were several different populations included in these weaning studies. Ten studies included a mixed population of patients with a variety of diagnoses causing respiratory failure. Two studies included only patients with a diagnosis of COPD. Severity of illness was described by the APACHE II score in 9 studies (median 18.2, range 9.0 to 36.5) and the SAPS in 3 studies (median 38.4, range 32.5 to 42.0).

The included studies described three general strategies for using NPPV in the management of ventilator weaning. Five studies investigated the use of NPPV in facilitating early extubation (i.e., comparing “usual” weaning strategy with extubation prior to meeting extubation criteria but with the application of NPPV as a bridge to liberation from invasive mechanical ventilation).114,116,119,122,124,125 A second category of studies (five studies) described the use of NPPV versus supportive care in preventing extubation failure, primarily in those deemed at higher than average risk for requiring reintubation.117,118,120,123 Finally, two studies examined the use of NPPV versus supportive care in the treatment of recurrent, postextubation acute respiratory failure.115,121 We analyzed each of these groups separately.

### Detailed Analysis

#### Weaning from Ventilatory Support by Early Extubation to NPPV

We identified five studies that evaluated the relative effects of NPPV versus “usual” weaning strategies on facilitating extubation for patients with acute respiratory failure.114,116,119,122,124 All studies used BPAP. Table 12 summarizes the pooled treatment effects. Mortality and hospital-acquired pneumonia were significantly reduced with early extubation to NPPV in the subgroup of patients with COPD. Reintubation was not significantly decreased with NPPV, but the point estimate favored early weaning to NPPV in the single study of patients with COPD. The small numbers of studies and patients, relatively few events, and increased risk of bias from the three fair-quality studies limit all summary estimates. Because formal statistical techniques for publication bias are not effective with small numbers of studies, we did not conduct analyses for publication bias.

Table 12 Summary of effects for key outcomes—early extubation to NPPV

Outcome | No. of Studies (N) | Summary OR (95% CI) | Tests for Heterogeneity
Mortality
COPD | 2 (140) | 0.17 (0.05 to 0.65) | p = 0.62, I^2^ = 0%
Mixed^a^ sample | 3 (214) | 0.46 (0.06 to 3.59) | p = 0.02, I^2^ = 76%
Reintubation | 4 (303) | 0.83 (0.48 to 1.44) | p = 0.44, I^2^ = 0%
Hospital-acquired pneumonia
COPD | 2 (140) | 0.14 (0.04 to 0.48) | p = 0.43, I^2^ = 0%
Mixed^a^ sample | 3 (214) | 0.53 (0.19 to 1.46) | p = 0.22, I^2^ = 33%
Myocardial infarction | 0 (0) | NR | NR

a ”Mixed” sample refers to studies where fewer than 70% of patients had a single etiology for acute respiratory failure.

Abbreviations: CI = confidence interval; COPD = chronic obstructive pulmonary disease; NPPV = noninvasive positive-pressure ventilation; NR = not reported; OR = odds ratio

##### Mortality

Mortality ranged from 0 to 23 percent for early extubation to NPPV and 13 to 41 percent for conventional weaning in five studies.114,116,119,122,124 Because treatment effects were highly variable across studies and across diagnostic groups, we give summary estimates by diagnoses only. For the two studies in patients with CODP, NPPV decreased mortality (summary OR 0.17; 95% CI, 0.05 to 0.65; Figure 13). In the three studies conducted in patients with mixed etiologies of acute respiratory failure, NPPV was not associated with a decrease in mortality (summary OR 0.46; 95% CI, 0.06 to 3.59; Figure 13). For this latter group, the number of patients randomized and events (38 deaths) were small, and the results were highly variable across studies (Q = 8.41, df = 2, p < 0.001, I^2^ = 76%). There were too few studies to explore other potential reasons for heterogeneity quantitatively. However, qualitative analyses show that Girault 2011,^124^ the only study that suggested the potential for increased risk of early extubation to NPPV, enrolled the oldest cohort of patients.

Figure 13 Random-effects analysis of data on mortality—early extubation to NPPV versus conventional weaning

Note: “Mixed” diagnosis refers to studies where fewer than 70% of patients had a single etiology for acute respiratory failure.

Abbreviations: CI = confidence interval; COPD = chronic obstructive pulmonary disease; NPPV = noninvasive positive-pressure ventilation

This figure displays a forest plot of the five studies reporting data on mortality rates in patients receiving early extubation to NPPV vs. conventional weaning. Because treatment effects were highly variable across studies and across diagnostic groups, summary estimates are shown by diagnoses only (no overall summary estimate). For the two studies in patients with CODP, NPPV decreased mortality (summary OR 0.17; 95% CI, 0.05 to 0.65). In the three studies conducted in patients with mixed etiologies of acute respiratory failure, NPPV was not associated with a decrease in mortality (summary OR 0.46; 95%, 0.06 to 3.59). For this latter group, the number of patients randomized and events (38 deaths) were small and the results were highly variable across studies (Q = 8.41, df = 2, p < 0.001; I-squared = 76%).

##### Reintubation

Four studies114,116,119,124 reported reintubation rates that ranged from 9–32 percent for NPPV and 19–29 percent for usual care. Overall, there was no difference in reintubation rates between early extubation to NPPV and usual weaning practices (OR 0.83; 95% CI, 0.48 to 1.44; Figure 14). Tests of heterogeneity suggested suggest no significant variability in treatment effects across studies (Q = 2.72, df = 3, p = 0.44, I^2^ = 0%). When analyzed by diagnostic subgroups (Figure 14), there is the suggestion that NPPV may be more effective in patients with COPD than samples with mixed etiologies of acute respiratory failure, but these comparisons are based on small numbers of studies and indirect comparisons, and were not statistically significant.

Figure 14 Random-effects analysis of data on reintubation rates—early extubation to NPPV versus conventional weaning

Note: “Mixed” diagnosis refers to studies where fewer than 70% of patients had a single etiology for acute respiratory failure.

Abbreviations: CI = confidence interval; COPD = chronic obstructive pulmonary disease; NPPV = noninvasive positive-pressure ventilation

This figure displays a forest plot of the four studies reporting data on reintubation rates in patients receiving early extubation to NPPV vs. conventional weaning. The summary OR was 0.83 (95% CI, 0.48 to 1.44). Treatment effects were consistent across studies (Q = 2.72 df = 3, p = 0.44; I-squared = 0%). These results show no statistically significant difference between early extubation to NPPV and conventional weaning for this outcome.

##### Hospital-Acquired Pneumonia

Hospital-acquired pneumonia ranged from 0 to 24 percent for NPPV and 6 to 59 percent for usual care. Because treatment effects showed important variability across studies and across diagnostic groups, we give summary estimates by diagnoses. For the two studies in patients with COPD, NPPV decreased rates of hospital-acquired pneumonia (summary OR 0.14; 95% CI, 0.04 to 0.48; Figure 15). In the three studies conducted in patients with mixed etiologies of acute respiratory failure, NPPV was not associated with a decrease in hospital-acquired pneumonia (summary OR 0.53; 95% CI, 0.19 to 1.46; Figure 15) but confidence intervals were broad and the number of patients studied were few.

Figure 15 Random-effects analysis of data on hospital-acquired pneumonia rates—early extubation to NPPV versus conventional weaning

Note: “Mixed” diagnosis refers to studies where fewer than 70% of patients had a single etiology for acute respiratory failure.

Abbreviations: CI = confidence interval; Conv Wean = conventional weaning; COPD = chronic obstructive pulmonary disease; NPPV = noninvasive positive-pressure ventilation

This figure displays a forest plot of the five studies reporting data on hospital-acquired pneumonia rates in patients receiving early extubation to NPPV vs.conventional weaning. Because treatment effects showed important variability across studies and across diagnostic groups, summary estimates are shown by diagnoses only (no overall summary estimate). For the two studies in patients with COPD, NPPV decreased rates of hospital-acquired pneumonia (summary OR 0.14; 95% CI, 0.04 to 0.48). In the three studies conducted in patients with mixed etiologies of acute respiratory failure, NPPV was not associated with a decrease in these rates (summary OR 0.53; 95% CI, 0.19 to 1.46) but confidence intervals were broad and the number of patients studied were few.

##### Length of Stay

Four studies reported effects on hospital length of stay.114,116,119,124 Mean length of stay varied substantially across studies, from 18 to 28 days in NPPV-treated patients and 20 to 41 days with conventional weaning. Of the four studies, two had large enough sample sizes to show a difference of 1 or more days in length of stay; neither study found a statistically significant difference.

ICU length of stay was reported in five studies. Mean ICU length of stay range from 8 to 15 days in NPPV-treated patients and 8 to 25 days with conventional weaning. Of the five studies, three had large enough sample sizes to show a difference of 1 or more days in length of stay; two found a statistically significant reduction in length of stay for early extubation to NPPV. In a good-quality study of 50 patients with mixed etiologies for acute respiratory failure, Nava et al.122 found a shorter mean (standard deviation [SD]) length of stay of 15.1 (5.4) days with NPPV versus 24.0 (13.7) days with conventional weaning (p = 0.005). A fair-quality study114 in 90 patients with acute respiratory failure due to COPD exacerbations also found shorter mean length of stay (12.0 [SD 8] vs. 16 [11]; p = 0.047). The largest study,124 conducted in patients with mixed etiologies for acute respiratory failure, found no difference in the median length of stay (7.5 vs. 7.5 days; p = 0.69).

Several issues limit these findings. Length-of-stay data typically have a skewed distribution, making statistical tests that assume normality inappropriate, but such tests were sometimes used in these studies. Second, the results may be biased if NPPV reduces mortality, thus increasing length of stay. None of the studies reported subgroup analyses that limited the results to surviving patients. In summary, current evidence suggests that ICU length of stay, but not hospital length of stay, may be decreased by early extubation to NPPV. However, these results should be interpreted with caution.

#### NPPV Versus Supportive Care to Prevent Respiratory Failure Postextubation

We identified five studies that evaluated the relative effects of NPPV versus supportive care in patients with acute respiratory failure or at high risk for acute respiratory failure postextubation.117,118,120,123,125 All studies used BPAP. Three of the five studies enrolled patients judged to be at high risk for postextubation respiratory failure. Study quality was judged to be good in two studies, fair in two studies, and poor in one study. Table 13 summarizes the pooled treatment effects. Mortality, reintubation rates, and hospital-acquired pneumonia rates were not decreased with NPPV following extubation. However, the point estimate favored NPPV in each case. The small numbers of studies and patients and relatively few events limit all summary estimates. Because formal statistical techniques for publication bias are not effective with small numbers of studies, we did not conduct analyses for publication bias.

Table 13 Summary of effects for key outcomes—NPPV versus supportive care to prevent respiratory failure postextubation

Outcome | Group | No. of Studies (N) | Summary OR (95% CI) | Tests for Heterogeneity
Mortality^a^ | All | 4 (771) | 0.65 (0.38 to 1.10) | p = 0.75, I^2^ = 0%
Mortality^a^ | High risk | 3 (365) | 0.60 (0.34 to 1.04) | p = 0.87, I^2^ = 0%
Mortality^a^ | Average risk | 1 (406) | 1.52 (0.25 to 9.21) | p = 0.24, I^2^ = NA
Reintubation^b^ | All | 5 (864) | 0.76 (0.38 to 1.53) | p = 0.03, I^2^ = 63%
Reintubation^b^ | High risk | 3 (365) | 0.43 (0.24 to 0.77) | p = 0.73, I^2^ = 0%
Reintubation^b^ | Average risk | 2 (499) | 1.56 (0.89 to 2.76) | p = 0.48, I^2^ = 0%
Hospital-acquired pneumonia | All | 2 (268) | 0.52 (0.28 to 0.97) | p = 0.32, I^2^ = 0%
Myocardial infarction | All | 0 (0) | NR | NR

a p = 0.33 for differences in treatment effect on mortality by high-risk versus average-risk groups.

b p = 0.002 for differences in treatment effect on reintubation by high-risk versus average-risk groups.

Abbreviations: CI = confidence interval; N = number of participants; NA = not applicable; NPPV = noninvasive positive-pressure ventilation; NR = not reported; OR = odds ratio

##### Mortality

Mortality ranged from 1 to 23 percent for usual care and 1 to 16 percent for NPPV in four studies.117,118,123,125 Overall, NPPV postextubation did not decrease mortality (OR 0.65; 95% CI, 0.38 to 1.10; Figure 16). Tests for heterogeneity did not suggest important variability in treatment effects across studies (Q = 1.23, df = 3, p = 0.75, I^2^ = 0%). Exploratory analysis that grouped studies into those evaluating patients at high versus average risk for recurrent acute respiratory failure suggested a greater effect in those at high risk, but the difference in effects was not statistically significant (p = 0.33).

Figure 16 Random-effects analysis of data on mortality—NPPV versus supportive care to prevent respiratory failure postextubation

Abbreviations: CI = confidence interval; NPPV = noninvasive positive-pressure ventilation

This figure displays a forest plot of the four studies reporting data on mortality rates in patients receiving NPPV vs. supportive care to prevent respiratory failure postextubation. The summary OR was 0.65 (95% CI, 0.38 to 1.10). Tests for heterogeneity did not suggest important variability in treatment effects across studies (Q = 1.23, df = 3, p = 0.75; I-squared = 0%). These results show no statistically significant difference between NPPV and supportive care postextubation for this outcome.

##### Reintubation

Five studies reported reintubation rates ranging from 8 to 25 percent for NPPV to 8 to 28 percent for usual care. Overall, NPPV postextubation did not decrease reintubation rates compared with usual supportive care (OR 0.84; 95% CI, 0.56 to 1.27; Figure 17), but tests for heterogeneity suggested significant variability in treatment effects across studies (Q = 10.73, df = 4, p = 0.03, I^2^ = 63%). Subgroup analyses by those at high risk for recurrent acute respiratory failure versus those at average risk showed a protective effect only for those at high risk (OR 0.43; 95% CI, 0.24 to 0.77).

Figure 17 Random-effects analysis of data on reintubation rates—NPPV versus supportive care to prevent respiratory failure postextubation

Abbreviations: CI = confidence interval; NPPV = noninvasive positive-pressure ventilation

This figure displays a forest plot of the five studies reporting data on reintubation rates in patients receiving NPPV vs. supportive care to prevent respiratory failure postextubation. Because treatment effects showed mocerate variability across studies and across diagnostic groups, summary estimates are shown by diagnoses only (no overall summary estimate). Subgroup analyses by those at high risk for recurrent acute respiratory failure versus those at average risk for recurrent acute respiratory failure showed a protective effect for those at high risk (OR 0.43; 95% CI, 0.24 to 0.77) but not for those at average risk (OR 1.56; 95% CI, 0.89 to 2.76).

##### Hospital-Acquired Pneumonia

Two studies, both in populations at high risk for reintubation, reported rates of hospital-acquired pneumonia, ranging from 6 to 23 percent for NPPV and 17 to 33 percent for usual care. Overall, NPPV postextubation decreased hospital-acquired pneumonia rates compared with usual supportive care (summary OR 0.52; 95% CI, 0.28 to 0.97; Figure 18). Tests for heterogeneity suggested no significant variability in treatment effects (Q = 0.99, df = 1, p = 0.32, I^2^ = 0%).

Figure 18 Random-effects analysis of data on hospital-acquired pneumonia rates—NPPV versus supportive care to prevent respiratory failure postextubation

Abbreviations: CI = confidence interval; NPPV = noninvasive positive-pressure ventilation

This figure displays a forest plot of the two studies reporting data on hospital-acquired pneumonia rates in patients receiving NPPV vs. supportive care to prevent respiratory failure postextubation. The summary OR was 0.52 (95% CI, 0.28 to 0.97). Tests for heterogeneity suggested no significant variability in treatment effects (Q = 0.99, df = 1, p = 0.32; I-squared = 0%). These results show statistically significantly lower rates of hospital-acquired pneumonia with NPPV postextubation compared to usual supportive care.

##### Length of Stay

Three studies reported effects on hospital length of stay.117,118,123 Mean length of stay varied from 23 to 30 days in NPPV-treated patients and 24 to 29 days with supportive care. All three had large enough sample sizes to show a difference of 1 or more days in length of stay; none found a statistically significant difference.

ICU length of stay was reported in the same three studies; mean ICU length of stay ranged from 9 to 11 days in NPPV-treated patients and 10 to 13 days with supportive care. Of the three studies, all had large enough sample sizes to show a difference of 1 or more days in length of stay; none found a statistically significant reduction in length of stay for early extubation to NPPV.

Several issues limit these findings. Length-of-stay data typically have a skewed distribution, making statistical tests that assume normality inappropriate, but such tests were sometimes used in these studies. Second, the results may be biased if NPPV reduces mortality, thus increasing length of stay. None of the studies reported subgroup analyses that limited the results to surviving patients. In summary, current evidence suggests that neither hospital nor ICU length of stay is decreased by NPPV postextubation. However, for the reasons described, these results should be interpreted with caution.

#### NPPV Versus Supportive Care to Treat Respiratory Failure Postextubation

We identified two studies that evaluated the relative treatment effects of NPPV versus supportive care in patients who develop recurrent acute respiratory failure postextubation.115,121 Both studies used BPAP and were judged to be good quality. Table 14 summarizes the pooled treatment effects. Mortality, reintubation rates, and hospital-acquired pneumonia rates did not differ for NPPV compared with supportive care. In each case, the point estimate suggested the possibility of worse outcomes for NPPV. The small numbers of studies and patients and relatively few events limit all summary estimates. Because formal statistical techniques for publication bias are not effective with small numbers of studies, we did not conduct analyses for publication bias.

Table 14 Summary of effects for key outcomes—NPPV versus supportive care to treat respiratory failure postextubation

Outcome | Group | No. of Studies (N) | Summary OR (95% CI) | Tests for Heterogeneity
Mortality | All | 2 (302) | 1.52 (0.78 to 2.97) | p = 0.24, I^2^ = 27%
Reintubation | All | 2 (302) | 1.05 (0.66 to 1.67) | p = 0.85, I^2^ = 0%
Hospital-acquired pneumonia | All | 1 (81) | 1.02 (0.42 to 2.48) | NA
Myocardial infarction | All | 0 (0) | NR | NR

Abbreviations: CI = confidence interval; N = number of participants; NA = not applicable; NPPV = noninvasive positive-pressure ventilation; NR = not reported; OR = odds ratio

##### Mortality

Mortality ranged from 14 to 31 percent for usual care and 25 to 31 percent for NPPV in two studies.115,121 Overall, NPPV postextubation did not decrease mortality (OR 1.52; 95% CI, 0.78 to 2.97; Figure 19). Tests for heterogeneity did not suggest important variability in treatment effects across studies (Q = 1.38, df = 1, p = 0.24, I^2^ = 27%).

Figure 19 Random-effects analysis of data on mortality—NPPV versus supportive care to treat respiratory failure postextubation

Abbreviations: CI = confidence interval; NPPV = noninvasive positive-pressure ventilation

This figure displays a forest plot of the two studies reporting data on mortality rates in patients receiving NPPV vs. supportive care to treat respiratory failure postextubation. The summary OR was 1.52 (95% CI, 0.78 to 2.97). Tests for heterogeneity did not suggest important variability in treatment effects across studies (Q = 1.38, df = 1, p = 0.24; I-squared = 27%). These results show no statistically significant difference between NPPV and supportive care postextubation for this outcome.

##### Reintubation

Two studies reported reintubation rates ranging from 48 to 72 percent for NPPV to 48 to 69 percent for usual care.115,121 Overall, NPPV postextubation did not decrease reintubation rates compared with usual supportive care (OR 1.05; 95% CI, 0.66 to 1.67; Figure 20). Tests for heterogeneity did not suggest important variability in treatment effects across studies (Q = 0.04, df = 1, p = 0.85, I^2^ = 0%).

Figure 20 Random-effects analysis of data on reintubation rates—NPPV versus supportive care to treat respiratory failure postextubation

Abbreviations: CI = confidence interval; NPPV = noninvasive positive-pressure ventilation

This figure displays a forest plot of the two studies reporting data on reintubation rates in patients receiving NPPV vs. supportive care to treat respiratory failure postextubation. The summary OR was 1.05 (95% CI, 0.66 to 1.67). Tests for heterogeneity did not suggest important variability in treatment effects across studies (Q = 0.04, df = 1, p = 0.85; I-squared = 0%). These results show no statistically significant difference between NPPV and supportive care postextubation for this outcome.

##### Hospital-Acquired Pneumonia

Only one study reported the rate of hospital-acquired pneumonia.121 In this study the rate of HAP was the same (41%) in both treatment groups.

##### Length of Stay

Only one study reported effects on hospital length of stay.121 Mean length of stay did not differ significantly; 32.2 days in NPPV-treated patients and 29.8 days with supportive care. Of the five studies, three had large enough sample sizes to show a difference of 1 or more days in length of stay; none found a statistically significant difference.

ICU length of stay was reported in two studies; median ICU length of stay ranged from 11.9 to 18 days in NPPV-treated patients and 10.8 to 18 days with supportive care. Both studies had large enough sample sizes to show a difference of 1 or more days in length of stay; neither found a statistically significant reduction in length of stay when NPPV was used to treat postextubation respiratory failure.

Several issues limit these findings. Length-of-stay results may be biased if NPPV reduces mortality, thus increasing length of stay. Neither of the studies reported subgroup analyses that limited the results to surviving patients. In summary, current evidence suggests that neither hospital nor ICU length of stay is decreased when NPPV is used to treat respiratory failure postextubation. However, for the reasons described, these results should be interpreted with caution.

#### Other Outcomes (Weaning and Postextubation Studies)

##### Intolerance and Facial Ulcerations

Three studies115,117,121 evaluating NPPV postextubation to prevent recurrent acute respiratory failure reported rates of discontinuation due to poor patient tolerability; median discontinuation was 9.3 percent (range 4.4 to 25.6%). Rates of facial abrasions or ulcerations were reported in four studies116,118,120,121 and varied widely, ranging from 2.1 to 26 percent. Variability appears related in part to different definitions for facial injury and in part to differing durations of followup.

##### Other Outcomes

Other outcomes were reported infrequently or not at all. No study reported effects on psychological response, functional status, or health-related quality of life. Giraualt et al,124 a good-quality study, reported equivalent rates of sinusitis in the NPPV weaning and conventional weaning arms (1 of 69 in each).

The duration of mechanical ventilation was reported in five studies that compared NPPV weaning with conventional weaning. The mean duration of mechanical ventilation ranged from 4.6 to 10.2 days for NPPV weaning and 7.7 to 20.1 days with conventional weaning. All studies showed a statistically significant decrease in invasive ventilation with NPPV weaning. Only one study reported the duration of mechanical ventilation when NPPV was used to treat respiratory distress after extubation.121 This good-quality study, conducted with 81 patients with ACPE, found a nonstatistically significant decrease in ventilator days with NPPV compared with supportive care (median 6.7 [range 0.5 to 28.6] versus 8.9 [range 2.0 to 146.7, p = 0.12]). One study reported the rate of ventilator dependence at hospital discharge for NPPV weaning (0 of 25) compared with conventional weaning (2 of 25, p-value not reported).123

## Key Question 4 Variation by Subgroups

KQ 4: For KQs 1–3, do the effectiveness and risks of NPPV vary by setting and associated resources, experience and training of clinicians, and use of protocols or by patient characteristics (e.g., morbid obesity, mental-status changes, overall disease burden)?

### Key Points

- The effects of NPPV on intubation rates are stronger when NPPV is initiated in the ICU than when it is initiated in the ED, but these findings are based on indirect comparisons.
- Few studies reported details about clinical setting and associated resources, experience and training of clinicians, or the use of clinical protocols. With the exception of diagnosis at study entry, no studies reported results by patient characteristics.
- The pooled OR associated with NPPV for both mortality and intubation shows a stronger effect for efficacy trials compared with effectiveness trials, but only two effectiveness trials were included in the analysis, and the 95% CIs overlapped.
- The treatment effects for NPPV on mortality and intubation rates are consistent across studies conducted in the United States or Canada versus European countries versus other countries.
- With the exception of the clinical setting in studies that compared NPPV with usual supportive care or invasive ventilator support (KQ 1), too few studies reported sufficient data to evaluate whether effectiveness or risks of NPPV vary by setting or patient characteristics.

### Description of Included Studies

Of the 69 eligible studies, 65 (94%) reported information about the clinical setting in which NPPV was initiated, 3 (4%) provided specific information about the experience or training of study clinicians, 2 (3%) reported patients' mean body mass index, 16 (23%) reported data on patients' neurological or mental status, 17 (25%) reported a measure of disease burden, and 46 (67%) reported mean baseline APACHE II, APACHE III, or SAPS scores for predicted ICU mortality.

We conducted subgroup analysis for the clinical setting, the geographical world region, and efficacy-effectiveness category. Of the 49 studies that pertain to KQ 1, NPPV was initiated in the ED setting in 10 studies (20%) and in the ICU setting in 23 studies (47%). In the remaining 16 studies (33%), clinical setting was either not reported, or NPPV was initiated in another setting such as a general medicine ward or ambulance. The majority of studies were conducted in Europe. Most studies were classified as mixed efficacy-effectiveness studies; only two were classified as effectiveness studies. Forty-six studies compared NPPV with supportive care or invasive ventilator support; of these 43 (93%) reported mortality rates and 39 (85%) reported intubation rates and were included in these subgroup analyses.

In addition to the subgroup analyses we conducted, we reviewed each study for subgroup analyses relevant to KQ 4. Nineteen of the 69 eligible studies (28%) reported subgroup analyses. None of these subgroups, however, corresponded to variables that we identified a priori, such as clinical setting, experience of clinicians, use of protocols, or such patient characteristics as obesity, mental status, or overall disease burden. Examples of the subgroups reported in the eligible studies include hypercapnic or acidotic patients, or patients with versus without cardiac disease. Among all the eligible studies (including those that did not report subgroup analyses), too few studies reported resources used, the experience and training of clinicians, the use of protocols, or patient characteristics to justify a qualitative or quantitative summary of the findings by these subgroups for KQs 1–3. Mortality and intubation rates were reported in a sufficient number of studies to justify subgroup analyses for these outcomes by clinical setting for KQ 1. Data were insufficient to justify subgroup analyses for KQ 2 or KQ 3 for these outcomes or for other outcomes considered for KQ 1. There were sufficient data, however, to explore whether estimates of effect of NPPV vary by whether studies were efficacy trials versus effectiveness trials for the outcomes of mortality and intubation, and whether estimates of effect of NPPV vary by the geographical region from which patients were recruited.

### Detailed Synthesis

#### Variations by Clinical Setting

We conducted subgroup analyses to explore whether the effectiveness and risks of NPPV varied by clinical setting. We constrained these analyses to studies that compared NPPV with usual supportive care or invasive ventilation (KQ 1), which together includes the largest set of conceptually similar studies included in our report. These analyses should be considered to be exploratory because they consist of indirect comparisons, and studies may have differed in important ways on characteristics other than the ones we examined. The summary OR for mortality associated with NPPV with usual supportive care as the referent was 0.72 (95% CI, 0.49 to 1.05) in studies in which NPPV was initiated in the ED and 0.48 (95% CI, 0.35 to 0.66) in studies in which NPPV was initiated in the ICU (Table 15). Among studies in which NPPV was initiated in other settings or for which the setting was not reported, the OR for mortality was 0.65 (95% CI, 0.43 to 0.98). The difference in pooled ORs across the three settings (ED, ICU, other) was not statistically significant (Q = 2.92, df = 2, p = 0.23). An analysis that examined risk of intubation showed differences in treatment effect that approached statistical significance: the ORs for intubation were 0.50 (95% CI, 0.26 to 0.95), 0.23 (0.15 to 0.34), and 0.36 (0.25 to 0.51) for NPPV initiated in the ED, ICU, or mixed/unreported, respectively (Q = 5.10, df = 2, p = 0.08). These differences could be related to the treatment setting or other factors (such as severity of illness) not considered in this analysis. Too few studies reported patient characteristics hypothesized to be associated with treatment effects (e.g., experience and training of clinicians or patient characteristics) to conduct subgroup analyses for these variables.

Table 15 Risk of mortality or intubation by clinical setting, NPPV versus usual supportive care or invasive ventilation^a^

Clinical Setting | Mortality^b^ (n = 43) Odds Ratio (95% CI) | Intubation^c^ (n = 39) Odds Ratio (95% CI)
Emergency department | 0.72 (0.49 to 1.05) | 0.50 (0.26 to 0.95)
ICU | 0.48 (0.35 to 0.66) | 0.23 (0.15 to 0.34)
Mixed, other, or not reported | 0.65 (0.43 to 0.98) | 0.36 (0.25 to 0.51)

a Studies that compared NPPV with usual supportive care or invasive ventilator support (KQ 1) are included, but studies that compared different NPPV approaches (KQ 2) or were weaning studies (KQ 3) are not included.

b Includes in-hospital mortality when reported and ICU mortality when in-hospital mortality not reported; p = 0.23 for differences in treatment effect by clinical setting.

c Does not include studies that compared NPPV with invasive ventilation; p = 0.08 for differences in treatment effect by clinical setting.

Abbreviations: CI = confidence interval; ICU = intensive care unit; KQ = Key Question; NPPV = noninvasive positive-pressure ventilation

#### Variations by Effectiveness Rating

We performed meta-analyses of the studies that pertain to KQ 1 to explore whether effectiveness of NPPV, as measured by mortality or intubation rates, varies by study type. We used the effectiveness rating scale proposed by Gartlehner et al.50 and assigned a scale score of 0–7 to each study, as described above in the Methods chapter. We defined studies with a score of 0–2 as efficacy trials and studies with a score of 6 to 7 as effectiveness trials. Studies with scores of 3–5 were defined as “mixed.”

The median effectiveness score for the 47 studies that pertain to Key Question 1 is 3.5 (range, 0.5–6). Of the 43 studies that compared NPPV with usual supportive care or invasive ventilation and reported mortality rates, 11 (26%) were efficacy trials, 2 (4%) were effectiveness trials, and 30 (70%) were mixed efficacy-effectiveness trials. The pooled ORs for mortality were 0.56 (95% CI, 0.31 to 1.02) and 0.99 (0.66 to 1.49) for efficacy and effectiveness trials, respectively; for mixed efficacy-effectiveness trials, the pooled OR was 0.52 (95% CI, 0.41, 0.66; Table 16). An analysis that examined risk of intubation yielded similar results: for intubation, the pooled ORs for efficacy (n = 10), effectiveness (n = 2), and mixed efficacy-effectiveness trials (n = 25) were, respectively, 0.29 (95% CI, 0.19 to 0.46), 0.58 (0.16 to 2.13), and 0.29 (0.21 to 0.41; Table 16). The difference in pooled ORs across the three categories of effectiveness was statistically significant for mortality (Q = 7.96, p = 0.02) but not for intubation (Q = 0.98, p = 0.61). For both mortality and intubation, there were only two effectiveness trials, thereby potentially rendering the pooled OR an unreliable estimate. The 95% CIs associated with the efficacy and effectiveness studies overlapped for both mortality and intubation.

Table 16 Risk of mortality or intubation by effectiveness rating, NPPV versus usual supportive care or invasive ventilation^a^

Effectiveness Rating | Mortality^b^ (n = 43) Odds Ratio (95% CI) | Intubation^c^ (n = 39) Odds Ratio (95% CI)
Efficacy trial | 0.56 (0.31 to 1.02) | 0.29 (0.19 to 0.46)
Mixed efficacy-effectiveness trial | 0.52 (0.41 to 0.66) | 0.29 (0.21 to 0.41)
Effectiveness trial | 0.99 (0.66 to 1.49) | 0.58 (0.16 to 2.13)

a Studies that compared NPPV with usual supportive care or invasive ventilator support (KQ 1) are included, but studies that compared different NPPV approaches (KQ 2) or were weaning studies (KQ 3) are not included.

b Includes in-hospital mortality when reported and ICU mortality when in-hospital mortality not reported; p = 0.02 for differences in treatment effect by effectiveness rating.

c Does not include studies that compared NPPV with invasive ventilation; p = 0.61 for differences in treatment effect by effectiveness rating.

Abbreviations: CI = confidence interval; NPPV = noninvasive positive-pressure ventilation

#### Variations by Geographical Region

There is evidence to suggest that several European countries have more extensive experience with NPPV than the United States, Canada, or other countries. We explored the hypothesis that studies conducted in Europe demonstrate greater effectiveness associated with NPPV compared with studies conducted in the U.S. or Canada. We conducted meta-analyses of the 43 studies that pertain to KQ 1 that reported mortality and the 39 studies that pertain to KQ 1 that reported intubation rates using three subgroups: (1) studies that included primarily patients recruited in Europe; (2) studies that included primarily patients recruited in the U.S. or Canada; and (3) studies that included primarily patients recruited in other countries. Results of these meta-analyses are summarized in Table 17. The pooled OR for mortality for the 25 studies conducted in Europe is 0.58 (95% CI, 0.46 to 0.73), compared with 0.58 (95% CI, 0.25 to 1.33) for the 5 studies conducted in the U.S. or Canada, and 0.64 (95% CI, 0.36 to 1.13) for the 13 studies conducted in other countries. The difference in pooled ORs for mortality across the three categories of countries was not statistically significant (Q = 0.11, df = 2, p = 0.95). For the 39 studies that pertain to KQ 1 and reported intubation rates, the pooled OR was 0.33 (95% CI, 0.22 to 0.48) for the 19 studies conducted in Europe, 0.36 (0.20 to 0.66) for the 6 studies conducted in the U.S. or Canada, and 0.25 (95% CI, 0.14 to 0.43) for the 14 studies conducted in other countries. The difference in pooled odds ratios for intubation across the three categories of countries was not statistically significant (Q = 0.73, p = 0.70).

Table 17 Risk of mortality or intubation by geographical location, NPPV versus usual supportive care or invasive ventilation^a^

Geographical Location | Mortality^b^ (n = 43) Odds Ratio (95% CI) | Intubation^c^ (n = 39) Odds Ratio (95% CI)
Europe | 0.58 (0.46 to 0.73) | 0.33 (0.22 to 0.48)
U.S. or Canada | 0.58 (0.25 to 1.13) | 0.36 (0.20 to 0.66)
Other countries | 0.64 (0.36 to 1.13) | 0.25 (0.14 to 0.43)

a Studies that compared NPPV with usual supportive care or invasive ventilator support (KQ 1) are included, but studies that compared different NPPV approaches (KQ 2) or were weaning studies (KQ 3) are not included.

b Includes in-hospital mortality when reported and ICU mortality when in-hospital mortality not reported; p = 0.95 for differences in treatment effect by geographical location'

c Does not include studies that compared NPPV with invasive ventilation; p = 0.70 for differences in treatment effect by geographical location.

Abbreviations: CI = confidence interval; NPPV = noninvasive positive-pressure ventilation

#### Summary

The results of our meta-analyses suggest that NPPV initiated in the ICU is effective in reducing mortality (OR 0.48; 95% CI, 0.35 to 0.66) and intubation rates (OR 0.23; 95% CI, 0.15 to 0.34). The 95% CIs for the pooled OR for mortality (0.72) included 1.0 among studies that initiated NPPV in the ED. These analyses should be considered exploratory because they consist of indirect comparisons, and studies may have differed in important ways on characteristics other than the ones we examined. There were too few studies that pertain to KQ 1 that reported patient characteristics, too few studies that pertain to either KQ 2 or KQ 3 that reported setting or patient characteristics, and too few studies that pertain to any of the KQs that reported adverse events to further explore whether effectiveness or risks of NPPV vary by setting or patient characteristics.

The pooled ORs associated with NPPV for both mortality and intubation were lower for efficacy trials compared with effectiveness trials, but only two effectiveness trials were included in the analysis, and the 95% CIs overlapped. Treatment effects for NPPV on mortality and intubation rates were similar between European countries, the U.S. or Canada, and other countries.