# Peer Reviewers

Neill Adhikari, M.D.C.M., M.Sc.

Lecturer

University of Toronto

Toronto, Ontario

Gregory Bierer, M.D.

Associate Clinical Professor

University of California, Los Angeles

Los Angeles, CA

Peter Dodek, M.D., M.H.Sc.

Professor

University of British Columbia

Vancouver, British Columbia

Dean Hess, Ph.D., R.R.T.

Associate Professor of Anesthesia

Harvard University

Cambridge, MA

Taz Sinuff, M.D., Ph.D.

Assistant Professor

University of Toronto

Toronto, Ontario