# Key Informants

James Donohue, M.D.

Professor of Medicine

University of North Carolina at Chapel Hill

Chapel Hill, NC

Donna Hamel, R.R.T., R.C.P., C.C.R.P.

Clinical Research Coordinator

Duke University

Durham, NC

Nicholas Hill, M.D.

Professor of Medicine

Tufts University

Boston, MA

Philip Marcus, M.D., M.P.H.

Associate Professor

New York College of Osteopathic Medicine

Old Westbury, NY

Marta Render, M.D.

Chief

Veterans Affairs Inpatient Evaluation Center

Cincinnati, OH

James Rollins, M.D., M.S.H.A. Ph.D.

Director, Division of Items and Devices

Centers for Medicare and Medicaid Services

Baltimore, MD

Jeffrey Sankoff, M.D.C.M.

Assistant Professor

University of Colorado Denver

Denver, CO

Eric Siegal, M.D., S.F.H.M.

Assistant Professor of Medicine

University of Wisconsin

Madison, WI

John Whitney, M.D.

Clinical Assistant Professor

Albany Medical College

Albany, NY