# Introduction

## Background

Acute respiratory failure is the most common reason for admission to an intensive care unit (ICU), accounting for approximately 800,000 ICU admissions annually in the United States.1,2 Epidemiological studies have estimated the annual incidence of acute respiratory failure to be between 77.6 and 430 patients per 100,000.^1,3-5^ The estimated health care costs related to critical care are approximately 0.7 percent of the annual gross domestic product, and the human and financial costs are only expected to increase with an aging population.6-9

Until the past couple of decades, invasive mechanical ventilation has been the standard of care treatment for acute respiratory failure. Noninvasive positive-pressure ventilation (NPPV), a newer modality of respiratory support, has been evaluated in a large number of trials, often with clinically important benefits, but use of NPPV remains highly variable across institutions and geographical regions.10-14 This comparative effectiveness review (CER) was commissioned by the Agency for Healthcare Research and Quality (AHRQ) to evaluate the evidence for NPPV versus other typical treatments for acute respiratory failure. We anticipate that clinicians involved in medical and surgical critical care medicine, emergency medicine, and anesthesiology, along with developers of clinical practice guidelines, will be the primary audience for this report.

### Acute Respiratory Failure

Respiratory failure is a syndrome characterized by the inability to maintain normal gas exchange due to dysfunction of the respiratory system. In its most basic sense, the respiratory system is comprised of a gas exchanging organ (lung) and a ventilatory pump (respiratory muscles and controllers, chest wall). Respiratory failure is further classified based on failure of one or both of these elements, as well as the timing of such failure.

Type I (hypoxemic) respiratory failure represents a failure of the gas exchange organ and is characterized by a low partial pressure of oxygen in arterial blood (PaO2) with a normal or low partial pressure of carbon dioxide in arterial blood (PaCO2). Type I is the most common form of respiratory failure and generally involves filling or collapse of lung tissue in disorders such as pulmonary edema and pneumonia. Inability of the lungs and breathing muscles to pump air leads to type II respiratory failure, which is characterized by a high PaCO2, as seen in conditions such as asthma and neuromuscular disease. Respiratory failure is further defined by the timing of the development of respiratory dysfunction. Acute respiratory failure develops over minutes to several days. Respiratory failure is deemed chronic when derangements occur over several days or longer. Acute-on-chronic respiratory failure occurs when a patient with chronic respiratory failure suffers an acute deterioration in gas exchange; this is most commonly seen in patients with severe chronic obstructive pulmonary disease (COPD). Table 1 presents a limited list of causes of respiratory failure, as well as some of the general underlying physiological mechanisms.

Table 1 Sample causes of respiratory failure and associated physiological mechanisms

Type of Respiratory Failure (With Examples) | Comments
Type I (hypoxemic) respiratory failure CHF (cardiogenic pulmonary edema) Noncardiogenic pulmonary edema (e.g., ARDS) Pneumonia Aspiration Atelectasis Pneumothorax Trauma/contusion Pulmonary embolism Interstitial lung disease (e.g. idiopathic pulmonary fibrosis) | “Lung failure” may be due to ventilation-perfusion mismatch, anatomic or physiologic shunt, diffusion impairment, etc.
Type II (hypercapnic) respiratory failure Asthma COPD Neuromuscular weakness (e.g., ALS) Sedative drug toxicity/anesthesia Sleep disordered breathing Obesity hypoventilation syndrome Multiple rib fractures (e.g., flail chest) Kyphoscoliosis Brainstem stroke or trauma | “Respiratory pump” failure may be due to airflow obstruction, respiratory muscle weakness, mechanical chest wall defect, lack of respiratory drive, etc.

Abbreviations: ALS = amyotrophic lateral sclerosis; ARDS = acute respiratory distress syndrome; CHF = congestive heart failure; COPD = chronic obstructive pulmonary disease

These definitions, however, are not rigid, as many disease states demonstrate mixed physiology, and the workings of the lung and the ventilatory pump do not ultimately exist in isolation. For example, in actual clinical practice, almost all patients with acute respiratory failure are hypoxemic and are distinguished by a normal or low blood level of carbon dioxide (type I) as opposed to an elevated blood level of carbon dioxide (type II). Furthermore, traditional definitions of acute respiratory failure rely on arbitrary blood gas values and may not account for preexisting cardiopulmonary disease (as might be evidenced by polycythemia or cor pulmonale for chronic hypoxemic failure or renal compensation for chronic hypercapnic failure). More recent descriptions of acute respiratory failure incorporate clinical findings such as tachypnea, cyanosis, and use of accessory muscles, but may not fully appreciate the spectrum of presentations. For the purposes of this report, we used a more inclusive definition of acute respiratory failure, namely: a significant change in a patient's baseline gas-exchange status (given the constellation of available clinical data) that occurs relatively suddenly (usually hours to days) and is potentially life-threatening, but which does not require emergent intubation.

### Treatment Strategies

#### Management of Respiratory Failure

The management of acute respiratory failure begins with efforts to identify the underlying etiology and an initial decision about the need for emergent invasive ventilation. Among the more common indications for emergent ventilation are cardiac arrest or shock, apnea, and need for airway protection (e.g., coma or seizures). For patients who do not require emergent ventilation, supportive care with supplemental oxygen is a mainstay of therapy. The use of medications (e.g., antibiotics, corticosteroids, beta-agonists, diuretics) is common but is dependent on identifying the underlying disorder. Unless a patient's condition is rapidly reversible, these conservative measures often fail to improve gas exchange or decrease the work of breathing sufficiently to prevent further deterioration and death. In such cases, acute respiratory failure is severe enough to require respiratory support. Invasive ventilation (also known as conventional mechanical ventilation) is a form of life support in which positive pressure delivers a mixture of air and oxygen through an endotracheal or tracheostomy tube to central airways. Invasive ventilation offers multiple modes and settings and can provide variable levels of respiratory support. Despite the life-saving potential of invasive ventilation in patients with respiratory failure, up to 40 percent of patients die in the hospital; some of these deaths are directly attributable to the complications of invasive ventilation and artificial airways.15-18 Additionally, many survivors of acute respiratory failure require prolonged invasive ventilation and suffer persistent decrements in quality of life and functional independence.19-21

#### NPPV as an Alternative Management Strategy

An increasingly recognized option in the management of patients who do not require emergent invasive ventilation for acute respiratory failure is NPPV. NPPV refers to a form of mechanical support in which positive pressure delivers a mixture of air and oxygen throughout the respiratory tree via a noninvasive interface. NPPV collectively includes several modalities of noninvasive ventilation, which can be delivered via a standard ICU ventilator or a portable device. Continuous positive airway pressure (CPAP) is applied throughout the respiratory cycle of a spontaneously breathing patient and is physiologically identical to constant positive end-expiratory pressure. Bilevel positive airway pressure (BPAP) delivers two pressure levels according to the respiratory cycle and improves ventilation, oxygenation, and alveolar recruitment. BPAP provides both an inspiratory positive airway pressure and a continuous expiratory positive airway pressure, and the difference between these reflects the volume of air displaced with each breath. NPPV can provide modes nearly identical to standard ICU ventilators, such as pressure, volume, assist control, or even proportional assist ventilation. Patient-ventilator interfaces for NPPV include a face mask, nasal mask or plugs, or a helmet that covers the head. Although the face mask may be less comfortable and more difficult to monitor for aspiration, it provides better physiological performance (less resistance to airflow and less air leak) when compared with nasal devices.22,23

The use of NPPV together with supportive care during the treatment of respiratory failure is attractive because it does not require either endotracheal intubation or moderate and/or deep sedation and can be safely initiated or discontinued as needed. It is also associated with few of the nosocomial complications recognized with endotracheal intubation, such as ventilator-associated pneumonia, critical illness-associated weakness, pneumothorax, delirium, and infections associated with the invasive monitoring that is typically required during invasive life support.16,20 NPPV is not appropriate for some patients, such as those with cardiopulmonary arrest or shock, where greater airway control is required, or those with facial trauma, where the interface (e.g., mask) cannot be used appropriately.

#### Barriers to the Use of NPPV and Factors That May Affect Outcomes

Although NPPV has been a readily available modality since the early 1990s, use varies substantially across and within countries. Surveys in the United States have shown high variability in estimated use across hospitals.14 Barriers to use include a lack of physician knowledge, low rates of perceived efficacy, lack of standard protocols and team-based care at some hospitals, and, among older clinicians, little training or experience with NPPV.24 A specific knowledge gap is uncertainty about the efficacy of NPPV for patients with acute respiratory failure for conditions other than COPD or ACPE.

NPPV is a resource-intensive modality and requires a substantial amount of training and experience to implement successfully. Optimal use requires coordination between respiratory therapists, nurses, and physicians to identify patients appropriate for NPPV treatment and to initiate and monitor response to treatment. Monitoring NPPV patients requires a significant time outlay for therapists because the severely ill patient does not have a protected airway. The patient receiving NPPV often requires more monitoring than one receiving invasive ventilation. In fact, there is a potential for harm if NPPV is applied or monitored improperly. Early in the course of NPPV, numerous adjustments must be made based on mask fit, patient-ventilator synchrony, and the ventilator settings themselves based on the patient's response to initial treatment. Since outcomes may be related to training and experience, some experts have questioned whether the beneficial effects of NPPV reported from randomized controlled trials (RCTs) are replicated when NPPV is used in routine practice. Differences in patient selection, the clinical setting and associated resources, use of protocols, and clinician training or experience could lead to important reductions in effectiveness when NPPV is implemented in more typical clinical settings.

## Scope and Key Questions

### Scope of This Review

The literature supporting the use of NPPV in the acute-care setting for respiratory failure has evolved over the last two decades.17 Although there have been some exceptions, such as a 2010 meta-analysis examining NPPV in acute respiratory failure of multiple causes,25 the use of NPPV has been most extensively studied in patients with acute respiratory failure due to COPD and congestive heart failure. Various professional societies have addressed NPPV in clinical practice guidelines; most of these address only the use of NPPV in COPD.26 In addition to these two well-studied uses, there is increasing interest in determining if NPPV is beneficial for other causes of acute respiratory failure (e.g., asthma) or can shorten the duration of invasive mechanical ventilation, either as a method to facilitate early extubation or to treat or prevent extubation failure in high-risk groups.25 Further, there is uncertainty about whether the beneficial effects demonstrated in RCTs are replicated in real-world settings where training, experience, organizational factors, and patient factors may differ substantially from the trials. For this reason, we conducted a systematic review that is inclusive of all major causes of acute respiratory failure and includes studies of NPPV used for weaning from invasive ventilation. Although real-world effects were of interest, we restricted our review to RCTs because RCTs give more valid estimates of comparative effectiveness. Further, our Technical Expert Panel (TEP) advised that observational studies were unsuitable for evaluating the comparative effectiveness of this treatment.

### Key Questions

With input from the TEP, we constructed Key Questions using the general approach of specifying the population of interest, the interventions, comparators, outcomes, timing of outcomes, and settings (PICOTS; see the section on “Inclusion and Exclusion Criteria” in the Methods chapter for details). The Key Questions considered in this CER are:

KQ 1 Is noninvasive positive-pressure ventilation (NPPV) associated with less morbidity (including from intubation), lower mortality, fewer adverse events, or lower medical utilization when compared with supportive medical therapy or invasive ventilation:
  a. In adults with chronic obstructive pulmonary disease (COPD) and acute respiratory failure?
  b. In adults with acute cardiogenic pulmonary edema (ACPE)?
  c. In adults with acute respiratory failure due to other causes including: pneumonia, asthma, obesity-hypoventilation syndrome, and interstitial lung disease?
  d. In adults with acute respiratory failure in selective settings including: postoperative setting and post-transplant setting?
KQ 2 Is NPPV with bilevel positive airway pressure (BPAP), compared with NPPV with continuous positive airway pressure (CPAP), associated with less morbidity, lower mortality, fewer adverse events, or lower medical utilization:
  a. In adults with COPD and acute respiratory failure?
  b. In adults with ACPE?
  c. In adults with acute respiratory failure due to other causes including: pneumonia, asthma, obesity-hypoventilation syndrome, and interstitial lung disease?
  d. In adults with acute respiratory failure in selective settings including: postoperative setting and post-transplant setting?
KQ 3 Is early extubation to NPPV, compared with usual care, associated with less morbidity, lower mortality, fewer adverse events, or lower medical utilization:
  a. In adults with COPD and acute respiratory failure?
  b. In adults with ACPE?
  c. In adults with acute respiratory failure due to other causes including: pneumonia, asthma, obesity-hypoventilation syndrome, and interstitial lung disease?
  d. In adults with acute respiratory failure in selective settings including: postoperative setting and post-transplant setting?
KQ 4 For KQs 1–3, do the effectiveness and risks of NPPV vary by setting and associated resources, experience and training of clinicians, and use of protocols or by patient characteristics (e.g., morbid obesity, mental-status changes, overall disease burden)?

## Analytic Framework

Figure 1 shows the analytic framework for this project.

Figure 1 Analytic framework

Abbreviations: ACPE = acute cardiogenic pulmonary edema; ARF = acute respiratory failure; BPAP = bilevel positive airway pressure; COPD = chronic obstructive pulmonary disease; CPAP = continuous positive airway pressure; HRQOL = health-related quality of life; ICU = intensive care unit; KQ = Key Question; MI = myocardial infarction; NPPV = noninvasive positive-pressure ventilation; PaCO2 = partial pressure of carbon dioxide in blood; PaO2 = partial pressure of oxygen in arterial blood.

This figure depicts the Key Questions (KQs) within the context of the PICO (population, interventions, comparators, and outcomes) described elsewhere in this report. In general, the figure shows that the report compares morbidity, mortality, adverse events, and health care utilization for patients receiving noninvasive positive pressure ventilation (NPPV) versus supportive medical therapy or invasive ventilation (KQ 1), patients receiving NPPV with bilevel positive airway pressure (BPAP) versus NPPV with continuous positive airway pressure (CPAP; KQ 2), and patients receiving early extubation to NPPV versus those receiving weaning strategies that do not utilize NPPV (KQ 3). Subgroups considered for KQs 1–3 include adults with chronic obstructive pulmonary disease (COPD) and respiratory failure; adults with acute cardiogenic pulmonary edema (ACPE); adults with acute respiratory failure due to other causes (pneumonia, asthma, obesity-hypoventilation syndrome, or interstitial lung disease) or in selective settings (postoperative or post-transplant). Adverse events considered are aspiration, secondary infections (including pneumonia and sinusitis), and facial ulcerations. Intermediate outcomes considered include physiological measures (respiratory rate, heart rate, PaO2, and PaCO2); intubation and reintubation rates; duration of mechanical ventilation; time to reintubation; rate of NPPV discontinuation due to intolerance; incident myocardial infarction; and psychological distress. Final outcomes assessed are functional status, health-related quality of life, mortality (in-hospital and 30-day), and health care utilization (ventilator-dependent days, rate of ventilator dependence at hospital discharge, length of hospital stay, length of intensive care unit stay, and total hospital costs). The report also considers whether the effectiveness and risks outlined in KQs 1–3 vary by setting and associated resources, experience and training of the clinicians, use of protocols, or by patient characteristics (e.g., mental status, obesity, and comorbidities).

This figure depicts the KQs within the context of the PICOTS described above. In general, the figure shows that this CER compares morbidity, mortality, adverse events, and health care utilization for patients receiving NPPV with supportive medical therapy or invasive ventilation (KQ 1), patients receiving NPPV with BPAP with NPPV with CPAP (KQ 2), and patients receiving early extubation to NPPV with those receiving weaning strategies that do not utilize NPPV (KQ 3). Subgroups considered for KQs 1–3 included adults with COPD and respiratory failure; adults with ACPE; adults with acute respiratory failure due to pneumonia, asthma, obesity-hypoventilation syndrome, or interstitial lung disease; and adults with acute respiratory failure in postoperative or posttransplant settings. Adverse events considered are aspiration, secondary infections (including pneumonia and sinusitis), and facial ulcerations. Intermediate outcomes included physiological measures (respiratory rate, heart rate, PaO2, and PaCO2); intubation and reintubation rates; duration of mechanical ventilation; time to reintubation; rate of NPPV discontinuation due to intolerance; incident myocardial infarction; and psychological distress. Final outcomes assessed are functional status, health-related quality of life, mortality (in-hospital and 30-day), and health care utilization (ventilator-dependent days, rate of ventilator dependence at hospital discharge, length of hospital stay, length of intensive care unit stay, and total hospital costs). The report also considers whether the effectiveness and risks outlined in KQs 1–3 vary by setting and associated resources, experience and training of the clinicians, use of protocols, or by patient characteristics (e.g., mental status, obesity, and comorbidities).