# Discussion

## Key Findings and Strength of Evidence

Acute respiratory failure is a common life-threatening disorder and is the most frequent condition managed in intensive care units (ICUs) around the world. Noninvasive positive-pressure ventilation (NPPV), most commonly delivered as continuous positive airway pressure (CPAP) or bilevel positive airway pressure (BPAP), is a form of mechanical ventilatory support that improves gas exchange and decreases a patient's work of breathing.

In this review, we included 69 trials that that compared NPPV with other common treatment strategies. Most studies compared NPPV with supportive care for the treatment of acute respiratory failure. A smaller group compared NPPV with conventional mechanical ventilation, compared different types of NPPV with one another (CPAP vs. BPAP), or considered NPPV to facilitate extubation or prevent or treat recurrent respiratory failure postextubation. We included common outcomes of interest such as mortality and adverse events, but also examined more difficult to measure issues such as resource utilization and efforts to shorten the duration of mechanical ventilation (by facilitating weaning from invasive ventilation, preventing extubation failure, and treating recurrent respiratory failure).

Results for these outcomes and comparisons, along with ratings for the strength of evidence (SOE)54,55 are summarized in Tables 18 and 19. Key findings with a high strength of evidence were decreased mortality and intubation rates for NPPV versus supportive care. This effect was established most strongly for patients with acute cardiogenic pulmonary edema (ACPE), or severe exacerbations of chronic obstructive pulmonary disease (COPD). Few studies enrolled patients with asthma, acute respiratory distress syndrome (ARDS), postoperative acute respiratory failure, or acute respiratory failure in post-transplant patients. We found moderate strength of evidence for a lack of treatment effect on myocardial infarction rates and reduced hospital-acquired pneumonia. Evidence was also moderately strong for comparable effects of CPAP and BPAP, but direct comparisons of these modalities come almost exclusively from studies of patients with ACPE. For NPPV versus supportive care, we found low SOE of no effect on length of hospitalization. We found insufficient evidence for other effects on utilization of medical resources due to inconsistent effects across studies, indirectness of the outcomes reported (length of stay) and imprecise results. Few studies reported effects beyond the duration of hospitalization, and no studies reported effects on functional status or quality of life.

Table 18 Summary of the strength of evidence for KQ 1—NPPV versus supportive care

Number of Studies (Subjects) | Domains Pertaining to SOE | | | | Strength of Evidence
Number of Studies (Subjects) | Risk of Bias: Study Design/ Quality | Consistency | Directness | Precision | Effect Estimate (95% CI)
Hospital mortality | | | | | High
39 (4111) | RCT/Good | Consistent | Direct | Precise | OR = 0.56 (0.44 to 0.72) RD = 64 fewer per 1000 (40 to 83)
Intubation rate | | | | | High
39 (3792) | RCT/Good | Inconsistent | Direct | Precise | OR = 0.31 (0.24 to 0.41) RD = 217 fewer per 1000 (177 to 247)
Myocardial infarction | | | | | Moderate
7 (1517) | RCT/Good | Consistent | Direct | Imprecise | OR = 1.11 (0.85 to 1.44) RD = not applicable
Medical utilization: Hospital length of stay (LOS) | | | | | Low
11 (2499)^a^ | RCT/Good | Consistent | Indirect | Imprecise | No study found a statistically significant difference in LOS
Medical utilization: ICU length of stay (LOS) | | | | | Insufficient
5 (523)^a^ | RCT/Good | Inconsistent | Indirect | Imprecise | Not estimable; 2 of 5 studies found a statistically significant decrease in LOS
Hospital-acquired pneumonia | | | | | Moderate
9 (650) | RCT/Good | Consistent | Direct | Imprecise | OR = 0.27 (0.15 to 0.49) RD = 121 fewer per 1000 (81 to 144)

a Data are for larger studies with sufficient power to test for a 1-day difference in LOS.

Abbreviations: CI = confidence interval; ICU = intensive care unit; LOS = length of stay; NA = not applicable; OR = odds ratio; RCT = randomized controlled trial; RD = risk difference; SOE = strength of evidence

Table 19 Summary of the strength of evidence for KQ 2—CPAP versus BPAP

Number of Studies (Subjects) | Domains Pertaining to SOE | | | | Strength of Evidence
Number of Studies (Subjects) | Risk of Bias: Study Design/Quality | Consistency | Directness | Precision | Effect Estimate (95% CI)
Hospital mortality | | | | | Moderate
10 (1338) | RCT/Good | Consistent | Direct | Imprecise | OR = 0.89 (0.58 to 1.35) RD = NA
Intubation rate | | | | | Moderate
12 (1463) | RCT/Good | Consistent | Direct | Imprecise | OR = 0.84 (0.51 to 1.38) RD = NA
Myocardial infarction | | | | | Low
7 (1056) | RCT/Good | Inconsistent | Indirect | Imprecise | OR = 0.69 (0.34 to 1.40) RD = NA
Medical utilization: hospital length of stay (LOS) | | | | | Insufficient
3 (278)^a^ | RCT/Good | Consistent | Indirect | Imprecise | Not estimable; No study found a statistically significant difference in LOS
Medical utilization: ICU length of stay (LOS) | | | | | Insufficient
0 (0) | NA | NA | NA | NA | Not estimable
Hospital-acquired pneumonia | | | | | Insufficient
0 (0) | NA | NA | NA | NA | Not estimable

a Data are for larger studies with sufficient power to test for a 1-day difference in LOS.

Abbreviations: CI = confidence interval; ICU = intensive care unit; LOS = length of stay; NA = not applicable; OR = odds ratio; RCT = randomized controlled trial; RD = risk difference; SOE = strength of evidence

NPPV was compared with invasive ventilation in only 405 subjects. Compared with invasive ventilation, NPPV lowered hospital-acquired pneumonia (SOE = high) but did not reduce mortality or length of stay (SOE = low).

Compared with studies evaluating NPPV for initial treatment of acute respiratory failure, fewer studies examined the effects of NPPV to assist in weaning from invasive ventilation or to prevent or treat recurrent acute respiratory failure postextubation. Results for these comparisons, along with ratings for the SOE are summarized in Tables 20–22. When compared with conventional weaning, we found low SOE for lower mortality in patients with COPD and a nonstatistically significant reduction in mortality in studies enrolling patient with mixed etiologies of acute respiratory failure. Results were similar for hospital-acquired pneumonia rates. NPPV did not affect reintubation rates, an effect that was consistent across diagnostic subgroups. Evidence was insufficient to estimate effects for other outcomes. When used to prevent acute respiratory failure postextubation, NPPV decreased mortality and reintubation (low SOE) only for patients at high-risk of recurrent acute respiratory failure (Table 21). Only two studies evaluated NPPV to treat recurrent acute respiratory failure postextubation. These studies did not show a benefit for NPPV on any outcome (Table 22).

Table 20 Summary of the strength of evidence for KQ 3—NPPV-assisted ventilator weaning versus conventional weaning

Number of Studies (Subjects) | Domains Pertaining to SOE | | | | Strength of Evidence
Number of Studies (Subjects) | Risk of Bias: Study Design/ Quality | Consistency | Directness | Precision | Effect Estimate (95% CI)
Hospital mortality—COPD | | | | | Low
2 (140) | RCT/Fair | Consistent | Direct | Imprecise | OR = 0.17 (0.05 to 0.65) RD = 129 fewer per 1000 (50 to 151)
Hospital mortality—mixed etiologies | | | | | Insufficient
3 (214) | RCT/Fair | Inconsistent | Direct | Imprecise | OR = 0.46 (0.06 to 3.59) RD = NA
Reintubation rate | | | | | Low
4 (303) | RCT/Good | Consistent | Direct | Imprecise | OR = 0.83 (0.48 to 1.44) RD = NA
Myocardial infarction | | | | | Insufficient
0 (none) | NA | NA | NA | NA | OR = not estimated
Medical utilization: hospital length of stay (LOS) | | | | | Insufficient
2 (229) | RCT/ | Consistent | Indirect | Imprecise | Not estimable; No study found a statistically significant difference in LOS
Medical utilization: ICU length of stay (LOS) | | | | | Insufficient
3 (279)^a^ | RCT/Good | Consistent | Indirect | Imprecise | Not estimable; 2 of 3 studies found a statistically significant decrease in LOS
Hospital acquired pneumonia—COPD | | | | | Low
2 (140) | RCT/Fair | Consistent | Direct | Imprecise | OR = 0.14 (0.04 to 0.48) RD = 167 fewer per 1,000 (33 to 233)
Hospital-acquired pneumonia—mixed etiologies | | | | | Low
3 (214) | RCT/Fair | Inconsistent | Direct | Imprecise | OR = 0.53 (0.19 to 1.46) RD = NA

a Data are for larger studies with sufficient power to test for a 1-day difference in LOS.

Abbreviations: CI = confidence interval; LOS = length of stay; NA = Not applicable; OR = odds ratio; RCT = randomized controlled trial; RD = risk difference; SOE = strength of evidence

Table 21 Summary of the strength of evidence for KQ 3—NPPV versus supportive care to prevent respiratory failure postextubation

Number of Studies (Subjects) | Domains Pertaining to SOE | | | | Strength of Evidence
Number of Studies (Subjects) | Risk of Bias: Study Design/ Quality | Consistency | Directness | Precision | Effect Estimate (95% CI)
Hospital mortality—high-risk group | | | | | Low
3 (365) | RCT/Good | Consistent | Direct | Imprecise | OR = 0.60 (0.34 to 1.04) RD = NA
Hospital mortality—average-risk group | | | | | Insufficient
1 (406) | RCT/Fair | NA | Direct | Imprecise | OR = 1.52 (0.25 to 9.21) RD = NA
Reintubation rate—high-risk group | | | | | Low
3 (365) | RCT/Good | Consistent | Direct | Imprecise | 0.43 (0.24 to 0.77)
Reintubation rate—average-risk group | | | | | Low
2 (499) | RCT/Fair | Consistent | Direct | Imprecise | OR = 1.56 (0.89 to 2.76) RD = NA
Myocardial infarction | | | | | Insufficient
0 (none) | NA | NA | NA | NA | OR = not estimated
Medical utilization: hospital length of stay (LOS) | | | | | Insufficient
3 (365) | RCT/Good | Consistent | Indirect | Imprecise | Not estimable; No study found a statistically significant difference in LOS
Medical utilization: ICU length of stay (LOS) | | | | | Insufficient
3 (365)^a^ | RCT/Good | Consistent | Indirect | Imprecise | Not estimable; No study found a statistically significant difference in LOS
Hospital acquired pneumonia | | | | | Low
2 (268)^a^ | RCT/Fair | Consistent | Direct | Imprecise | OR = 0.52 (0.28 to 0.97) RD = 102 fewer per 1,000 (6 to 164)

a Data are for larger studies with sufficient power to test for a 1-day difference in LOS.

Abbreviations: CI = confidence interval; LOS = length of stay; OR = odds ratio; RCT = randomized controlled trial; RD = risk difference; SOE = strength of evidence

Table 22 Summary of the strength of evidence for KQ 3—NPPV versus supportive care to treat respiratory failure postextubation

Number of Studies (Subjects) | Domains Pertaining to SOE | | | | Strength of Evidence
Number of Studies (Subjects) | Risk of Bias: Study Design/ Quality | Consistency | Directness | Precision | Effect Estimate (95% CI)
Hospital mortality | | | | | Low
2 (302) | RCT/Good | Consistent | Direct | Imprecise | OR = 1.52 (0.78 to 2.97) RD = NA
Reintubation rate | | | | | Low
2 (302) | RCT/Good | Consistent | Direct | Imprecise | OR = 1.05 (0.66 to 1.67) RD = NA
Myocardial infarction | | | | | Insufficient
0 (none) | NA | NA | NA | NA | OR = not estimated
Medical utilization: hospital length of stay (LOS) | | | | | Insufficient
1 (81) a | RCT/Good | NA | Indirect | Imprecise | Not estimable
Medical utilization: ICU length of stay (LOS) | | | | | Insufficient
2 (302)^a^ | RCT/Good | Consistent | Indirect | Imprecise | Not estimable; No study found a statistically significant difference in LOS
Hospital-acquired pneumonia | | | | | Insufficient
1 (81) | RCT/Good | NA | Direct | Imprecise | OR = 1.02 (0.42 to 2.48)

a Data are for larger studies with sufficient power to test for a 1-day difference in LOS.

Abbreviations: CI = confidence interval; LOS = length of stay; OR = odds ratio; RCT = randomized controlled trial; RD = risk difference; SOE = strength of evidence

We also sought to determine whether the effects of NPPV varied by clinical setting, the experience and composition of the treating clinicians, by patient characteristics and by whether each individual study was primarily an efficacy trial, an effectiveness trial, or mixed efficacy-effectiveness (Table 23). Too few studies reported clinician experience, treating team composition, or patient characteristics such as body mass index, mental status or overall disease burden to evaluate for differential effects. We used global geographical region as a proxy for experience with NPPV and found no significant difference in treatment effects across different regions. Most studies were classified as mixed efficacy-effectiveness studies; only two were classified as predominately effectiveness studies. Effects on mortality were lower for effectiveness studies but did not differ for intubation rates. These analyses were limited by the paucity of effectiveness trials. NPPV was initiated in intensive care unit, emergency departments (EDs), and mixed or other settings. In an exploratory analysis, treatment effects for death or intubation did not differ significantly by clinical setting.

Table 23 Summary of the strength of evidence for KQ 4—variability in treatment effect by study characteristics

Number of Studies (Subjects) | Domains Pertaining to SOE | | | | Strength of Evidence
Number of Studies (Subjects) | Risk of Bias: Study Design/Quality | Consistency | Directness | Precision | Summary of Effect
Different treatment effects by study effectiveness characteristics | | | | | Low
43 (4467)^a^ | Observational | Inconsistent | Direct | Imprecise | [underlined: OR (95% CI) for mortality:] Efficacy trial: 0.56 (0.31 to 1.02) Mixed trial: 0.52 (0.41 to 0.66) Effectiveness trial: 0.99 (0.66 to 1.49) [underlined: OR (95% CI) for intubation:] Efficacy trial: 0.29 (0.19 to 0.46) Mixed trial: 0.29 (0.21 to 0.41) Effectiveness trial: 0.58 (0.16 to 2.13)
Different treatment effects across clinical settings | | | | | Low
43 (4467)^a^ | Observational | Consistent | Direct | Imprecise | [underlined: OR (95% CI) for mortality:] ED: 0.72 (0.49 to 1.05) ICU: 0.48 (0.35 to 0.66) [underlined: OR (95% CI) for intubation:] ED: 0.50 (0.26 to 0.95) ICU: 0.23 (0.15 to 0.34)
Different treatment effects across geographical regions b | | | | | Low
43 (4467)^a^ | Observational | Consistent | Direct | Imprecise | [underlined: OR (95% CI) for mortality:] Europe: 0.58 (0.46 to 0.73) U.S./Canada: 0.58 (0.25 to 1.33) [underlined: OR (95% CI) for intubation:] Europe: 0.33 (0.22 to 0.48) U.S./Canada: 0.36 (0.20 to 0.66)

a 39 studies and 3792 patients for analyses of intubation rates.

b Geographical regions used were: U.S./Canada, Europe, and other

Abbreviations: KQ = Key Question; OR = odds ratio; SOE = strength of evidence; ED = emergency department; ICU = intensive care unit

### Findings in Relation to What Is Already Known

Our results are generally consistent with previous systematic reviews45,47,48 and clinical guidelines.26,41,126 Previous reviews have found similar benefits on mortality and intubation rates in patients with respiratory failure due to ACPE36,39,42,47,48 and severe exacerbations of COPD.45,46 Our review spanned multiple conditions, finding consistent treatment effects across conditions, whereas prior reviews tend to be focused on a single cause of acute respiratory failure. Like others, we found few studies addressing acute respiratory failure in patients who are postoperative, post-transplant, or who have acute respiratory failure in the context of obesity-hypoventilation syndrome, asthma, or interstitial lung disease. As in other reviews, we found comparable effects for CPAP and BPAP, but we were able to strengthen this conclusion by incorporating indirect comparisons. Also of note, our review is the first to classify trials by efficacy and effectiveness characteristics, an analysis that highlights the paucity of effectiveness studies.

There are several other considerations that warrant further discussion. Regarding NPPV for ACPE, our positive findings are in contrast to the Three Interventions in Cardiogenic Pulmonary Oedema (3CPO) trial, the largest published trial, comprising about one-quarter of our overall sample. Investigators in that trial concluded that NPPV does not reduce early mortality.71,127 The lack of treatment effect in the 3CPO study was likely related to the relatively short duration of the NPPV intervention, a patient sample that was less severely ill than in many other studies, and the large number of patients assigned to supportive care who crossed over to the NPPV treatment arms. It should also be considered that standard medical therapy for ACPE has likely improved over the past 20 years. The 3CPO study is a relatively recent study and improved supportive treatments could diminish the differential treatment effects. In fact, our analysis of time trends showed smaller treatment effects in more recent studies.

A systematic review and meta-analysis by Burns et al.34 demonstrated a consistent positive effect of NPPV weaning on mortality and ventilator-associated pneumonia, which is in contrast to our findings of significant effects that vary by population. However, the Burns review and the trials included had important limitations. Most studies in their review were restricted to patients with predominately or exclusively COPD. There was also evidence for publication bias, imprecision due to a relatively small number of study participants (n = 530) and events (102 deaths), and the review included studies from countries with health systems that are less applicable to care in the United States. Our review also has limitations when evaluating this question. We too identified a relatively small number of trials that were analyzed in three subgroups depending on the specific clinical application of NPPV. For each clinical scenario, we conducted exploratory analysis by diagnostic group or risk of recurrent acute respiratory failure, indirect comparisons that are subject to confounding.

### Applicability

The positive effects of interventions do not always translate well to usual practice, where clinician training, clinical setting, system resources and patients characteristics may vary importantly from trial conditions. In our review, relatively few studies were conducted in the United States or Canada (n = 8), with most studies (57%) conducted in Europe. There is a longer clinical experience with NPPV in Europe compared with the United States, leading us to hypothesize that outcomes may be better in European countries. However, our analyses showed treatment effects for NPPV that were consistent across studies conducted in the U.S. or Canada compared with European or other countries. Treatment effects associated with NPPV were also fairly consistent across clinical settings. Summary odds ratios (ORs) for NPPV initiated in the ICU showed greater, although not statistically significant, differences compared with usual supportive care or invasive ventilator support. Our analysis of differential treatment effects by design characteristics showed inconsistent results for those with more effectiveness characteristics (more real-world application) than those designed as efficacy trials. Effectiveness studies showed significantly less effect on mortality but not on intubation. Collectively, these results do not show strong differential effects related to experience in using NPPV, but our analyses were limited by few studies in some categories and proxies for experience. Given these limitations, current evidence is insufficient to estimate the effect of clinician experience, setting, system resources, and patient characteristics on treatment effects.

Other study reporting issues also affect applicability. The study interventions were not well-described in the majority of the studies, a limitation that could impede dissemination. Twelve of the 69 studies poorly described the patient population, and 9 reported only outcomes that occurred 72 hours or less after initiating NPPV or a control intervention. More consistent reporting of patient characteristics, including overall medical comorbidity, race and body mass index, would facilitate evaluations of differential effects in these important subgroups.

## Implications for Clinical and Policy Decisionmaking

Our review updates and strengthens the evidence for the benefits of NPPV, particularly in patients with acute respiratory failure due to severe exacerbations of COPD or congestive heart failure (CHF). The Canadian Critical Care Society recently made strong recommendations to use NPPV in these two populations.41 Guidelines groups from the United States have made weaker recommendations to use NPPV in patients with CHF128 or have not addressed the use of NPPV.129 The Canadian guideline panel made weaker recommendations suggesting that centers with expertise in NPPV use this treatment for early liberation from mechanical ventilation and in patients at high risk for respiratory failure postextubation.

Consistent with other systematic reviews, our review highlights the limited data for patient with acute respiratory failure not due to COPD or CHF. Although additional studies are needed to strengthen the evidence, current studies support the use of NPPV for patients with acute respiratory failure postoperatively or who are post-transplant and immunocompromised. The data for other indications are insufficient to draw any conclusions. The Canadian guideline panel made a weak recommendation to use NPPV for these indications but limited their recommendation to postoperative use after abdominal or lung-resection surgery.

We found that factors potentially related to treatment effects, such as the experience of the treating clinicians, resources such as staffing ratios, and patient characteristics were poorly reported. Understanding whether treatment effects vary by patient characteristics can help to target treatment to patients most likely to benefit. Understanding whether treatment effects in real-world practice are similar to those found in carefully controlled trials can inform needed improvements in patient selection and clinician training. This is particularly important because the misuse of NPPV, which may occur by persons insufficiently trained in its application, could in fact be associated with patient harm. A survey of respiratory care directors in two northeastern states showed relatively low use of NPPV (20% of ventilator starts) and high variability in estimated use across hospitals (none to greater than 50%).14 The top two reasons given for lower utilization rates were a lack of physician knowledge and inadequate equipment. A more recent study in Veterans Affairs hospitals found a wide range in training and experience with NPPV, underutilization and low rates of perceived efficacy.24 Respiratory therapists had greater training and experience with NPPV than physicians and more recently trained physicians had greater training than their older peers. Surveys of EDs in the United States and United Kingdom report higher rates of use.130,131 Reassuringly, use is most common for patients where the evidence is strongest, in those with acute respiratory failure due to COPD or ACPE. Nevertheless, the gap between the evidence for strong effects in specific patient populations and routine clinical use suggests the need for better dissemination of clinical guidelines and efforts to implement NPPV more uniformly. A review that uses Rogers Diffusions of Innovations as a model outlines potential steps for improving uptake into clinical practice.131

## Limitations of the Comparative Effectiveness Review Process

Our findings have limitations related to the literature and our approach. Important limitations of the literature include few studies in certain populations of high interest, incomplete reporting of outcomes related to resource utilization, and descriptions of the interventions that were often inadequate to permit replication. In addition, the limited reporting of adverse effects and myocardial infarction suggest the possibility of selective outcomes reporting. Limitations in reporting precluded any analyses of variability in treatment effects by patient characteristics. A patient level meta-analysis was not possible in the current study, but would be a useful approach to examine this issue.

Our review methods also had limitations. Our study was limited to English-language publications which may have contributed to different conclusions about the effects of NPPV on ventilator weaning compared with Burns et al.34 Some outcomes, such as hospital-acquired pneumonia, were not defined explicitly in many of the primary studies, and depending on the definition and method of ascertainment, could be biased when outcome assessors were not blind to treatment allocation. Although we attempted to evaluate the impact of effectiveness versus efficacy studies, our approach consisted of indirect comparisons without adjustment for potential confounders. The approach was further limited by a simple rules based approach to classifying certain items in the efficacy-effectiveness scale (e.g., university affiliation = highly trained) and few effectiveness studies. Finally, some would argue that summary estimates across different etiologies of acute respiratory failure are not indicated. Although the underlying pathophysiology of acute respiratory failure differs by etiology, the studies were conceptually similar in design, intervention, and outcomes. In most instances, there was small to moderate variability in effects, even across diagnostic groups, and thus we computed summary estimates of effect for most outcomes.

## Research Gaps

We used the framework recommended by Robinson et al.132 to identify gaps in evidence and classify why these gaps exist. This approach considers PICOTS (population, intervention, comparator, outcomes, timing, and setting) to identify gaps and classifies gaps as due to (a) insufficient or imprecise information, (b) biased information; (c) inconsistency or unknown consistency, and (d) not the right information. In addition, we considered studies in progress identified from ClinicalTrials.gov when making recommendations for future research. Gaps and recommendations are presented in Table 24. Although we recommend multicenter RCTs to address some evidence gaps, we are aware that there are some particular challenges to conducting these RCTs. It is difficult to blind patients or treating clinicians to the treatment group. While lack of blinding is unlikely to bias ascertainment of mortality outcomes, it could introduce bias in the assessment of more subjective outcomes and a subtle bias into patient care. Therefore it is critical that supportive treatments be specified carefully and that outcomes be assessed by individuals who are blind to treatment assignment. Blinded outcome assessment and carefully defined endpoints are particularly important for outcomes that include subjectivity such as the need for intubation. Some studies included in our review reported effects on length of stay for the sample overall and the subgroup of survivors. Since NPPV has a mortality advantage, length-of-stay analyses could be biased if analyses use all patients randomized. Studies should report length of stay for the sample overall and for the subgroup of survivors. Additionally, the application of NPPV among patients at the end of life needs further study. Many providers do not conceptualize NPPV as a form of life support, and this constitutes a potential threat to the patient-centeredness of care among those with do not attempt resuscitation orders. Finally, we recommend that authors provide more careful descriptions of the patient population, details of randomization and allocation concealment, and detailed intervention protocols to facilitate dissemination of effective treatments.

Table 24 Evidence gaps and future research

Evidence Gap | Reason | Type of Studies To Consider
Patients
Effects versus supportive care in patients with asthma, interstitial lung disease, pneumonia, acute decompensated, obesity-hypoventilation syndrome and those who are postoperative or post-transplant | Insufficient or imprecise information | Multicenter RCTs
Uncertain benefit of NPPV to assist weaning | Imprecise information | Multicenter RCTs
Uncertain benefit of NPPV to prevent recurrent acute respiratory failure postextubation | Imprecise information | Multicenter RCTs
Whether NPPV treatment effects vary by patient characteristics | Insufficient information | Patient level meta-analyses Subgroup analyses from large, multicenter RCTs Improved reporting in trial publications
Outcomes
Effects on resource utilization NPPV compared with supportive care for acute respiratory failure | Insufficient information; not the right information | Analyze effects on resource utilization from large trials Model effects on resource utilization
Effects on psychological response, functional status, or health-related quality of life | Insufficient information | Multicenter RCTs
Settings
Effectiveness of NPPV as implemented in usual care (outside of RCTs) | Insufficient information | Observational studies
Uncertainty about the effects of training, staffing composition/ratios and use of algorithms on NPPV effectiveness | Insufficient information | Observational studies

Abbreviations: NPPV = noninvasive positive-pressure ventilation; RCT = randomized controlled trial

## Conclusions

In summary, for patients with acute respiratory failure due to severe exacerbations of COPD or congestive heart failure, NPPV plus supportive care shows important reductions in mortality and intubation rates compared with supportive care alone. BPAP has been studied more rigorously, but direct comparisons of CPAP and BPAP in patients with ACPE show similar efficacy. Current evidence suggests potential benefit for patients with acute respiratory failure who are postoperative or post-transplant and as a method to facilitate weaning from invasive ventilation or prevent recurrent postextubation respiratory failure in those at high risk. However, the evidence for these indications is much weaker. Limited evidence shows similar treatment effects across different settings and the possibility of less benefit in trials designed to replicate usual clinical practice. There is a clear need for further studies in patient populations where NPPV has not been rigorously studied and to understand the role of training and effectiveness when used as part of routine clinical care.