# Characteristics of Included Studies

Table G-1 Characteristics of included studies (ordered first by KQ, then alphabetically by first author)

Study | KQ Applicability | Location; Setting; Total N | ARF Etiology^a^ | Demographics | Disease Severity | Type of NPPV | Comparator | Quality Assessment Rating
Anonymous 2005^1^ | KQ 1 KQ 4 | Asia GMU 342 | COPD | Mean age: 69.5 % Male: 38.0 | APACHE II score: 10.9 | BPAP | Supportive | Good
Antonelli 1998^2^ | KQ 1 KQ 4 | Italy ICUs 64 | Mixed | Mean age: 54.5 % Male: 59.4 | SAPS: 12.5 | BPAP | IVS | Good
Antonelli 2000^3^ | KQ 1 KQ 4 | Italy ICUs 40 | Transplant | Mean age: 44.5 % Male: 37.5 | SAPS: 13 | BPAP | Supportive | Good
Auriant 2001^4^ | KQ 1 KQ 4 | France ICUs 48 | Post-op | Mean age: 61.0 % Male: NR | SAPS: 16.25 | BPAP | Supportive | Good
Barbe 1996^5^ | KQ 1 KQ 4 | Spain Respiratory ward 24 | COPD | Mean age: 68.0 % Male: NR | NR | BPAP | Supportive | Poor
Bersten 1991^6^ | KQ 1 KQ 4 | Australia ED 39 | ACPE | Mean age: 75.5 % Male: 33.3 | APACHE II score: 20.51 | CPAP | Supportive | Fair
Bott 1993^7^ | KQ 1 KQ 4 | UK NR 60 | COPD | Mean age: NR % Male: NR | NR | BPAP | Supportive | Poor
Brochard 1995^8^ | KQ 1 KQ 4 | Europe ICUs 85 | COPD | Mean age: 70.0 % Male: NR | SAPS: 12.49 | BPAP | Supportive | Good
Carrera 2009^9^ | KQ 1 | Europe Respiratory ward 75 | COPD | Mean age: 70.5 % Male: NR | NR | BPAP | Supportive | Good
Celikel 1998^10^ | KQ 1 KQ 4 | Turkey ICUs 30 | COPD (≥ 70%) | Mean age: NR % Male: NR | NR | BPAP | Supportive | Poor
Confalonieri 1999^11^ | KQ 1 KQ 4 | Europe ICUs 56 | Mixed | Mean age: 63.5 % Male: 71.4 | APACHE II score: 19 | Other | Supportive | Good
Conti 2002^12^ | KQ 1 | Italy ICUs 49 | COPD | Mean age: 71.9 % Male: NR | SAPS: 38.22 | Other | IVS | Fair
Delclaux 2000^13^ | KQ 1 KQ 4 | Europe; Africa ICUs 123 | Mixed | Mean age: NR % Male: 63.4 | NR | CPAP | Supportive | Good
Dhamija 2005^14^ | KQ 1 KQ 4 | India NR 29 | COPD | Mean age: NR % Male: NR | NR | BPAP | Supportive | Poor
Dikensoy 2002^15^ | KQ 1 KQ 4 | Turkey ED 34 | COPD | Mean age: 64.7 % Male: 58.8 | NR | BPAP | Supportive | Poor
Ferrer 2003^16^ | KQ 1 KQ 4 | Europe ICUs 105 | Mixed | Mean age: 61.5 % Male: 55.2 | SAPS: 33.49 | BPAP | Supportive | Fair
Gupta 2010^17^ | KQ 1 | India ICUs 53 | Asthma | Mean age: 43.8 % Male: 20.8 | NR | BPAP | Supportive | Good
Hilbert 2001^18^ | KQ 1 KQ 4 | France ICUs 52 | Transplant | Mean age: 49.0 % Male: 71.2 | SAPS: 43.5 | BPAP | Supportive | Good
Holley 2001^19^ | KQ 1 | Jacksonville, FL ED 35 | Asthma | Mean age: 36.8 % Male: 28.6 | NR | BPAP | Supportive | Fair
Honrubia 2005^20^ | KQ 1 KQ 4 | Europe ICUs 64 | Mixed | Mean age: 67.4 % Male: 70.3 | APACHE II score: 24.48 | BPAP | IVS | Fair
Jurjevic 2009^21^ | KQ 1 KQ 4 | Croatia ICUs 156 | COPD | Mean age: NR % Male: 66.0 | NR | BPAP | IVS | Fair
Keenan 2005^22^ | KQ 1 KQ 4 | Canada Respiratory ward 52 | COPD | Mean age: 70.0 % Male: 46.2 | APACHE II score: 18.04 | BPAP | Supportive | Good
Kelly 2002^23^ | KQ 1 KQ 4 | NR ED; stepdown unit 58 | ACPE | Mean age: 77.5 % Male: 44.8 | NR | CPAP | Supportive | Fair
Khilnani 2010^24^ | KQ 1 KQ 4 | India ICUs 40 | COPD | Mean age: 57.5 % Male: 77.5 | APACHE II score: 16.44 | BPAP | Supportive | Fair
Kramer 1995^25^ | KQ 1 KQ 4 | U.S. ICUs; GMU; stepdown unit 30 | COPD(≥ 70%) | Mean age: 68.5 % Male: 60.0 | APACHE II score: 18.48 | BPAP | Supportive | Good
Levitt 2001^26^ | KQ 1 KQ 4 | Oakland, California ED 38 | ACPE | Mean age: 67.9 % Male: 34.2 | NR | BPAP | Supportive | Fair
L'Her 2004^27^ | KQ 1 KQ 4 | Europe ED 89 | ACPE | Mean age: 84.0 % Male: 41.6 | NR | CPAP | Supportive | Fair
Lin 1991^28^ | KQ 1 | Taiwan ICUs 55 | ACPE | Mean age: 73.8 % Male: 90.9 | NR | CPAP | Supportive | Fair
Lin 1995^29^ | KQ 1 KQ 4 | Asia ED; ICU 100 | ACPE | Mean age: 72.5 % Male: 90.0 | NR | CPAP | Supportive | Fair
Martin 2000^30^ | KQ 1 KQ 4 | Pittsburg, PA ICU 61 | Mixed | Mean age: 61.1 % Male: 47.5 | APACHE III score: 61.33 | BPAP | Supportive | Fair
Masip 2000^31^ | KQ 1 KQ 4 | Europe ICUs 142 | ACPE | Mean age: 76.9 % Male: 13.4 | APACHE II score: 16 | BPAP | Supportive | Fair
Matic 2007^32^ | KQ 1 KQ 4 | Croatia ICUs 72 | COPD | Mean age: NR % Male: 66.7 | NR | BPAP | IVS | Fair
Nava 2003^33^ | KQ 1 KQ 4 | ER ED 130 | ACPE | Mean age: 72.6 % Male: 77.7 | SAPS: 21.1 | BPAP | Supportive | Good
Nava 2011^34^ | KQ 1 KQ 4 | Europe ICU 82 | COPD | Mean age: 81.3 % Male: 65.9 | SAPS: 33.5 | Other | Supportive | Good
Pastaka 2007^35^ | KQ 1 KQ 4 | Greece Respiratory ward 42 | COPD | Mean age: 68.4 % Male: 78.6 | NR | BPAP | Supportive | Fair
Plant 2000;^36^ Plant 2001^37^ | KQ 1 KQ 4 | UK GMU; Respiratory ward 236 | COPD | Mean age: 69.0 % Male: 49.6 | NR | BPAP | Supportive | Good
Soroksky 2003^38^ | KQ 1 | Tel Aviv, Israel ED 30 | Asthma | Mean age: 33.3 % Male: 50.0 | NR | BPAP | Supportive | Fair
Squadrone 2005^39^ | KQ 1 KQ 4 | Europe Postoperative 209 | Post-op | Mean age: 65.5 % Male: 64.6 | SAPS: 27.5 | CPAP | Supportive | Good
Takeda 1997^40^ | KQ 1 KQ 4 | Japan ICU 30 | ACPE | Mean age: 66.5 % Male: 73.3 | APACHE II score: 14.65 | CPAP | Supportive | Fair
Takeda 1998^41^ | KQ 1 KQ 4 | Tokyo, Japan ICU 22 | ACPE | Mean age: 74.5 % Male: 77.3 | APACHE II score: 10.65 | CPAP | Supportive | Fair
Thys 2002^42^ | KQ 1 KQ 4 | Belgium ED 20 | Mixed | Mean age: 73.5 % Male: 55.0 | NR | BPAP | Supportive | Good
Wermke 2011^43^ | KQ 1 KQ 4 | Dresden, Germany Oncology unit 86 | Transplant | Mean age: NR % Male: NR | NR | BPAP | Supportive | Fair
Wood 1998^44^ | KQ 1 KQ 4 | St. Louis, MO ED 27 | Mixed | Mean age: 58.7 % Male: 59.3 | APACHE II score: 17.08 | BPAP | Supportive | Good
Wysocki 1995^45^ | KQ 1 KQ 4 | France ICUs 41 | Mixed | Mean age: 63.0 % Male: 58.5 | SAPS: 12 | Other | Supportive | Good
Zhan 2012^46^ | KQ 1 KQ 4 | Asia ICUs 40 | ARDS | Mean age: 46.3 % Male: 60.0 | SAPS: 12.6 | BPAP | Supportive | Good
Crane 2004^47^ | KQ 1 KQ 2 KQ 4 | UK ED 60 | ACPE | Mean age: 75.2 % Male: 38.3 | NR | CPAP BPAP | Supportive | Good
Gray 2008;^48^ Gray 2009^49^ | KQ 1 KQ 2 KQ 4 | UK ED 1069 | ACPE | Mean age: 78.0 % Male: 43.3 | NR | CPAP BPAP | Supportive | Good
Park 2001^50^ | KQ 1 KQ 2 KQ 4 | Sao Paulo, Brazil NR 26 | ACPE | Mean age: NR % Male: 38.5 | NR | CPAP BPAP | Supportive | Poor
Park 2004^51^ | KQ 1 KQ 2 KQ 4 | Brazil ED 80 | ACPE | Mean age: 64.0 % Male: 42.5 | APACHE II score: 19.34 | CPAP | BPAP | Fair
Bellone 2004^52^ | KQ 2 | Italy ED 46 | ACPE | Mean age: 77.1 % Male: 50.0 | APACHE II score: 18.26 | CPAP | BPAP | Fair
Bellone 2005^53^ | KQ 2 | Italy ED 36 | ACPE | Mean age: 76.8 % Male: 33.3 | APACHE II score: 18.15 | CPAP | BPAP | Fair
Cross 2003^54^ | KQ 2 | Australia/N.Z. ED 101 | COPD (≥ 70%) | Mean age: 72.5 % Male: NR | NR | CPAP | BPAP | Fair
Ferrari 2007^55^ | KQ 2 | Turin, Italy High dependency unit 52 | ACPE | Mean age: 75.5 % Male: 44.2 | SAPS: 45.97 | CPAP | BPAP | Fair
Ferrari 2010^56^ | KQ 2 | Europe ED 80 | ACPE | Mean age: 77.0 % Male: NR | SAPS: 41.6 | CPAP | BPAP | Good
Mehta 1997^57^ | KQ 2 | Providence, RI ED 27 | ACPE | Mean age: 76.5 % Male: 40.7 | APACHE II score: 17.93 | BPAP | CPAP | Poor
Moritz 2007^58^ | KQ 2 | Europe ED 109 | ACPE | Mean age: 77.6 % Male: 52.3 | NR | CPAP | BPAP | Fair
Nouira 2011^59^ | KQ 2 | Africa ED 200 | ACPE | Mean age: 69.0 % Male: 43.5 | APACHE II score: 16 | CPAP | BPAP | Good
Anonymous 2005^60^ | KQ 3 | Asia ICUs 90 | COPD | Mean age: 68.6 % Male: 66.7 | APACHE II score: 9 | BPAP | IVS | Fair
Esteban 2004^61^ | KQ 3 | U.S., Canada, Europe, S. America, Middle East ICUs 221 | Mixed | Mean age: 59.5 % Male: 57.5 | APACHE II score: 36.52 | BPAP | Supportive | Good
Ferrer 2003^62^ | KQ 3 | Europe ICUs 43 | Mixed | Mean age: 70.7 % Male: 69.8 | APACHE II score: 18.16 | BPAP | IVS | Fair
Ferrer 2006^63^ | KQ 3 | Spain ICUs 162 | Mixed | Mean age: 71.0 % Male: 71.0 | APACHE II score: 13.49 | BPAP | Supportive | Fair
Ferrer 2009^64^ | KQ 3 | Europe ICUs 106 | Mixed | Mean age: 68.5 % Male: 75.5 | APACHE II score: 11 | BPAP | Supportive | Good
Girault 1999^65^ | KQ 3 | Rouen, France ICUs 33 | Mixed | Mean age: 64.2 % Male: NR | SAPS: 38.42 | BPAP | IVS | Fair
Girault 2011^66^ | KQ 3 | Europe ICUs 208 | Mixed | Mean age: NR % Male: 71.6 | NR | Other | Supportive IVS | Good
Jiang 1999^67^ | KQ 3 | Taiwan ICUs 93 | Mixed | Mean age: 72.8 % Male: 63.4 | APACHE II score: 16.8 | BPAP | Supportive | Poor
Keenan 2002^68^ | KQ 3 | Canada ICUs 81 | Mixed | Mean age: 68.5 % Male: NR | APACHE II score: 23.28 | BPAP | Supportive | Good
Nava 1998^69^ | KQ 3 | Europe ICUs 50 | COPD | Mean age: 67.9 % Male: NR | APACHE II score: 23.7 | BPAP | IVS | Good
Nava 2005^70^ | KQ 3 | Europe ICUs 97 | Mixed | Mean age: 54.6 % Male: 62.9 | SAPS: 32.45 | BPAP | Supportive | Good
Su 2012^71^ | KQ3 | Asia ICUs 406 | Mixed | Mean age: 63.9 % Male: 60.8 | SAPS: 18.2 | BPAP | Supportive | Fair

a In instances where a single ARF etiology made up 70% or more of the population, that etiology has been listed, along with the notation “(≥ 70%).” ARF etiology has been listed as “Mixed” if no single etiology made up at least 70% of the population.

Abbreviations: ACPE = acute cardiogenic pulmonary edema; APACHE II = Acute Physiology And Chronic Health Evaluation II; ARF = acute respiratory failure; BPAP = bilevel positive airway pressure; COPD = chronic obstructive pulmonary disease; CPAP = continuous positive airway pressure; GMU = general medical unit; ICU = intensive care unit; IVS = invasive ventilatory support; KQ = key question; N = number of participants; NPPV = noninvasive positive-pressure ventilation; NR = not reported; SAPS = Simplified Acute Physiology Score

## References

1 Anonymous. Early use of non-invasive positive pressure ventilation for acute exacerbations of chronic obstructive pulmonary disease: a multicentre randomized controlled trial. Chin Med J (Engl). 2005;118(24):2034-40. [pmid: 16438899].
2 Antonelli M, Conti G, Rocco M, et al. A comparison of noninvasive positive-pressure ventilation and conventional mechanical ventilation in patients with acute respiratory failure. N Engl J Med. 1998;339(7):429-35. [pmid: 9700176].
3 Antonelli M, Conti G, Bufi M, et al. Noninvasive ventilation for treatment of acute respiratory failure in patients undergoing solid organ transplantation: a randomized trial. JAMA. 2000;283(2):235-41. [pmid: 10634340].
4 Auriant I, Jallot A, Herve P, et al. Noninvasive ventilation reduces mortality in acute respiratory failure following lung resection. Am J Respir Crit Care Med. 2001;164(7):1231-5. [pmid: 11673215].
5 Barbe F, Togores B, Rubi M, et al. Noninvasive ventilatory support does not facilitate recovery from acute respiratory failure in chronic obstructive pulmonary disease. Eur Respir J. 1996;9(6):1240-5. [pmid: 8804944].
6 Bersten AD, Holt AW, Vedig AE, et al. Treatment of severe cardiogenic pulmonary edema with continuous positive airway pressure delivered by face mask. N Engl J Med. 1991;325(26):1825-30. [pmid: 1961221].
7 Bott J, Carroll MP, Conway JH, et al. Randomised controlled trial of nasal ventilation in acute ventilatory failure due to chronic obstructive airways disease. Lancet. 1993;341(8860):1555-7. [pmid: 8099639].
8 Brochard L, Mancebo J, Wysocki M, et al. Noninvasive ventilation for acute exacerbations of chronic obstructive pulmonary disease. N Engl J Med. 1995;333(13):817-22. [pmid: 7651472].
9 Carrera M, Marin JM, Anton A, et al. A controlled trial of noninvasive ventilation for chronic obstructive pulmonary disease exacerbations. J Crit Care. 2009;24(3):473 e7-14. [pmid: 19327308].
10 Celikel T, Sungur M, Ceyhan B, et al. Comparison of noninvasive positive pressure ventilation with standard medical therapy in hypercapnic acute respiratory failure. Chest. 1998;114(6):1636-42. [pmid: 9872200].
11 Confalonieri M, Potena A, Carbone G, et al. Acute respiratory failure in patients with severe community-acquired pneumonia. A prospective randomized evaluation of noninvasive ventilation. Am J Respir Crit Care Med. 1999;160(5 Pt 1):1585-91. [pmid: 10556125].
12 Conti G, Antonelli M, Navalesi P, et al. Noninvasive vs. conventional mechanical ventilation in patients with chronic obstructive pulmonary disease after failure of medical treatment in the ward: a randomized trial. Intensive Care Med. 2002;28(12):1701-7. [pmid: 12447511].
13 Delclaux C, L'Her E, Alberti C, et al. Treatment of acute hypoxemic nonhypercapnic respiratory insufficiency with continuous positive airway pressure delivered by a face mask: A randomized controlled trial. JAMA. 2000;284(18):2352-60. [pmid: 11066186].
14 Dhamija A, Tyagi P, Caroli R, et al. Noninvasive ventilation in mild to moderate cases of respiratory failure due to acute exacerbation of chronic obstructive pulmonary disease. Saudi Med J. 2005;26(5):887-90. [pmid: 15951894].
15 Dikensoy O, Ikidag B, Filiz A, et al. Comparison of non-invasive ventilation and standard medical therapy in acute hypercapnic respiratory failure: a randomised controlled study at a tertiary health centre in SE Turkey. Int J Clin Pract. 2002;56(2):85-8. [pmid: 11926711].
16 Ferrer M, Esquinas A, Leon M, et al. Noninvasive ventilation in severe hypoxemic respiratory failure: a randomized clinical trial. Am J Respir Crit Care Med. 2003;168(12):1438-44. [pmid: 14500259].
17 Gupta D, Nath A, Agarwal R, et al. A prospective randomized controlled trial on the efficacy of noninvasive ventilation in severe acute asthma. Respir Care. 2010;55(5):536-43. [pmid: 20420722].
18 Hilbert G, Gruson D, Vargas F, et al. Noninvasive ventilation in immunosuppressed patients with pulmonary infiltrates, fever, and acute respiratory failure. N Engl J Med. 2001;344(7):481-7. [pmid: 11172189].
19 Holley MT, Morrissey TK, Seaberg DC, et al. Ethical dilemmas in a randomized trial of asthma treatment: can Bayesian statistical analysis explain the results?. Acad Emerg Med. 2001;8(12):1128-35. [pmid: 11733289].
20 Honrubia T, Garcia Lopez FJ, Franco N, et al. Noninvasive vs conventional mechanical ventilation in acute respiratory failure: a multicenter, randomized controlled trial. Chest. 2005;128(6):3916-24. [pmid: 16354864].
21 Jurjevic M, Matic I, Sakic-Zdravcevic K, et al. Mechanical ventilation in chronic obstructive pulmonary disease patients, noninvasive vs. invasive method (randomized prospective study). Coll Antropol. 2009;33(3):791-7. [pmid: 19860105].
22 Keenan SP, Powers CE, McCormack DG. Noninvasive positive-pressure ventilation in patients with milder chronic obstructive pulmonary disease exacerbations: a randomized controlled trial. Respir Care. 2005;50(5):610-6. [pmid: 15871754].
23 Kelly CA, Newby DE, McDonagh TA, et al. Randomised controlled trial of continuous positive airway pressure and standard oxygen therapy in acute pulmonary oedema; effects on plasma brain natriuretic peptide concentrations. Eur Heart J. 2002;23(17):1379-86. [pmid: 12191749].
24 Khilnani GC, Saikia N, Banga A, et al. Non-invasive ventilation for acute exacerbation of COPD with very high PaCO2: A randomized controlled trial. Lung India. 2010;27(3):125-30. [pmid: 20931029].
25 Kramer N, Meyer TJ, Meharg J, et al. Randomized, prospective trial of noninvasive positive pressure ventilation in acute respiratory failure. Am J Respir Crit Care Med. 1995;151(6):1799-806. [pmid: 7767523].
26 Levitt MA. A prospective, randomized trial of BiPAP in severe acute congestive heart failure. J Emerg Med. 2001;21(4):363-9. [pmid: 11728761].
27 L'Her E, Duquesne F, Girou E, et al. Noninvasive continuous positive airway pressure in elderly cardiogenic pulmonary edema patients. Intensive Care Med. 2004;30(5):882-8. [pmid: 14991092].
28 Lin M, Chiang HT. The efficacy of early continuous positive airway pressure therapy in patients with acute cardiogenic pulmonary edema. J Formos Med Assoc. 1991;90(8):736-43. [pmid: 1683365].
29 Lin M, Yang YF, Chiang HT, et al. Reappraisal of continuous positive airway pressure therapy in acute cardiogenic pulmonary edema. Short-term results and long-term follow-up. Chest. 1995;107(5):1379-86. [pmid: 7750335].
30 Martin TJ, Hovis JD, Costantino JP, et al. A randomized, prospective evaluation of noninvasive ventilation for acute respiratory failure. Am J Respir Crit Care Med. 2000;161(3 Pt 1):807-13. [pmid: 10712326].
31 Masip J, Betbese AJ, Paez J, et al. Non-invasive pressure support ventilation versus conventional oxygen therapy in acute cardiogenic pulmonary oedema: a randomised trial. Lancet. 2000;356(9248):2126-32. [pmid: 11191538].
32 Matic I, Sakic-Zdravcevic K, Jurjevic M. Comparison of invasive and noninvasive mechanical ventilation for patients with chronic obstructive pulmonary disease: Randomized prospective study. Periodicum Biologorum. 2007;109(2):137-45.
33 Nava S, Carbone G, DiBattista N, et al. Noninvasive ventilation in cardiogenic pulmonary edema: a multicenter randomized trial. Am J Respir Crit Care Med. 2003;168(12):1432-7. [pmid: 12958051].
34 Nava S, Grassi M, Fanfulla F, et al. Non-invasive ventilation in elderly patients with acute hypercapnic respiratory failure: a randomised controlled trial. Age Ageing. 2011;40(4):444-50. [pmid: 21345841].
35 Pastaka C, Kostikas K, Karetsi E, et al. Non-invasive ventilation in chronic hypercapnic COPD patients with exacerbation and a pH of 7.35 or higher. Eur J Intern Med. 2007;18(7):524-30. [pmid: 17967333].
36 Plant PK, Owen JL, Elliott MW. Early use of non-invasive ventilation for acute exacerbations of chronic obstructive pulmonary disease on general respiratory wards: a multicentre randomised controlled trial. Lancet. 2000;355(9219):1931-5. [pmid: 10859037].
37 Plant PK, Owen JL, Elliott MW. Non-invasive ventilation in acute exacerbations of chronic obstructive pulmonary disease: long term survival and predictors of in-hospital outcome. Thorax. 2001;56(9):708-12. [pmid: 11514692].
38 Soroksky A, Stav D, Shpirer I. A pilot prospective, randomized, placebo-controlled trial of bilevel positive airway pressure in acute asthmatic attack. Chest. 2003;123(4):1018-25. [pmid: 12684289].
39 Squadrone V, Coha M, Cerutti E, et al. Continuous positive airway pressure for treatment of postoperative hypoxemia: a randomized controlled trial. JAMA. 2005;293(5):589-95. [pmid: 15687314].
40 Takeda S, Takano T, Ogawa R. The effect of nasal continuous positive airway pressure on plasma endothelin-1 concentrations in patients with severe cardiogenic pulmonary edema. Anesth Analg. 1997;84(5):1091-6. [pmid: 9141937].
41 Takeda S, Nejima J, Takano T, et al. Effect of nasal continuous positive airway pressure on pulmonary edema complicating acute myocardial infarction. Jpn Circ J. 1998;62(8):553-8. [pmid: 9741730].
42 Thys F, Roeseler J, Reynaert M, et al. Noninvasive ventilation for acute respiratory failure: a prospective randomised placebo-controlled trial. Eur Respir J. 2002;20(3):545-55. [pmid: 12358327].
43 Wermke M, Schiemanck S, Hoffken G, et al. Respiratory failure in patients undergoing allogeneic hematopoietic SCT—a randomized trial on early non-invasive ventilation based on standard care hematology wards. Bone Marrow Transplant. 2011. [Epub ahead of print]. [pmid: 21927036].
44 Wood KA, Lewis L, Von Harz B, et al. The use of noninvasive positive pressure ventilation in the emergency department: results of a randomized clinical trial. Chest. 1998;113(5):1339-46. [pmid: 9596317].
45 Wysocki M, Tric L, Wolff MA, et al. Noninvasive pressure support ventilation in patients with acute respiratory failure. A randomized comparison with conventional therapy. Chest. 1995;107(3):761-8. [pmid: 7874950].
46 Zhan Q, Sun B, Liang L, et al. Early use of noninvasive positive pressure ventilation for acute lung injury: a multicenter randomized controlled trial. Crit Care Med. 2012;40(2):455-60. [pmid: 22020236].
47 Crane SD, Elliott MW, Gilligan P, et al. Randomised controlled comparison of continuous positive airways pressure, bilevel non-invasive ventilation, and standard treatment in emergency department patients with acute cardiogenic pulmonary oedema. Emerg Med J. 2004;21(2):155-61. [pmid: 14988338].
48 Gray A, Goodacre S, Newby DE, et al. Noninvasive ventilation in acute cardiogenic pulmonary edema. N Engl J Med. 2008;359(2):142-51. [pmid: 18614781].
49 Gray AJ, Goodacre S, Newby DE, et al. A multicentre randomised controlled trial of the use of continuous positive airway pressure and non-invasive positive pressure ventilation in the early treatment of patients presenting to the emergency department with severe acute cardiogenic pulmonary oedema: the 3CPO trial. Health Technol Assess. 2009;13(33):1-106. [pmid: 19615296].
50 Park M, Lorenzi-Filho G, Feltrim MI, et al. Oxygen therapy, continuous positive airway pressure, or noninvasive bilevel positive pressure ventilation in the treatment of acute cardiogenic pulmonary edema. Arq Bras Cardiol. 2001;76(3):221-30. [pmid: 11262572].
51 Park M, Sangean MC, Volpe Mde S, et al. Randomized, prospective trial of oxygen, continuous positive airway pressure, and bilevel positive airway pressure by face mask in acute cardiogenic pulmonary edema. Crit Care Med. 2004;32(12):2407-15. [pmid: 15599144].
52 Bellone A, Monari A, Cortellaro F, et al. Myocardial infarction rate in acute pulmonary edema: noninvasive pressure support ventilation versus continuous positive airway pressure. Crit Care Med. 2004;32(9):1860-5. [pmid: 15343013].
53 Bellone A, Vettorello M, Monari A, et al. Noninvasive pressure support ventilation vs. continuous positive airway pressure in acute hypercapnic pulmonary edema. Intensive Care Med. 2005;31(6):807-11. [pmid: 15871011].
54 Cross AM, Cameron P, Kierce M, et al. Non-invasive ventilation in acute respiratory failure: a randomised comparison of continuous positive airway pressure and bi-level positive airway pressure. Emerg Med J. 2003;20(6):531-4. [pmid: 14623840].
55 Ferrari G, Olliveri F, De Filippi G, et al. Noninvasive positive airway pressure and risk of myocardial infarction in acute cardiogenic pulmonary edema: continuous positive airway pressure vs noninvasive positive pressure ventilation. Chest. 2007;132(6):1804-9. [pmid: 17908705].
56 Ferrari G, Milan A, Groff P, et al. Continuous positive airway pressure vs. pressure support ventilation in acute cardiogenic pulmonary edema: a randomized trial. J Emerg Med. 2010;39(5):676-84. [pmid: 19818574].
57 Mehta S, Jay GD, Woolard RH, et al. Randomized, prospective trial of bilevel versus continuous positive airway pressure in acute pulmonary edema. Crit Care Med. 1997;25(4):620-8. [pmid: 9142026].
58 Moritz F, Brousse B, Gellee B, et al. Continuous positive airway pressure versus bilevel noninvasive ventilation in acute cardiogenic pulmonary edema: a randomized multicenter trial. Ann Emerg Med. 2007;50(6):666-75. 75 e1. [pmid: 17764785].
59 Nouira S, Boukef R, Bouida W, et al. Non-invasive pressure support ventilation and CPAP in cardiogenic pulmonary edema: A multicenter randomized study in the emergency department. Intensive Care Med. 2011;37(2):249-56. [pmid: 21136039].
60 Anonymous. Pulmonary infection control window in treatment of severe respiratory failure of chronic obstructive pulmonary diseases: a prospective, randomized controlled, multi-centred study. Chin Med J (Engl). 2005;118(19):1589-94. [pmid: 16232342].
61 Esteban A, Frutos-Vivar F, Ferguson ND, et al. Noninvasive positive-pressure ventilation for respiratory failure after extubation. N Engl J Med. 2004;350(24):2452-60. [pmid: 15190137].
62 Ferrer M, Esquinas A, Arancibia F, et al. Noninvasive ventilation during persistent weaning failure: a randomized controlled trial. Am J Respir Crit Care Med. 2003;168(1):70-6. [pmid: 12689847].
63 Ferrer M, Valencia M, Nicolas JM, et al. Early noninvasive ventilation averts extubation failure in patients at risk: a randomized trial. Am J Respir Crit Care Med. 2006;173(2):164-70. [pmid: 16224108].
64 Ferrer M, Sellares J, Valencia M, et al. Non-invasive ventilation after extubation in hypercapnic patients with chronic respiratory disorders: randomised controlled trial. Lancet. 2009;374(9695):1082-8. [pmid: 19682735].
65 Girault C, Daudenthun I, Chevron V, et al. Noninvasive ventilation as a systematic extubation and weaning technique in acute-on-chronic respiratory failure: a prospective, randomized controlled study. Am J Respir Crit Care Med. 1999;160(1):86-92. [pmid: 10390384].
66 Girault C, Bubenheim M, Abroug F, et al. Noninvasive ventilation and weaning in patients with chronic hypercapnic respiratory failure: a randomized multicenter trial. Am J Respir Crit Care Med. 2011;184(672-9). [pmid: 21680944].
67 Jiang JS, Kao SJ, Wang SN. Effect of early application of biphasic positive airway pressure on the outcome of extubation in ventilator weaning. Respirology. 1999;4(2):161-5. [pmid: 10382235].
68 Keenan SP, Powers C, McCormack DG, et al. Noninvasive positive-pressure ventilation for postextubation respiratory distress: a randomized controlled trial. JAMA. 2002;287(24):3238-44. [pmid: 12076220].
69 Nava S, Ambrosino N, Clini E, et al. Noninvasive mechanical ventilation in the weaning of patients with respiratory failure due to chronic obstructive pulmonary disease. A randomized, controlled trial. Ann Intern Med. 1998;128(9):721-8. [pmid: 9556465].
70 Nava S, Gregoretti C, Fanfulla F, et al. Noninvasive ventilation to prevent respiratory failure after extubation in high-risk patients. Crit Care Med. 2005;33(11):2465-70. [pmid: 16276167].
71 Su CL, Chiang LL, Yang SH, et al. Preventive use of noninvasive ventilation after extubation: a prospective, multicenter randomized controlled trial. Respir Care. 2012;57(2):204-10. [pmid: 21762554].