# Excluded Studies

All studies listed below were reviewed in their full-text version and excluded. Following each reference, in italics, is the reason for exclusion. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

Agmy G, Metwally M. Noninvasive ventilation in the weaning of patients with acute-on-chronic respiratory failure due to COPD. Chest. 2011;140(4):1032A. Exclude: Does not include intervention/comparators of interest.
Aguilo R, Togores B, Pons S, et al. Noninvasive ventilatory support after lung resectional surgery. Chest. 1997;112(1):117-21. Exclude: Does not include intervention/comparators of interest. [pmid: 9228366].
Agusti AG, Carrera M, Barbe F, et al. Oxygen therapy during exacerbations of chronic obstructive pulmonary disease. Eur Respir J. 1999;14(4):934-9. Exclude: Does not include intervention/comparators of interest. [pmid: 10573245].
Allan PF, Thomas KV, Ward MR, et al. Feasibility study of noninvasive ventilation with helium-oxygen gas flow for chronic obstructive pulmonary disease during exercise. Respir Care. 2009;54(9):1175-82. Exclude: Does not include clinical or utilization-related outcomes of interest. [pmid: 19712493].
Ambrogio C, Lowman X, Kuo M, et al. Sleep and non-invasive ventilation in patients with chronic respiratory insufficiency. Intensive Care Med. 2009;35(2):306-13. Exclude: Does not include a study population of interest. [pmid: 18795255].
Ambrosino N, Nava S, Bertone P, et al. Physiologic evaluation of pressure support ventilation by nasal mask in patients with stable COPD. Chest. 1992;101(2):385-91. Exclude: Does not include clinical or utilization-related outcomes of interest. [pmid: 1735260].
Ambrosino N, Vitacca M, Polese G, et al. Short-term effects of nasal proportional assist ventilation in patients with chronic hypercapnic respiratory insufficiency. Eur Respir J. 1997;10(12):2829-34. Exclude: Does not include clinical or utilization-related outcomes of interest. [pmid: 9493669].
Anderson J, Groth M. Usefulness of noninvasive positive-pressure ventilation in postextubation respiratory distress. Clinical Pulmonary Medicine. 2003;10(2):123-4. Exclude: Not a full publication (abstract only), not original data, not peer-reviewed literature published 1990 to present, or not grey lit meeting specified criteria.
Angus RM, Ahmed AA, Fenwick LJ, et al. Comparison of the acute effects on gas exchange of nasal ventilation and doxapram in exacerbations of chronic obstructive pulmonary disease. Thorax. 1996;51(10):1048-50. Exclude: Does not include clinical or utilization-related outcomes of interest. [pmid: 8977608].
Anjos CFD, Schettino GPP, Park M, et al. A randomized trial of noninvasive positive end expiratory pressure in patients with acquired immune deficiency syndrome and hypoxemic respiratory failure. Respir Care. 2012;57(2):211-20. Exclude: Does not include intervention/comparators of interest. [pmid: 21762561].
Anonymous. Non-invasive ventilation in acute respiratory failure. Thorax. 2002;57(3):192-211. Exclude: Study type is not RCT. [pmid: 11867822].
Anton A, Tarrega J, Giner J, et al. Acute physiologic effects of nasal and full-face masks during noninvasive positive-pressure ventilation in patients with acute exacerbations of chronic obstructive pulmonary disease. Respir Care. 2003;48(10):922-5. Exclude: Does not include intervention/comparators of interest. [pmid: 14525628].
Antonaglia V, Ferluga M, Molino R, et al. Comparison of noninvasive ventilation by sequential use of mask and helmet versus mask in acute exacerbation of chronic obstructive pulmonary disease: a preliminary study. Respiration. 2011;82(2):148-54. Exclude: Does not include intervention/comparators of interest. [pmid: 21447934].
Antonelli M, Conti G, Pelosi P, et al. New treatment of acute hypoxemic respiratory failure: noninvasive pressure support ventilation delivered by helmet—a pilot controlled trial. Crit Care Med. 2002;30(3):602-8. Exclude: Study type is not RCT. [pmid: 11990923].
Arzt M, Floras JS, Logan AG, et al. Suppression of central sleep apnea by continuous positive airway pressure and transplant-free survival in heart failure: a post hoc analysis of the Canadian Continuous Positive Airway Pressure for Patients with Central Sleep Apnea and Heart Failure Trial (CANPAP). Circulation. 2007;115(25):3173-80. Exclude: Does not include a study population of interest. [pmid: 17562959].
Bailey CR, Jones RM, Kelleher AA. The role of continuous positive airway pressure during weaning from mechanical ventilation in cardiac surgical patients. Anaesthesia. 1995;50(8):677-81. Exclude: Does not include intervention/comparators of interest. [pmid: 7645695].
Baillard C, Fosse JP, Sebbane M, et al. Noninvasive ventilation improves preoxygenation before intubation of hypoxic patients. Am J Respir Crit Care Med. 2006;174(2):171-7. Exclude: Does not include clinical or utilization-related outcomes of interest. [pmid: 16627862].
Bardi G, Pierotello R, Desideri M, et al. Nasal ventilation in COPD exacerbations: early and late results of a prospective, controlled study. Eur Respir J. 2000;15(1):98-104. Exclude: Study type is not RCT. [pmid: 10678628].
Baser S, Kiter G, Kavas M, et al. Binasal cannula versus face mask for oxygen therapy in patients with chronic pulmonary disease. Adv Ther. 2006;23(6):1068-74. Exclude: Does not include intervention/comparators of interest. [pmid: 17276974].
Battisti A, Tassaux D, Bassin D, et al. Automatic adjustment of noninvasive pressure support with a bilevel home ventilator in patients with acute respiratory failure: a feasibility study. Intensive Care Med. 2007;33(4):632-8. Exclude: Does not include clinical or utilization-related outcomes of interest. [pmid: 17323049].
Beecroft JM, Hanly PJ. Comparison of the OxyMask and Venturi mask in the delivery of supplemental oxygen: pilot study in oxygen-dependent patients. Can Respir J. 2006;13(5):247-52. Exclude: Does not include intervention/comparators of interest. [pmid: 16896425].
Bell D, Riordan JF, McNicol MW, et al. Non-invasive mechanical ventilation for acute respiratory failure. BMJ. 1990;300(6729):944. Exclude: Not a full publication (abstract only), not original data, not peer-reviewed literature published 1990 to present, or not grey lit meeting specified criteria. [pmid: 2337729].
Bianchi L, Foglio K, Pagani M, et al. Effects of proportional assist ventilation on exercise tolerance in COPD patients with chronic hypercapnia. Eur Respir J. 1998;11(2):422-7. Exclude: Does not include clinical or utilization-related outcomes of interest. [pmid: 9551748].
Bolton J, Russell WJ. Are nasal spectacles adequate for supplementary oxygen in patients after anaesthesia?. Int J Nurs Pract. 2001;7(5):329-35. Exclude: Does not include intervention/comparators of interest. [pmid: 11811431].
Borel JC, Tamisier R, Gonzalez-Bermejo J, et al. Noninvasive ventilation in mild obesity hypoventilation syndrome: a randomized controlled trial. Chest. 2012;141(3):692-702. Exclude: Does not include a study population of interest. [pmid: 21885724].
Bourke SC, Bullock RE, Williams TL, et al. Noninvasive ventilation in ALS: indications and effect on quality of life. Neurology. 2003;61(2):171-7. Exclude: Does not include a study population of interest. [pmid: 12874394].
Bourke SC, Tomlinson M, Williams TL, et al. Effects of non-invasive ventilation on survival and quality of life in patients with amyotrophic lateral sclerosis: a randomised controlled trial. Lancet Neurol. 2006;5(2):140-7. Exclude: Does not include a study population of interest. [pmid: 16426990].
Brandao DC, Lima VM, Filho VG, et al. Reversal of bronchial obstruction with bi-level positive airway pressure and nebulization in patients with acute asthma. J Asthma. 2009;46(4):356-61. Exclude: Does not include clinical or utilization-related outcomes of interest. [pmid: 19484669].
Cammarota G, Olivieri C, Costa R, et al. Noninvasive ventilation through a helmet in postextubation hypoxemic patients: physiologic comparison between neurally adjusted ventilatory assist and pressure support ventilation. Intensive Care Med. 2011;37(12):1943-50. Exclude: Does not include intervention/comparators of interest. [pmid: 22005826].
Caron D, Sorba V, Kerrouche N, et al. Split-face comparison of adapalene 0.1% gel and tretinoin 0.025% gel in acne patients. J Am Acad Dermatol. 1997;36(6 Pt 2):S110-2. Exclude: Does not include a study population of interest. [pmid: 9204087].
Casanova C, Celli BR, Tost L, et al. Long-term controlled trial of nocturnal nasal positive pressure ventilation in patients with severe COPD. Chest. 2000;118(6):1582-90. Exclude: Not conducted in a hospital or ED setting. [pmid: 11115443].
Celebi S, Koner O, Menda F, et al. Pulmonary effects of noninvasive ventilation combined with the recruitment maneuver after cardiac surgery. Anesth Analg. 2008;107(2):614-9. Exclude: Does not include a study population of interest. [pmid: 18633041].
Chadda K, Annane D, Hart N, et al. Cardiac and respiratory effects of continuous positive airway pressure and noninvasive ventilation in acute cardiac pulmonary edema. Crit Care Med. 2002;30(11):2457-61. Exclude: Does not include clinical or utilization-related outcomes of interest. [pmid: 12441754].
Chen J, Qiu D, Tao D. Time for extubation and sequential noninvasive mechanical ventilation in COPD patients with exacerbated respiratory failure who received invasive ventilation. Zhonghua Jie He He Hu Xi Za Zhi. 2001;24(2):99-100. Exclude: Not in English. [pmid: 11802949].
Chermont S, Quintao MM, Mesquita ET, et al. Noninvasive ventilation with continuous positive airway pressure acutely improves 6-minute walk distance in chronic heart failure. J Cardiopulm Rehabil Prev. 2009;29(1):44-8. Exclude: Does not include a study population of interest. [pmid: 19158587].
Cheung AP, Chan VL, Liong JT, et al. A pilot trial of non-invasive home ventilation after acidotic respiratory failure in chronic obstructive pulmonary disease. Int J Tuberc Lung Dis. 2010;14(5):642-9. Exclude: Not conducted in a hospital or ED setting. [pmid: 20392360].
Chidini G, Piastra M, Wolfler A, et al. Noninvasive continuous positive airway pressure (NCPAP) by helmet versus facial mask: a multicenter RCT. Intensive Care Med. Suppl 2. 2011;37:S331-S2. Exclude: Not a full publication (abstract only), not original data, not peer-reviewed literature published 1990 to present, or not grey lit meeting specified criteria.
Coimbra VR, Lara Rde A, Flores EG, et al. Application of noninvasive ventilation in acute respiratory failure after cardiovascular surgery. Arq Bras Cardiol. 2007;89(5):270-6. 98. 305. Exclude: Does not include clinical or utilization-related outcomes of interest. [pmid: 18066449].
Confalonieri M, Calderini E, Terraciano S, et al. Noninvasive ventilation for treating acute respiratory failure in AIDS patients with Pneumocystis carinii pneumonia. Intensive Care Med. 2002;28(9):1233-8. Exclude: Study type is not RCT. [pmid: 12209270].
Conti G, Costa R. Noninvasive ventilation in patients with hypoxemic, nonhypercapnic acute respiratory failure. Clinical Pulmonary Medicine. 2011;18(2):83-7. Exclude: Study type is not RCT.
Corrado A, Gorini M, Melej R, et al. Iron lung versus mask ventilation in acute exacerbation of COPD: a randomised crossover study. Intensive Care Med. 2009;35(4):648-55. Exclude: Does not include intervention/comparators of interest. [pmid: 19020859].
Cosentini R, Brambilla AM, Aliberti S, et al. Helmet continuous positive airway pressure vs oxygen therapy to improve oxygenation in community-acquired pneumonia: a randomized, controlled trial. Chest. 2010;138(1):114-20. Exclude: Does not include clinical or utilization-related outcomes of interest. [pmid: 20154071].
Craven RA, Singletary N, Bosken L, et al. Use of bilevel positive airway pressure in out-of-hospital patients. Acad Emerg Med. 2000;7(9):1065-8. Exclude: Not conducted in a hospital or ED setting. [pmid: 11044006].
Cuvelier A, Pujol W, Pramil S, et al. Cephalic versus oronasal mask for noninvasive ventilation in acute hypercapnic respiratory failure. Intensive Care Med. 2009;35(3):519-26. Exclude: Does not include intervention/comparators of interest. [pmid: 18854973].
Cydulka RK. Noninvasive ventilation in cardiogenic pulmonary edema: a multicenter randomized trial. Ann Emerg Med. 2005;45(2):227-8. Exclude: Not a full publication (abstract only), not original data, not peer-reviewed literature published 1990 to present, or not grey lit meeting specified criteria.
De Backer L, Vos W, Dieriks B, et al. The effects of long-term noninvasive ventilation in hypercapnic COPD patients: a randomized controlled pilot study. Int J Chron Obstruct Pulmon Dis. 2011;6:615-24. Exclude: Does not include a study population of interest. [pmid: 22135493].
Delay JM, Sebbane M, Jung B, et al. The effectiveness of noninvasive positive pressure ventilation to enhance preoxygenation in morbidly obese patients: a randomized controlled study. Anesth Analg. 2008;107(5):1707-13. Exclude: Does not include a study population of interest. [pmid: 18931236].
Drummond GB, Stedul K, Kingshott R, et al. Automatic CPAP compared with conventional treatment for episodic hypoxemia and sleep disturbance after major abdominal surgery. Anesthesiology. 2002;96(4):817-26. Exclude: Does not include a study population of interest. [pmid: 11964587].
Ducros L, Logeart D, Vicaut E, et al. CPAP for acute cardiogenic pulmonary oedema from out-of-hospital to cardiac intensive care unit: a randomised multicentre study. Intensive Care Med. 2011;37(9):1501-9. Exclude: Does not include a study population of interest. [pmid: 21805159].
Elrazek EA. Randomized prospective crossover study of biphasic intermittent positive airway pressure ventilation (BIPAP) versus pressure support ventilation (PSV) in surgical intensive care patients. Middle East J Anesthesiol. 2004;17(6):1009-21. Exclude: Does not include intervention/comparators of interest. [pmid: 15651509].
Esen F, Denkel T, Telci L, et al. Comparison of pressure support ventilation (PSV) and intermittent mandatory ventilation (IMV) during weaning in patients with acute respiratory failure. Adv Exp Med Biol. 1992;317:371-6. Exclude: Does not include intervention/comparators of interest. [pmid: 1288147].
Fagevik Olsen M, Wennberg E, Johnsson E, et al. Randomized clinical study of the prevention of pulmonary complications after thoracoabdominal resection by two different breathing techniques. Br J Surg. 2002;89(10):1228-34. Exclude: Does not include a study population of interest. [pmid: 12296888].
Fontanella B, Affatato A, Bianchetti F, et al. Randomized, prospective comparison of continuous positive airway pressure (CPAP) versus bilevel non invasive pressure support ventilation (NIPSV) in acute cardiogenic pulmonary edema. Eur J Heart Fail, Supplement. 2009;8:ii399. Exclude: Not a full publication (abstract only), not original data, not peer-reviewed literature published 1990 to present, or not grey lit meeting specified criteria.
Foster R, Scales DC. Can CPAP prevent the need for endotracheal intubation in patients with hypoxemia after abdominal surgery?. Can Med Assoc J. 2005;172(6):744. Exclude: Not a full publication (abstract only), not original data, not peer-reviewed literature published 1990 to present, or not grey lit meeting specified criteria. [pmid: 15772998].
Gaszynski T, Tokarz A, Piotrowski D, et al. Boussignac CPAP in the postoperative period in morbidly obese patients. Obes Surg. 2007;17(4):452-6. Exclude: Does not include intervention/comparators of interest. [pmid: 17608255].
Gay PC, Hess DR, Hill NS. Noninvasive proportional assist ventilation for acute respiratory insufficiency. Comparison with pressure support ventilation. Am J Respir Crit Care Med. 2001;164(9):1606-11. Exclude: Does not include intervention/comparators of interest. [pmid: 11719297].
Girault C, Briel A, Benichou J, et al. Interface strategy during noninvasive positive pressure ventilation for hypercapnic acute respiratory failure. Crit Care Med. 2009;37(1):124-31. Exclude: Does not include intervention/comparators of interest. [pmid: 19050635].
Girault C, Chajara A, Dachraoui F, et al. VENISE: Non-invasive ventilation during mechanical ventilation weaning in chronic respiratory failure patients. A prospective randomised controlled and multicenter trial. Rev Mal Respir. 2003;20(6 Pt 1):940-5. Exclude: Not in English. [pmid: 14743096].
Girault C, Chevron V, Richard JC, et al. Physiological effects and optimisation of nasal assist-control ventilation for patients with chronic obstructive pulmonary disease in respiratory failure. Thorax. 1997;52(8):690-6. Exclude: Does not include clinical or utilization-related outcomes of interest. [pmid: 9337827].
Girault C, Richard JC, Chevron V, et al. Comparative physiologic effects of noninvasive assist-control and pressure support ventilation in acute hypercapnic respiratory failure. Chest. 1997;111(6):1639-48. Exclude: Does not include clinical or utilization-related outcomes of interest. [pmid: 9187187].
Gregoretti C, Confalonieri M, Navalesi P, et al. Evaluation of patient skin breakdown and comfort with a new face mask for non-invasive ventilation: a multi-center study. Intensive Care Med. 2002;28(3):278-84. Exclude: Does not include intervention/comparators of interest. [pmid: 11904656].
Guarracino F, Ambrosino N. Non invasive ventilation in cardio-surgical patients. Minerva Anestesiol. 2011;77(7):734-41. Exclude: Study type is not RCT. [pmid: 21709660].
Hao CX, Luo XR, Liu YM. Treatment of severe cardiogenic pulmonary edema with continuous positive airway pressure by basal face mask. Acta Academiae Medicinae Jiangxi. 2002;5:48-50. Exclude: Not in English.
Hawker F, Breen D, Torzillo P, et al. Randomized prospective trial of noninvasive positive pressure ventilation in acute respiratory failure. Am J Respir Crit Care Med. 1996;153(3):1188-9. Exclude: Not a full publication (abstract only), not original data, not peer-reviewed literature published 1990 to present, or not grey lit meeting specified criteria. [pmid: 8630567].
Jolliet P, Tassaux D, Roeseler J, et al. Helium-oxygen versus air-oxygen noninvasive pressure support in decompensated chronic obstructive disease: a prospective, multicenter study. Crit Care Med. 2003;31(3):878-84. Exclude: Does not include intervention/comparators of interest. [pmid: 12627000].
Jolliet P, Tassaux D, Thouret JM, et al. Beneficial effects of helium:oxygen versus air:oxygen noninvasive pressure support in patients with decompensated chronic obstructive pulmonary disease. Crit Care Med. 1999;27(11):2422-9. Exclude: Does not include intervention/comparators of interest. [pmid: 10579259].
Joris JL, Sottiaux TM, Chiche JD, et al. Effect of bi-level positive airway pressure (BiPAP) nasal ventilation on the postoperative pulmonary restrictive syndrome in obese patients undergoing gastroplasty. Chest. 1997;111(3):665-70. Exclude: Does not include clinical or utilization-related outcomes of interest. [pmid: 9118706].
Jousela I, Rasanen J, Verkkala K, et al. Continuous positive airway pressure by mask in patients after coronary surgery. Acta Anaesthesiol Scand. 1994;38(4):311-6. Exclude: Does not include clinical or utilization-related outcomes of interest. [pmid: 8067215].
Kazmaier S, Rathgeber J, Buhre W, et al. Comparison of ventilatory and haemodynamic effects of BIPAP and S-IMV/PSV for postoperative short-term ventilation in patients after coronary artery bypass grafting. Eur J Anaesthesiol. 2000;17(10):601-10. Exclude: Does not include a study population of interest. [pmid: 11050517].
Keenan SP. Noninvasive positive pressure ventilation in acute respiratory failure. JAMA. 2000;284(18):2376-8. Exclude: Not a full publication (abstract only), not original data, not peer-reviewed literature published 1990 to present, or not grey lit meeting specified criteria. [pmid: 11066190].
Khayat RN, Abraham WT, Patt B, et al. In-hospital treatment of obstructive sleep apnea during decompensation of heart failure. Chest. 2009;136(4):991-7. Exclude: Does not include a study population of interest. [pmid: 19567491].
Khayat RN, Abraham WT, Patt B, et al. Cardiac effects of continuous and bilevel positive airway pressure for patients with heart failure and obstructive sleep apnea: a pilot study. Chest. 2008;134(6):1162-8. Exclude: Does not include a study population of interest. [pmid: 18641111].
Kindgen-Milles D, Muller E, Buhl R, et al. Nasal-continuous positive airway pressure reduces pulmonary morbidity and length of hospital stay following thoracoabdominal aortic surgery. Chest. 2005;128(2):821-8. Exclude: Does not include a study population of interest. [pmid: 16100174].
Kirakli C, Cerci T, Ucar ZZ, et al. Noninvasive assisted pressure-controlled ventilation: as effective as pressure support ventilation in chronic obstructive pulmonary disease?. Respiration. 2008;75(4):402-10. Exclude: Does not include clinical or utilization-related outcomes of interest. [pmid: 17627100].
Kohler M, Ayers L, Pepperell JC, et al. Effects of continuous positive airway pressure on systemic inflammation in patients with moderate to severe obstructive sleep apnoea: a randomised controlled trial. Thorax. 2009;64(1):67-73. Exclude: Does not include a study population of interest. [pmid: 18786982].
Kohler M, Pepperell JC, Davies RJ, et al. Continuous positive airway pressure and liver enzymes in obstructive sleep apnoea: data from a randomized controlled trial. Respiration. 2009;78(2):141-6. Exclude: Does not include a study population of interest. [pmid: 18984944].
Krachman SL, D'Alonzo GE, Berger TJ, et al. Comparison of oxygen therapy with nasal continuous positive airway pressure on Cheyne-Stokes respiration during sleep in congestive heart failure. Chest. 1999;116(6):1550-7. Exclude: Does not include a study population of interest. [pmid: 10593775].
Krachman SL, Quaranta AJ, Berger TJ, et al. Effects of noninvasive positive pressure ventilation on gas exchange and sleep in COPD patients. Chest. 1997;112(3):623-8. Exclude: Does not include a study population of interest. [pmid: 9315793].
Kwok H, McCormack J, Cece R, et al. Controlled trial of oronasal versus nasal mask ventilation in the treatment of acute respiratory failure. Crit Care Med. 2003;31(2):468-73. Exclude: Does not include intervention/comparators of interest. [pmid: 12576953].
Leman P, Greene S, Whelan K, et al. Simple lightweight disposable continuous positive airways pressure mask to effectively treat acute pulmonary oedema: randomized controlled trial. Emerg Med Australas. 2005;17(3):224-30. Exclude: Does not include intervention/comparators of interest. [pmid: 15953223].
Li J, Zhang DH, Huang XF, et al. Comparison of healing effect of noninvasive positive pressure ventilation and invasive positive pressure ventilation in patients of acute respiratory failure. Chinese Journal of Critical Care Medicine. 2003;8:528-30. Exclude: Not in English.
Li XK, Zhao WH. The treatment of acute cardiogenic pulmonary edema with noninvasive positive pressure ventilation. Chongqing Medical Journal. 2004;4:575-6. Exclude: Not in English.
Liao XQ, Li Q, Lin KX. Non-invasive positive pressure ventilation for early treatment of respiratory failure due to exacerbation of chronic obstructive pulmonary disease: A random controlled trial. Acta Academic Medicine Militaris Tertiae. 2004;8:739-41. Exclude: Not in English.
Liesching TN, Cromier K, Nelson D, et al. Bilevel noninvasive ventilation vs continuous positive airway pressure to treat acute pulmonary edema. Am J Respir Crit Care Med. Suppl 7. 2003:27. Exclude: Not a full publication (abstract only), not original data, not peer-reviewed literature published 1990 to present, or not grey lit meeting specified criteria. [pmid: 14500258].
Lindner KH, Lotz P, Ahnefeld FW. Continuous positive airway pressure effect on functional residual capacity, vital capacity and its subdivisions. Chest. 1987;92(1):66-70. Exclude: Does not include a study population of interest. [pmid: 3297521].
Loeckinger A, Kleinsasser A, Lindner KH, et al. Continuous positive airway pressure at 10 cm H(2)O during cardiopulmonary bypass improves postoperative gas exchange. Anesth Analg. 2000;91(3):522-7. Exclude: Does not include a study population of interest. [pmid: 10960369].
Lopes CR, Brandao CM, Nozawa E, et al. Benefits of non-invasive ventilation after extubation in the postoperative period of heart surgery. Rev Bras Cir Cardiovasc. 2008;23(3):344-50. Exclude: Does not include a study population of interest. [pmid: 19082322].
Malbouisson LM, de Souza EL, Barbalho L, et al. Assessing the impact of lung hyperinflation maneuver on systemic inflammatory response and lung collapse in patients undergoing surgeries under spontaneous ventilation. Rev Bras Anestesiol. 2010;60(3):247-58. Exclude: Does not include a study population of interest. [pmid: 20682157].
Mansfield DR, Gollogly NC, Kaye DM, et al. Controlled trial of continuous positive airway pressure in obstructive sleep apnea and heart failure. Am J Respir Crit Care Med. 2004;169(3):361-6. Exclude: Does not include a study population of interest. [pmid: 14597482].
Marvisi M, Brianti M, Marani G, et al. Acute antiarrhythmic effects of bi-level positive airway pressure ventilation in patients with acute respiratory failure caused by chronic obstructive pulmonary disease: a randomized clinical trial. Respiration. 2004;71(2):152-8. Exclude: Does not include clinical or utilization-related outcomes of interest. [pmid: 15031570].
Matic I, Pavicic F, Sakic-Zdravcevic K, et al. Pulmonary compliance values provide prognosis in mechanically ventilated patients—a randomized prospective study. Coll Antropol. 2007;31(3):829-36. Exclude: Does not include intervention/comparators of interest. [pmid: 18041396].
Matic I, Titlic M, Dikanovic M, et al. Effects of APACHE II score on mechanical ventilation; prediction and outcome. Acta Anaesthesiol Belg. 2007;58(3):177-83. Exclude: Does not include intervention/comparators of interest. [pmid: 18018838].
Matte P, Jacquet L, Van Dyck M, et al. Effects of conventional physiotherapy, continuous positive airway pressure and non-invasive ventilatory support with bilevel positive airway pressure after coronary artery bypass grafting. Acta Anaesthesiol Scand. 2000;44(1):75-81. Exclude: Does not include a study population of interest. [pmid: 10669276].
McEvoy RD, Pierce RJ, Hillman D, et al. Nocturnal non-invasive nasal ventilation in stable hypercapnic COPD: a randomised controlled trial. Thorax. 2009;64(7):561-6. Exclude: Does not include a study population of interest. [pmid: 19213769].
Meduri GU, Cook TR, Turner RE, et al. Noninvasive positive pressure ventilation in status asthmaticus. Chest. 1996;110(3):767-74. Exclude: Study type is not RCT. [pmid: 8797425].
Moritz F, Benichou J, Vanheste M, et al. Boussignac continuous positive airway pressure device in the emergency care of acute cardiogenic pulmonary oedema: a randomized pilot study. Eur J Emerg Med. 2003;10(3):204-8. Exclude: Does not include clinical or utilization-related outcomes of interest. [pmid: 12972896].
Murphy M, Scanlon A. A randomised controlled study suggesting equivalence between full face vs. nasal high flow oxygen delivery on health outcomes. Aust Crit Care. 2011;24(2):139-41. Exclude: Not a full publication (abstract only), not original data, not peer-reviewed literature published 1990 to present, or not grey lit meeting specified criteria. [pmid: 21376624].
Naughton MT, Liu PP, Bernard DC, et al. Treatment of congestive heart failure and Cheyne-Stokes respiration during sleep by continuous positive airway pressure. Am J Respir Crit Care Med. 1995;151(1):92-7. Exclude: Does not include a study population of interest. [pmid: 7812579].
Navalesi P, Costa R, Ceriana P, et al. Non-invasive ventilation in chronic obstructive pulmonary disease patients: helmet versus facial mask. Intensive Care Med. 2007;33(1):74-81. Exclude: Does not include intervention/comparators of interest. [pmid: 17039354].
Navalesi P, Fanfulla F, Frigerio P, et al. Physiologic evaluation of noninvasive mechanical ventilation delivered with three types of masks in patients with chronic hypercapnic respiratory failure. Crit Care Med. 2000;28(6):1785-90. Exclude: Does not include intervention/comparators of interest. [pmid: 10890620].
Neligan PJ, Malhotra G, Fraser M, et al. Continuous positive airway pressure via the Boussignac system immediately after extubation improves lung function in morbidly obese patients with obstructive sleep apnea undergoing laparoscopic bariatric surgery. Anesthesiology. 2009;110(4):878-84. Exclude: Does not include a study population of interest. [pmid: 19293693].
Neligan PJ, Malhotra G, Fraser M, et al. Noninvasive ventilation immediately after extubation improves lung function in morbidly obese patients with obstructive sleep apnea undergoing laparoscopic bariatric surgery. Anesth Analg. 2010;110(5):1360-5. Exclude: Does not include a study population of interest. [pmid: 20418299].
Norman D, Loredo JS, Nelesen RA, et al. Effects of continuous positive airway pressure versus supplemental oxygen on 24-hour ambulatory blood pressure. Hypertension. 2006;47(5):840-5. Exclude: Does not include a study population of interest. [pmid: 16585412].
Pasquina P, Merlani P, Granier JM, et al. Continuous positive airway pressure versus noninvasive pressure support ventilation to treat atelectasis after cardiac surgery. Anesth Analg. 2004;99(4):1001-8. Exclude: Does not include a study population of interest. [pmid: 15385340].
Patel RG, Petrini MF. Respiratory muscle performance, pulmonary mechanics, and gas exchange between the BiPAP S/T-D system and the Servo Ventilator 900C with bilevel positive airway pressure ventilation following gradual pressure support weaning. Chest. 1998;114(5):1390-6. Exclude: Does not include clinical or utilization-related outcomes of interest. [pmid: 9824020].
Perrin C, Jullien V, Venissac N, et al. Prophylactic use of noninvasive ventilation in patients undergoing lung resectional surgery. Respir Med. 2007;101(7):1572-8. Exclude: Does not include a study population of interest. [pmid: 17257820].
Pessoa KC, Araujo GF, Pinheiro AN, et al. Noninvasive ventilation in the immediate postoperative of gastrojejunal derivation with Roux-en-Y gastric bypass. Rev Bras Fisioter. 2010;14(4):290-5. Exclude: Does not include a study population of interest. [pmid: 20949229].
Pinilla JC, Oleniuk FH, Tan L, et al. Use of a nasal continuous positive airway pressure mask in the treatment of postoperative atelectasis in aortocoronary bypass surgery. Crit Care Med. 1990;18(8):836-40. Exclude: Does not include a study population of interest. [pmid: 2199148].
Plaisance P, Pirracchio R, Berton C, et al. A randomized study of out-of-hospital continuous positive airway pressure for acute cardiogenic pulmonary oedema: physiological and clinical effects. Eur Heart J. 2007;28(23):2895-901. Exclude: Does not include intervention/comparators of interest. [pmid: 17967821].
Rasanen J, Heikkila J, Downs J, et al. Continuous positive airway pressure by face mask in acute cardiogenic pulmonary edema. Am J Cardiol. 1985;55(4):296-300. Exclude: Not a full publication (abstract only), not original data, not peer-reviewed literature published 1990 to present, or not grey lit meeting specified criteria. [pmid: 3881920].
Rathgeber J, Schorn B, Falk V, et al. The influence of controlled mandatory ventilation (CMV), intermittent mandatory ventilation (IMV) and biphasic intermittent positive airway pressure (BIPAP) on duration of intubation and consumption of analgesics and sedatives. A prospective analysis in 596 patients following adult cardiac surgery. Eur J Anaesthesiol. 1997;14(6):576-82. Exclude: Does not include a study population of interest. [pmid: 9466092].
Reissmann HK, Ranieri VM, Goldberg P, et al. Continuous positive airway pressure facilitates spontaneous breathing in weaning chronic obstructive pulmonary disease patients by improving breathing pattern and gas exchange. Intensive Care Med. 2000;26(12):1764-72. Exclude: Does not include clinical or utilization-related outcomes of interest. [pmid: 11271083].
Riley RW, Powell NB, Guilleminault C, et al. Obstructive sleep apnea surgery: risk management and complications. Otolaryngol Head Neck Surg. 1997;117(6):648-52. Exclude: Does not include a study population of interest. [pmid: 9419093].
Rudkowski JC. Noninvasive ventilation after extubation reduced respiratory failure and 90-day mortality in hypercapnic patients. Ann Intern Med. 2010;152(4):JC2-4. Exclude: Not a full publication (abstract only), not original data, not peer-reviewed literature published 1990 to present, or not grey lit meeting specified criteria.
Rusterholtz T, Bollaert PE, Feissel M, et al. Continuous positive airway pressure vs. proportional assist ventilation for noninvasive ventilation in acute cardiogenic pulmonary edema. Intensive Care Med. 2008;34(5):840-6. Exclude: Does not include intervention/comparators of interest. [pmid: 18214425].
Sassoon CS, Light RW, Lodia R, et al. Pressure-time product during continuous positive airway pressure, pressure support ventilation, and T-piece during weaning from mechanical ventilation. Am Rev Respir Dis. 1991;143(3):469-75. Exclude: Does not include a study population of interest. [pmid: 2001053].
Soma T, Hino M, Kida K, et al. A prospective and randomized study for improvement of acute asthma by non-invasive positive pressure ventilation (NPPV). Intern Med. 2008;47(6):493-501. Exclude: Does not include clinical or utilization-related outcomes of interest. [pmid: 18344635].
Spiegler P. Noninvasive ventilation after extubation revisited. Clinical Pulmonary Medicine. 2010;17(1):50. Exclude: Not a full publication (abstract only), not original data, not peer-reviewed literature published 1990 to present, or not grey lit meeting specified criteria.
Squadrone V, Massaia M, Bruno B, et al. Early CPAP prevents evolution of acute lung injury in patients with hematologic malignancy. Intensive Care Med. 2010;36(10):1666-74. Exclude: Does not include a study population of interest. [pmid: 20533022].
Stock MC, Downs JB, Gauer PK, et al. Prevention of postoperative pulmonary complications with CPAP, incentive spirometry, and conservative therapy. Chest. 1985;87(2):151-7. Exclude: Does not include a study population of interest. [pmid: 3881226].
Strickland JH Jr, Hasson JH. A computer-controlled ventilator weaning system. A clinical trial. Chest. 1993;103(4):1220-6. Exclude: Does not include intervention/comparators of interest. [pmid: 8131469].
Sutherasan Y, Kiatboonsri S, Kiatboonsri C, et al. The impact of continuous positive airway pressure on the treatment of acute exacerbation of asthma: randomised controlled trial of efficacy. Respirology. Suppl 2. 2011;16:197-8. Exclude: Not a full publication (abstract only), not original data, not peer-reviewed literature published 1990 to present, or not grey lit meeting specified criteria.
Sutton PJ, Perkins CL, Giles SP, et al. Randomised controlled cross-over comparison of continuous positive airway pressure through the Hamilton Galileo ventilator with a Drager CF 800 device. Anaesthesia. 2005;60(1):72-6. Exclude: Does not include intervention/comparators of interest. [pmid: 15601276].
Takami Y, Ina H. Beneficial effects of bilevel positive airway pressure after surgery under cardiopulmonary bypass. Interactive Cardiovascular and Thoracic Surgery. 2003;2(2):156-9. Exclude: Study type is not RCT. [pmid: 17670016].
Wang H, Xu T, Yu X. Clinical observation of continuous positive airway pressure and bi-level positive airway pressure in treatment of acute cardiogenic pulmonary edema. Journal of Internal Intensive Medicine. 2003;9(3):141-4. PMID:. Exclude: Not in English.
Wang X, Due X, Zhang W. Observation of the effect and the time for extubation and sequential noninvasive mechanical ventilation in COPD patients with exacerbated respiratory failure who received invasive ventilation. Shandong Med J. 2004;44(7):4-6. Exclude: Not in English.
Wysocki M, Richard JC, Meshaka P. Noninvasive proportional assist ventilation compared with noninvasive pressure support ventilation in hypercapnic acute respiratory failure. Crit Care Med. 2002;30(2):323-9. Exclude: Does not include intervention/comparators of interest. [pmid: 11889302].
Ye F, Chang Y, Duan B, et al. Application of bi-level noninvasive ventilation in treatment of aged acute cardiogenic pulmonary edema. Practical Geriatrics. 2004;18:300-2. Exclude: Not in English.
Yokoyama T, Tsushima K, Yamamoto H, et al. Potential benefits of early continuous positive pressure ventilation in patients with rapidly progressive interstitial pneumonia. Respirology. 2012;17(2):315-21. Exclude: Study type is not RCT. [pmid: 21883678].
Zarbock A, Mueller E, Netzer S, et al. Prophylactic nasal continuous positive airway pressure following cardiac surgery protects from postoperative pulmonary complications: a prospective, randomized, controlled trial in 500 patients. Chest. 2009;135(5):1252-9. Exclude: Does not include a study population of interest. [pmid: 19017864].
Zhan Q, Sun B, Wang C. Early use of noninvasive positive pressure ventilation for acute lung injury: A multicenter randomized controlled trial. Chest. 2011;140(4):2011-10. Exclude: Not a full publication (abstract only), not original data, not peer-reviewed literature published 1990 to present, or not grey lit meeting specified criteria.
Zhang D, Liu Y. Treatment of acute pulmonary edema with non invasive positive pressure ventilation. International Journal of Respiration. 2005;25(12):910-1. Exclude: Not in English.
Zhang X, Wang X, Ding C. The comparison between the continual positive airway pressure ventilation in treating acute cardiogenic pulmonary edema. Chinese General Practice. 2005;16:1345-7. Exclude: Not in English.
Zheng R, Liu L, Yang Y, et al. Prospective randomized controlled clinical study of sequential non-invasive following invasive mechanical ventilation in patients with acute respiratory failure induced by COPD. Chin J Emerg Med. 2005;14(1):21-5. Exclude: Not in English.