# Analyses of Potential Publication Bias

Testing for publication bias is difficult at best. In effect, one is testing for the number of studies that have not been reported based on the results of those that have been reported. For comparisons with at least 10 studies, we used three tools to look for bias: (1) the funnel plot, which looks for an uneven number of studies falling to the left or right of the funnel; (2) Begg and Mazumdar's test1 based on the rank correlation between the observed effect sizes and observed standard errors; and (3) Egger's regression intercept, which is similar to Begg and Mazumdar's but uses actual values instead of ranks. For Begg and Egger's test statistics, we report two-sided p-values. When the funnel plot or test statistics suggested publication bias, we used Duval and Tweedie's trim-and-fill method to estimate an effect, corrected for publication bias.2

We used Comprehensive Meta-Analysis (Version 2; Biotstat, Englewood, NJ) to test for potential publication bias for the outcomes described below.

## Key Question 1

### Mortality Outcomes

We used Comprehensive Meta-Analysis to examine any potential publication bias in the studies of mortality outcomes. The resulting funnel plot is shown in Figure D-1.

Figure D-1 Funnel plot for studies of mortality outcomes

This figure plots the treatment effects, expressed as the log odds ratio versus the the standard error, for each of the 39 studies. The plot does not suggest publication bias.

The funnel plot does not suggest significant publication bias: Begg's test statistic, p = 0.80; Eggers test statistic, p = 0.03.

### Intubation Rate Outcomes

We used Comprehensive Meta-Analysis to examine any potential publication bias in the studies of intubation rate outcomes. The resulting funnel plot is shown in Figure D-2.

Figure D-2 Funnel plot for studies of intubation rate outcomes

This figure plots the treatment effects, expressed as the log odds ratio versus the the standard error, for each of the 39 studies. The plot suggests possible publication bias.

The funnel plots suggest possible publication bias, with expected studies missing to the right of the summary effect. Funnel plot assymetry may have other causes, including true heterogeneity and chance. Begg's test statistic, p = 0.16; Egger's test statistic, p = 0.02. Trim-and-fill adjusted estimate OR = 0.45 (95% CI, 0.33 to 0.61).

## Key Question 2

### Mortality Outcomes

We used Comprehensive Meta-Analysis to examine any potential publication bias in the studies of mortality outcomes. The resulting funnel plot is shown in Figure D-3.

Figure D-3 Funnel plot for studies of mortality outcomes

This figure plots the treatment effects, expressed as the log odds ratio versus the the standard error, for each of the 10 studies. The plot does not suggest publication bias.

The funnel plot does not suggest publication bias: Begg's test statistic, p = 0.42; Egger's test statistic, p = 0.64.

### Intubation Rate Outcomes

We used Comprehensive Meta-Analysis to examine any potential publication bias in the studies of intubation rate outcomes. The resulting funnel plot is shown in Figure D-4.

Figure D-4 Funnel plot for studies of intubation rate outcomes

This figure plots the treatment effects, expressed as the log odds ratio versus the the standard error, for each of the 12 studies. The plot does not suggest publication bias.

The funnel plot does not suggest publication bias: Begg's test statistic, p = 0.84; Egger's test statistic, p = 0.80.

## Key Question 3

No funnel plots or test statistics were performed because no set of comparisons had at least 10 studies.

## References

1 Begg CB, Mazumdar M. Operating characteristics of a rank correlation test for publication bias. Biometrics. 1994;50(4):1088-101. [pmid: 7786990].
2 Duval S, Tweedie R. Trim and fill: A simple funnel-plot-based method of testing and adjusting for publication bias in meta-analysis. Biometrics. 2000;56(2):455-63. [pmid: 10877304].