# Data Abstraction Elements

## I Study Characteristics

- Additional articles used in this abstraction
  ○ If an additional article is used to supplement this abstraction, provide the article(s)' full citation(s).
- Study dates
  ○ Year enrollment started
  ○ Year enrollment ended
- Study sites
  ○ Single center
    ■ Geographic location: Enter City and State (if U.S.) and Country (if outside the U.S.).
  ○ Multicenter
    ■ Enter number of sites
    ■ Select all applicable geographical regions from the following options: US, Canada, UK, Europe, South America, Central America, Asia, Africa, Australia/New Zealand, Not reported/Unclear, Other (specify)
  ○ Not reported/Unclear
- Funding source (check all that apply): Government, Private foundation, Industry, Not reported, Other (specify)
- Setting (check all that apply): ICUs, Emergency departments, Critical care units, Postoperative settings, General medical units, Not reported/unclear, Other (specify)
- Enrollment approach (check all that apply): Consecutive patients, Convenience sample (not explicitly consecutive), Not reported/Unclear, Other (specify)
- Study inclusion and exclusion criteria
  ○ Copy/paste criteria as reported in the article
  ○ Were any of the following exclusion reasons applied?
    ■ Need for emergent intubation (includes respiratory arrest, severe hemodynamic instability [e.g., SBP < 90, severe bradycardia, severe arrhythmia], other indications)
    ■ Unable to cooperate with NPPV (includes decreased level of consciousness, encephalopathy, agitation)
    ■ Acute respiratory failure requiring a specific treatment (e.g. pulmonary embolus, pneumothorax, acute myocardial infarction)
    ■ Conditions that preclude NPPV face mask or nasal prong application (e.g., tracheostomy; facial deformities; recent oral, esophageal, or gastric surgery)
- Study enrollment and completion
  ○ Number of subjects assessed for eligibility
  ○ Number eligible
  ○ Number randomized
  ○ Number that completed follow-up
- Comments (if needed)

## II Ventilation Procedures

- Does the study address weaning? (Yes, No)
- Are there significant baseline imbalances between the patient groups? (Yes, No)
- For each treatment arm, indicate type of treatment and answer questions specific to that treatment:
  ○ Treatment type: NPPV, Supportive care, or Invasive Ventilatory Support
    ■ If NPPV
      - Interface used: Full face, Nasal prongs, Nasal mask, Not reported, Other (specify)
      - Type of NPPV
        ○ Bilevel positive airway pressure with supportive care
          ■ Bilevel upper/inspiratory pressure
          ■ Bilevel lower/expiratory pressure
        ○ Continuous positive airway pressure (CPAP) with supportive care
          ■ Planned CPAP pressure:
            - Fixed pressure
            - Acceptable pressure range
              ○ Min pressure
              ○ Max pressure
          ■ Mean CPAP pressure delivered
        ○ Other
        ○ Not reported
      - Other Details:
        ○ Autotitrating: Yes, No, Not reported/ Not available
        ○ Duration of ventilation, per protocol (mean hours per day, or if not given, mean and intended duration for Day 1)
        ○ Protocolized (presence of a structured algorithm for adjusting the non-invasive ventilation): Yes, No, Not reported
    ■ If Supportive care
      - Is planned supportive care identical for the intervention arm(s) and the comparator arm?
      - Describe supportive care
    ■ If Invasive Ventilatory Support
      - Autotitrating: Yes, No, Not reported/ Not available
      - Duration of ventilation, per protocol (mean hours per day, or if not given, mean and intended duration for Day 1)
- Staffing/training experience
- Staffing composition (check all that apply): Respiratory therapist, Nurse practitioner, Physician's assistant, Physician (general), Physician (other subspecialty), Physician (critical care trained), Nurse, Not reported
- Adjunctive treatments
  ○ High flow oxygen: Yes, No, Not reported/Unclear
  ○ Helium gas mixture: Yes, No, Not reported/Unclear
  ○ Sedatives and anxiolytics: Yes, No, Not reported/Unclear
    ■ If yes, was Precedex (dexametomidine) used?
- Comments (if needed)

## III Applicability of Key Questions

- Indicate populations included in the study (check all that apply):
  ○ Adults with chronic obstructive pulmonary disease (COPD) and acute respiratory failure
  ○ Adults with acute cardiogenic pulmonary edema (ACPE)
  ○ Adults with acute respiratory failure due to other causes including pneumonia, asthma, obesity-hypoventilation syndrome, and interstitial lung disease
  ○ Adults with acute respiratory failure in selective settings including perioperative setting and post-transplant setting
- Indicate applicable Key Questions
  ○ Key Question 1: Is noninvasive positive-pressure ventilation (NPPV) associated with less morbidity (including from intubation), lower mortality, lower adverse events, or lower medical utilization when compared to supportive medical therapy or invasive ventilation:
    ■ In adults with chronic obstructive pulmonary disease (COPD) and acute respiratory failure?
    ■ In adults with acute cardiogenic pulmonary edema (ACPE)?
    ■ In adults with acute respiratory failure due to other causes including: pneumonia, asthma, obesity-hypoventilation syndrome, and interstitial lung disease?
    ■ In adults with acute respiratory failure in selective settings including: perioperative setting and post-transplant setting?
  ○ Key Question 2: Is NPPV with bilevel positive airway pressure (BiPAP™), compared to NPPV with continuous positive airway pressure (CPAP), associated with less morbidity, lower mortality, lower adverse events, or lower medical utilization:
    ■ In adults with chronic obstructive pulmonary disease (COPD) and acute respiratory failure?
    ■ In adults with acute cardiogenic pulmonary edema (ACPE)?
    ■ In adults with acute respiratory failure due to other causes including: pneumonia, asthma, obseity-hypoventilation syndrome, and interstitial lung disease?
    ■ In adults with acute respiratory failure in selective settings including: perioperative setting and post-transplant setting?
  ○ Key Question 3: Is early extubation to NPPV, compared to usual care, associated with less morbidity, lower mortality, lower adverse events, or lower medical utilization:
    ■ In adults with chronic obstructive pulmonary disease (COPD) and acute respiratory failure?
    ■ In adults with acute cardiogenic pulmonary edema (ACPE)?
    ■ In adults with acute respiratory failure due to other causes including: pneumonia, asthma, obesity-hypoventilation syndrome, and interstitial lung disease?
    ■ In adults with acute respiratory failure in selective settings including: perioperative setting and post-transplant setting?
  ○ Key Question 4: Did this study report a subgroup analysis?
- Comments (if needed)

## IV Baseline Characteristics

- Number of subjects: For the total population and each treatment arm, indicate the following:
  ○ Treatment type: CPAP, Bilevel, Weaning without NPPV, Weaning with NPPV, Endotracheal intubation, Supportive care
  ○ N: Total, Female, Male
  ○ Percentage: Female, Male
- Total population age in years: For the total population and each treatment arm, indicate the following:
  ○ Treatment type: CPAP, Bilevel, Weaning without NPPV, Weaning with NPPV, Endotracheal intubation, Supportive care
  ○ Mean
  ○ Standard deviation
  ○ Median
  ○ Interquartile range
- Severity of illness score: Apache II score, Apache III score, Simplified acute physiological score, Other (specify), Not reported
  ○ For the total population and each treatment arm, indicate the following:
    ■ Treatment type: CPAP, Bilevel, Weaning without NPPV, Weaning with NPPV, Endotracheal intubation, Supportive care
    ■ Mean
    ■ Standard deviation
    ■ Median
    ■ Interquartile range
- Ethnicity (indicate total N and percentage of total population)
  ○ Hispanic or Latino
  ○ Not Hispanic or Latino
- Race (indicate total N and percentage of total population)
  ○ Black/African American
  ○ American Indian or Alaska Native
  ○ Asian
  ○ Native Hawaiian or other Pacific Islander
  ○ White
  ○ Multiracial
  ○ Other
- Baseline characteristics: For the total population and each treatment arm, indicate the following:
  ○ N or Percentage of patients
  ○ Heart rate: Not reported, or Mean and Standard deviation
  ○ Respiratory rate: Not reported, or Mean and Standard deviation
  ○ Systolic blood pressure: Not reported, or Mean and Standard deviation Arterial pH: Not reported, or Mean and Standard deviation
  ○ PaCO2 : Not reported, or Mean and Standard deviation
  ○ PaO2: Not reported, or Mean and Standard deviation
  ○ Ratio of PaO2 to Fraction of inspired O2: Not reported, or Mean and Standard deviation
  ○ Impaired mental status (Define) : Not reported, or Mean and Standard deviation
  ○ Mental status changes (Define) : Not reported, or Mean and Standard deviation
  ○ BMI: Not reported, or Mean and Standard deviation
  ○ Obesity (e.g. BMI>30) (Define): Not reported, or Mean and Standard deviation
  ○ Other (Specify): Not reported, or Mean and Standard deviation
- Causes of acute respiratory failure: For the total population and each treatment arm, indicate the following:
  ○ N or Percentage of patients
  ○ Chronic obstructive pulmonary disease (COPD): N, Percent
  ○ Pneumonia: N, Percent
  ○ Asthma: N, Percent
  ○ Obesity-hypoventilation syndrome: N, Percent
  ○ Interstitial lung disease: N, Percent
  ○ Acute cardiogenic pulmonary edema (ACPE) : N, Percent
  ○ Acute respiratory failure following a solid organ or bone marrow transplant: N, Percent
  ○ Acute respiratory failure following surgery requiring general anesthesia other than solid organ or bone marrow transplant: N, Percent
  ○ Other: N, Percent
- Comments (if needed)

## V Outcomes (repeatable per outcome of interest)

- Select outcome reported:
  ○ Intermediate Outcome/Respiratory Rate
  ○ Intermediate Outcome/Heart Rate
  ○ Intermediate Outcome/Partial Pressure of Oxygen in Arterial Blood (PaO2)
  ○ Intermediate Outcome/Partial Pressure of Carbon Dioxide in Arterial Blood (PaCO2)
  ○ Intermediate Outcome/Improved PaO2 to Fraction of inspired oxygen
  ○ Intermediate Outcome/Intubation Rate (NA for weaning studies)
  ○ Intermediate Outcome/Reintubation Rate (Post-op: weaning)
  ○ Intermediate Outcome/Duration of Mechanical Ventilation
  ○ Intermediate Outcome/Time to Reintubation (Post-op: weaning)
  ○ Intermediate Outcome/Rates of Discontinuing NPPV secondary to treatment intolerance
  ○ Intermediate Outcome/Successful Extubation
  ○ Intermediate Outcome/Myocardial Infarctions
  ○ Intermediate Outcome/Psychological Distress/Anxiety Validated Measure
  ○ Intermediate Outcome/AE: Discontinued NPPV-unable to tolerate
  ○ Final Outcome/Functional Status measured by SF36 or equivalent
  ○ Final Outcome/Health-related Quality of Life (HRQoL)
  ○ Final Outcome/Disease-specific functional status measure
  ○ Final Outcome/Mortality rates
  ○ Outcome/Ventilator dependent days
  ○ Days Final Outcome/Rate of Ventilator Dependence at Hospital Discharge
  ○ Final Outcome/Length of Hospital Stay
  ○ Final Outcome/Length of Intensive Care Stay
  ○ Final Outcome/Total Hospital Costs
  ○ Adverse Event/Aspiration
  ○ Adverse Event/Secondary Infections
  ○ Adverse Event/Facial Ulcerations
  ○ Adverse Event/Other (specify)
  ○ Other (specify)
- Provide the following data for the indicated outcome
  ○ Timing of the outcome data: 2 hours, 6 hours, 24 hours, At discharge, 30 days, In hospital, Other (Specify)
  ○ For each treatment arm, record the following:
    ■ N or Percentage of patients
    ■ Result, recorded as one of the following:
      - Mean
      - Median
      - Number of points with outcome
      - Percentage of points with outcome
      - Events per denominator
      - Other (specify)
    ■ Variability, recorded as one of the following:
      - Standard error
      - Standard deviation
      - Range
      - Interquartile range
      - Other (specify)
    ■ Comparative result, recorded as one of the following:
      - Relative risk
      - Relative hazard
      - Odds ratio
      - Risk difference
      - Other (specify)
      - Comparator: Treatment arm 1, Treatment arm 2, Treatment arm 3
    ■ Confidence interval (CI) or interquartile range (IQR)
      - Indicate measure (select one): 95% CI, Other percent CI (specify), IQR
      - Lower level (25% if IQR)
      - Upper level (75% if IQR)
- Comments (if needed)

## VI Subgroup Analyses (if applicable)

- Indicate the factor being considered: Setting, Experience and training of clinicians, Use of protocols, Morbid obesity, Mental status changes, Overall disease burden, Other patient characteristic (specify)
- Define the categories considered in this subgroup analysis.
- For each category described, provide data by outcome. Clearly indicate units (number of patients, %, hazard ratio, etc.). Include values for confidence intervals, p values, standard error, standard deviation, etc. when available.
  ○ Outcomes (provide data for all that apply):
    ■ Intermediate Outcome/Respiratory Rate
    ■ Intermediate Outcome/Heart Rate
    ■ Intermediate Outcome/Partial Pressure of Oxygen in Arterial Blood (PaO2)
    ■ Intermediate Outcome/Partial Pressure of Carbon Dioxide in Arterial Blood (PaCO2)
    ■ Intermediate Outcome/Improved PaO2 to Fraction of inspired oxygen
    ■ Intermediate Outcome/Intubation Rate (NA for weaning studies)
    ■ Intermediate Outcome/Reintubation Rate (Post-op: weaning)
    ■ Intermediate Outcome/Duration of Mechanical Ventilation
    ■ Intermediate Outcome/Time to Reintubation (Post-op: weaning)
    ■ Intermediate Outcome/Rates of Discontinuing NPPV secondary to treatment intolerance
    ■ Intermediate Outcome/Successful Extubation
    ■ Intermediate Outcome/Myocardial Infarctions
    ■ Intermediate Outcome/Psychological Distress/Anxiety Validated Measure
    ■ Intermediate Outcome/AE: Discontinued NPPV-unable to tolerate
    ■ Final Outcome/Functional Status measured by SF36 or equivalent
    ■ Final Outcome/Health-related Quality of Life (HRQoL)
    ■ Final Outcome/Disease-specific functional status measure
    ■ Final Outcome/Mortality rates
    ■ Outcome/Ventilator dependent days
    ■ Days Final Outcome/Rate of Ventilator Dependence at Hospital Discharge
    ■ Final Outcome/Length of Hospital Stay
    ■ Final Outcome/Length of Intensive Care Stay
    ■ Final Outcome/Total Hospital Costs
    ■ Adverse Event/Aspiration
    ■ Adverse Event/Secondary Infections
    ■ Adverse Event/Facial Ulcerations
    ■ Adverse Event/Other (specify)
    ■ Other (specify)
- Comments (if needed)

## VII Quality Assessment

- Rate each individual risk of bias item as Yes, No, or Unclear
  ○ Randomization and allocation concealment:
    ■ Was the allocation sequence adequately generated?^*^
      * Items contained in the Cochrane Risk of Bias Tool (Chapter 8 in the Cochrane Handbook, www.cochrane-handbook.org/)
    ■ Was the allocation adequately concealed?^*^
  ○ Study performance
    ■ Did variation from the study protocol compromise the conclusion of the study?
  ○ Outcomes
    ■ Were outcome assessors blind to treatment assigned for “hard outcomes” such as mortality?^*^
    ■ Were outcome assessors blind to treatment assignments for “soft outcomes” such as symptoms?^*^
    ■ Were the measures used reliable and valid? If so, choose “Yes,” indicating no important measurement bias.
  ○ Data analysis
    ■ Are reports of the study free of suggestion of selective outcome reporting (systematic differences between planned and reported findings)?^*^
    ■ Was incomplete outcome data adequately addressed?^*^
      - Yes (no systematic differences between groups in withdrawals from a study and no high overall loss to follow-up; all eligible patients that were randomized are included in analysis (“intention-to-treat” [ITT] analysis; note – mixed models and survival analyses are in general ITT)
      - No
      - Unclear
    ■ Was there adequate power for main effects?
  ○ Results
    ■ Were systematic differences observed in baseline characteristics and prognostic factors across the groups compared?
    ■ Were comparable groups maintained? Consider issues of crossover (e.g., from one intervention to another), adherence (major differences in adherence to the interventions being compared), contamination (e.g., some members of control group get intervention), or other systematic differences in care that was provided.^*^
  ○ Conflict of interest
    ■ Was there the absence of potential important conflict of interest? The focus is financial conflict of interest. If no financial conflict of interest (e.g., if funded by government or foundation and authors do not have financial relationships with drug/device manufacturer), then answer “Yes.”
- Overall study rating: Good, Fair, Poor
  ○ Assign each study an overall quality rating based on the following definitions:
    ■ Good. A “Good” study has the least bias, and results are considered valid. A good study has a clear description of the population, setting, interventions, and comparison groups; uses a valid approach to allocate patients to alternative treatments; has a low dropout rate; and uses appropriate means to prevent bias, measure outcomes, and analyze and report results.
    ■ Fair. A “Fair” study is susceptible to some bias but probably not enough to invalidate the results. The study may be missing information, making it difficult to assess limitations and potential problems. As the fair-quality category is broad, studies with this rating vary in their strengths and weaknesses. The results of some fair-quality studies are possibly valid, while others are probably valid.
    ■ Poor. A “Poor” rating indicates significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information; or have discrepancies in reporting. The results of a poor-quality study are at least as likely to reflect flaws in the study design as to indicate true differences between the compared interventions.
  ○ If the study is rated as “Fair” or “Poor,” provide rationale for decision.
- Comments (if needed)

## VIII Applicability

- Use the PICOTS format to identify specific issues that may limit the applicability of the study. Indicate the most important limitations affecting applicability, if any, from the list below.
  ○ Population (P)
    ■ Study population poorly specified
    ■ Overly narrow definition of acute respiratory failure
  ○ Intervention (I)
    ■ Intervention not well described
    ■ Highly selected intervention team or level of training/proficiency not widely available
  ○ Comparator (C)
    ■ Inadequate comparison therapy
    ■ Comparator(s) not well described
  ○ Outcomes (O)
    ■ Composite outcomes that mix outcomes of different significance
  ○ Timing (T)
    - No outcomes at 72 hours or greater
  ○ Setting (S)
    ■ Conducted outside of the US and practices not well described or widely divergent relative to US practices
    ■ Not widely accessible technology
- Comments (if needed)