# Exact Search Strings

## PubMed^®^

Original search date: April 7, 2011

Strategy:

((randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR placebo[tiab] OR drug therapy[sh] OR randomly[tiab] OR trial[tiab] OR groups[tiab]) NOT (animals[mh] NOT humans[mh])) AND (positive airway pressure respiration OR continuous positive airway pressure OR bilevel positive airway pressure OR bi-level positive airway pressure OR NPPV OR NIPPV OR BIPAP OR CPAP OR ippv OR ippb OR niv OR niav OR pav OR “proportional assist ventilation” OR “respiratory assist devices” OR ((noninvasive[tiab] OR non-invasive[tiab]) AND (ventilat*[tiab] OR respirat*[tiab])) OR (ventilat* AND helmet[tiab]) OR ((facial[tiab] OR nasal[tiab] OR face[tiab]) AND mask*[tiab]))

Limits: English, All Adult: 19+ years, Publication Date from 1990/01/01

Final search date: January 31, 2012

Strategy:

((randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR placebo[tiab] OR drug therapy[sh] OR randomly[tiab] OR trial[tiab] OR groups[tiab]) NOT (animals[mh] NOT humans[mh])) AND (positive airway pressure respiration OR continuous positive airway pressure OR bilevel positive airway pressure OR bi-level positive airway pressure OR NPPV OR NIPPV OR BIPAP OR CPAP OR ippv OR ippb OR niv OR niav OR pav OR “proportional assist ventilation” OR “respiratory assist devices” OR ((noninvasive[tiab] OR non-invasive[tiab]) AND (ventilat*[tiab] OR respirat*[tiab])) OR (ventilat* AND helmet[tiab]) OR ((facial[tiab] OR nasal[tiab] OR face[tiab]) AND mask*[tiab]))

Limits: English, Entry Date from 2011/03/07 to present

Note: The ‘All Adult: 19+ years’ limit was removed when updating the PubMed^®^ search to avoid exclusion of in-process citations.

Total number of unique results: 2885

## Embase^®^

Final search date: January 31, 2012

Total number of results: 879

Strategy:

‘positive end expiratory pressure’/exp OR ‘positive end expiratory pressure’ OR ‘pressure support ventilation’/exp OR ‘pressure support ventilation’ OR ‘positive airway pressure respiration’ OR ‘continuous positive airway pressure’ OR ‘bilevel positive airway pressure’ OR ‘bi-level positive airway pressure’ OR nppv OR nippv OR bipap OR cpap OR ippv OR ippb OR niv OR niav OR pav OR ‘proportional assist ventilation’ OR ‘respiratory assist devices’ OR (noninvasive:ti OR ‘non invasive’:ti AND (ventilat*:ti OR respirat*:ti)) OR (noninvasive:ab OR ‘non invasive’:ab AND (ventilat*:ab OR respirat*:ab)) OR (ventilat*:ti AND helmet:ti) OR (ventilat*:ab AND helmet:ab) OR (facial:ti OR nasal:ti OR face:ti AND mask*:ti) OR (facial:ab OR nasal:ab OR face:ab AND mask*:ab) AND (random* OR factorial* OR crossover* OR ‘cross over’ OR ‘cross overs’ OR placebo* OR doubl* NEAR/1 blind* OR singl* NEAR/1 blind* OR assign* OR allocat* OR volunteer* OR ‘double blind procedure’/exp OR ‘crossover procedure’/exp OR ‘randomized controlled trial’/exp OR ‘single blind procedure’/exp) AND [humans]/lim AND [english]/lim AND [embase]/lim NOT [medline]/lim AND [1990-2012]/py

## Cochrane Database of Systematic Reviews

Final search date: January 31, 2012

Total number of results: 84

Strategy:

#1 (positive airway pressure respiration OR continuous positive airway pressure OR bilevel positive airway pressure OR bi-level positive airway pressure OR NPPV OR NIPPV OR BIPAP OR CPAP OR ippv OR ippb OR niv OR niav OR pav OR “proportional assist ventilation” OR “respiratory assist devices” ):ti,ab,kw
#2 (ventilat* AND helmet):ti,ab,kw
#3 (noninvasive OR non invasive):ti,ab,kw and (respirat* OR ventilat*):ti,ab,kw
#4 (facial OR nasal OR face):ti,ab,kw and (mask):ti,ab,kw
#5 (#1 OR #2 OR #3 OR #4)
#6 (#1 OR #2 OR #3 OR #4), from 1990 to 2012

## ClinicalTrials.gov

Final search date: January 27, 2012

Total number of results: 125

Strategy:

(noninvasive OR positive pressure ventilation OR positive airway pressure AND respiration OR continuous positive airway pressure OR bilevel positive airway pressure OR bi-level positive airway pressure OR proportional AND assist ventilation OR respiratory assist AND device ) [ALL-FIELDS] AND “Interventional” [STUDY-TYPES] AND respiratory failure [DISEASE] AND (“Adult” OR “Senior” ) [AGE-GROUP]