# Abbreviations and Acronyms

3CPO: Three Interventions in Cardiogenic Pulmonary Oedema (3CPO)
ACPE: acute cardiogenic pulmonary edema
AHRQ: Agency for Healthcare Research and Quality
APACHE: Acute Physiology And Chronic Health Evaluation
ARDS: acute respiratory distress syndrome
BPAP: bilevel positive airway pressure
CER: comparative effectiveness review
CHF: congestive heart failure
CI: confidence interval
COPD: chronic obstructive pulmonary disease
CPAP: continuous positive airway pressure
ED: emergency department
ICU: intensive care unit
KQ: Key Question
MeSH: medical subject headings
NPPV: noninvasive positive-pressure ventilation
OR: odds ratio
PaCO2: partial pressure of carbon dioxide in blood
PaO2: partial pressure of oxygen in arterial blood
PICOTS: Population, Intervention, Comparator, Outcome, Timing, Setting
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta-Analyses
RCT: randomized controlled trial
SAPS: Simplified Acute Physiology Score
SD: standard deviation
TEP: Technical Expert Panel
TOO: Task Order Officer