# Results

We identified 1,428 nonduplicate titles or abstracts, with 574 proceeding to full text review (Figure 3). Fifty-eight publications were included in the review, representing 59 distinct study populations: 13 randomized controlled trials (RCTs), seven crossover RCTs, four nonrandomized clinical trials, 14 prospective cohorts, one retrospective cohort, three case series, four case-control studies, 11 cross-sectional studies, and two trend studies. The most common reasons for exclusion were irrelevance to the topic and ineligible study size. Twenty-one articles pertain to Key Question (KQ) 1, nine articles to KQ2, six articles to KQ3, 49 articles to KQ4, and zero articles to KQ5. Tables 3, 4 and 5 provide summaries of the nitrous oxide interventions represented in this review. Studies are grouped by study type and displayed in reverse chronological order. Seven studies of occupational exposure to nitrous oxide,26-32 three studies of addiction in offspring following nitrous oxide use during labor,33-35 and one study of leukemia in offspring following nitrous oxide use during labor36 are not included in the tables but are described in detail in the results of KQ4.

Figure 3 Disposition of articles identified by the search strategy

KQ = Key Question

* The number of articles addressing Key Questions and those excluded exceed the total number of articles in each category because some articles fit multiple exclusion categories or addressed more than one Key Question.

Figure 3 depicts the disposition of all articles included in the search and lists the reasons for exclusion. The search identified 1,428 nonduplicate articles, of which 1,362 were identified via literature search and 66 via hand-searching of the reference lists of articles. Of the 1,428 nonduplicate articles, 854 were excluded at the abstract review phase, and 574 moved on to the full-text review phase. Of the 574 that moved on to the full-text review phase, 58 were included in the review and 516 were excluded. Of the 58 articles included, 21 were included in Key Question 1, 9 in Key Question 2, 6 in Key Question 3, 49 in Key Question 4, and 0 in Key Question 5. Of the 574 articles excluded, 501 did not address study questions, 415 were not related to the use of nitrous oxide for the management of labor pain, 392 included an ineligible study size, 215 were not original research, and 3 were not published in English. The number of articles addressing Key Questions and those excluded exceed the total number of articles in each category because some articles fit multiple exclusion criteria or addressed more than one Key Question.

Table 3 Summary of nitrous oxide interventions, RCTs

Study Country Total N Study Type, Quality | Nitrous Oxide Mix and Administration Method | Comparator(s)
Talebi et al.,37 2009 Iran N = 523 RCT, poor | 50%;self-administered via facemask | 50% oxygen
Yeo et al.,38 2007 U.K. N = 32 Crossover RCT, poor | Entonox (50%); self-administered | 0.8% sevoflurane
Einarsson et al.,39 1996 Sweden N = 24 RCT, poor | 50%, 70%; administered via mouthpiece | The alternate nitrous oxide mixes were compared (50% vs. 70%)^*^
Abboud et al.,40 1995 U.S. N = 80 RCT, poor | 30 - 60%; administered by an anesthesiologist | 1 – 4.5% desflurane
Carstoniu et al.,41 1994 Canada N = 26 Crossover RCT, poor | 50%; self-administered | Compressed air
Arora et al.,42 1992 U.K. N = 41 RCT, fair | Entonox (50%); administration method not reported | Entonox and isoflurane
Westling et al.,43 1992 Sweden N = 24 Crossover RCT, poor | 40% and 70% (intermittent), 40% (continuous); administered via facemask | Intermittent oxygen, alternate nitrous oxide mixes, intermittent vs. continuous
Chia et al.,44 1990 Singapore N = 121 RCT, poor | Entonox (50%); administration method not reported | TENS
Abboud et al.,45 1989 U.S. N = 60 RCT, poor | 30 - 60% | 0.7% isoflurane
Constantine et al.,46 1989 U.K. N = 149 RCT, poor | Entonox (50%); administered via facemask, mouthpiece, or humidifier | The alternate administration methods were compared^*^
McLeod et al.,47 1985 U.K. N = 32 Crossover RCT, poor | Entonox (50%); administered via facemask | 0.75% isoflurane
McGuinness and Rosen,48 1984 U.K. N = 20 Crossover RCT, poor | Entonox (50%); administered by an anesthesiologist via mouthpiece | 1% enflurane
Abboud et al.,49 1981 U.S. N = 105 RCT, poor | 30 - 60%; administered by an anesthesiologist | 0.25 – 1.25% enflurane
Rosen et al.,50 1972 U.K. N = 250 RCT and prospective cohort, poor | Entonox (50%); administration method not reported | 0.35% methoxyflurane
Bergsjo and Lindbaek,51 1971 Norway N = 63 Crossover RCT, poor | 50%; administered via facemask | 0.5 – 0.8% methoxyflurane
Phillips and Macdonald,52 1971 U.K. N = 152 RCT, poor | Entonox (50%); administration method not reported | Trichloroethylene and pethidine, pethidine only
NA,12 1970 U.K. N = 778 RCT, fair | 50%, 70%; administration method not reported | The alternate nitrous oxide mixes were compared (50% vs. 70%)^*^
Jones et al.,53 1969 U.K. N = 50 RCT, poor | 50%; administration method not reported | 0.35% methoxyflurane
Jones et al.,54 1969 U.K. N = 50 RCT, poor | 0 - 80%; administration method not reported | 60% methoxyflurane

TENS = transcutaneous electrical nerve stimulation

* Studies that assessed nitrous oxide and no other pain management methods were only included in the harms KQ.

Table 4 Summary of nitrous oxide interventions, nonrandomized trials and cohort studies

Study Country Total N Study Type, Quality | Nitrous Oxide Mix and Administration Method | Comparator(s)
Stirk et al.,55 2002 U.K. N = 115 Prospective cohort, poor | Entonox (50%); administration method not reported | Diamorphine
Leong et al.,56 2000 Malaysia N = 118 Prospective cohort, good | Entonox (50%); administration method not reported | Epidural and bupivacine and/or fentanyl
Arfeen et al.,57 1994 U.K. N = 40 Prospective cohort, poor | Entonox (50%); administration method not reported | Epidural and bupivacine
Ranta et al.,58 1994 Finland N = 1,091 Prospective cohort, poor | 50%; administered by an anesthesiologist | Epidural, water block, pethidine, multiple analgesics, no analgesia
Landon et al.,59 1992 U.K. N = 58 Prospective cohort, poor | Entonox (50%); administration method not reported | No nitrous oxide
Zelcer et al.,60 1989 Australia N = 75 Prospective cohort, poor | % not reported, administration method not reported | Epidural, pethidine
Deckardt et al.,61 1987 Germany N = 55 Prospective cohort, poor | 50%; administration method not reported | Lumbar peridural anesthesia, no analgesic drugs
Harrison et al.,62 1987 Ireland N = 170 Prospective cohort, poor | Entonox (50%); self-administered | Epidural, TENS, pethidine and promazine
Harrison and Cullen63 1986 Ireland N = 110 Prospective cohort, poor | Entonox (50%); self-administered | Epidural, pethidine and promazine, TENS, TENS placebo, general anesthesia
Soyannwo,64 1985 Nigeria N = 150 Prospective cohort, poor | Entonox (50%); self-administered | Entonox and pethidine or pethilorphan
Murphy et al.,65 1984 U.K. N = 8,392 Retrospective cohort, poor | Entonox (50%); administration method not reported | Epidural, pethidine
Arthurs et al.,16 1979 U.K. N = 49 Prospective cohort, poor | Entonox (50%); self-administered intermittently via facemask, or continuously via nasal cannula | Facemask and nasal cannula vs. facemask only^*^
Rosen et al.,66 1969 U.K. N = 1,522 Nonrandomized trial, poor | Entonox (50%); administration method not reported | 0.35%, 0.5% trichloroethylene; 0.35% methoxyflurane
Beppu,67 1968 Japan N = 667 Prospective cohort, poor | 50 – 80%; administration method not reported | Trichloroethylene, halothane
Smith et al.,68 1968 U.S. N = 2,066 Nonrandomized trial, poor | 25 – 50%; administration method not reported | 0.2 – 0.5% methoxyflurane, 1 – 5% cyclopropane, pudendal, spinal
Clark et al.,69 1967 U.S. N = 94 Nonrandomized trial, fair | 50% oxygen with nitrous oxide and methoxyflurane^†^; administered via inhaler | Methoxyflurane
McAneny and Doughty,13 1963 U.K. N = 501 Nonrandomized trial, poor | 50%, 60%, 70%, 75%, 80%; self-administered | Alternate nitrous oxide mixes^*^

TENS = transcutaneous electrical nerve stimulation

* Studies that assessed nitrous oxide and no other pain management methods were only included in the harms KQ.

† Nitrous oxide concentration not reported.

Table 5 Summary of nitrous oxide interventions, other study designs

Study Country Total N Study Type, Quality | Nitrous Oxide Mix and Administration Method | Other Pain Management Method(s) Assessed
Waldenstrom and Irestedt,70 2006 Sweden N = 2,482 Trend, fair | % not reported; administration method not reported^*^ | Epidural block , pethidine, paracervical bock, pudendal block
Henry and Nand,71 2004 Australia N = 496 Cross-sectional, poor | % not reported; administration method not reported^†^ | Pethidine, epidural, local anesthesia, nonpharmacological methods
Peach,72 1999 Australia N = 1,000 Cross-sectional, fair | % not reported; administration method not reported^†^ | Epidural, pethidine, nonpharmacological (alone and in combination)
Ross et al.,73 1999 U.K. N = 221 Case series, poor | Entonox (50%) with isoflurane; administration method not reported | None
Waldenstrom,74 1999 Sweden N = 1,148 Cross-sectional, fair | Entonox (50%); administration method not reported | Epidural, pethidine
Waldenstrom et al.,75 1996 Sweden N = 385 Cross-sectional, fair | Entonox (50%); administration method not reported | Epidural, local anesthesia, acupuncture, bath, breathing techniques
Ranta et al.,76 1995 Finland N = 1,091 Cross-sectional, fair | 50%; administered via facemask | Epidural, pethidine, paracervical block, bupivacaine
Reed et al.,77 1988 U.K. N = 41 Case series, poor | Entonox (50%); administration method not reported | Pethidine
Morgan et al.,78 1982 U.K. N = 1,000 Cross-sectional, poor | Entonox (50%); self-administered | Epidural, pethidine, pudendal block
Holdcroft and Morgan,79 1974 U.K. N = 705 Cross-sectional, poor | Entonox (50%); administration method not reported | Entonox and pethidine, pethidine only
Marx et al.,80 1970 U.S. N = 40 Case series, poor | 50 – 70%; administered via facemask | None

* Survey of the prevalence of pain management methods; concentrations of nitrous oxide not reported

## KQ1 Effectiveness of Nitrous Oxide for Labor Pain Management

### Key Points

- The heterogeneous outcomes used to assess pain make synthesis of studies challenging.
- Epidural anesthesia provides more effective pain relief than nitrous oxide, but the quality of the studies is predominately poor.
- The strength of the evidence for the effectiveness of nitrous oxide to manage labor pain compared with other, nonepidural pain management methods is insufficient because the studies are predominately of poor quality, use heterogenous outcome measures, and have inconsistent findings.
- The strength of the evidence for the effectiveness of nitrous oxide to manage labor pain compared with epidurals was not assessed because the two interventions have different goals with the purpose of epidural to substantially block pain and the purpose of nitrous oxide to make pain manageable. A head to head comparison will always demonstrate greater effectiveness of epidural for reducing pain.

This section presents the results of the literature search and findings about the effectiveness of nitrous oxide as a labor analgesic compared with other pharmacologic and nonpharmacologic modalities. The pharmacologic modalities that were compared with nitrous oxide in the literature were other inhalational anesthetic gases, including methoxyflurane, isoflurane, enflurane, desflurane, sevoflurane, trichloroethylene, and cyclopropane; epidural anesthesia; the opioid pethidine/meperidine (Demerol^®^), which was sometimes used in conjunction with the antiemetic promazine; paracervical block; pudendal block; and varied combinations of the pharmacologic agents. Nonpharmacologic modalities included transcutaneous electrical nerve stimulation (TENS), hydrotherapy (bath or shower), sterile water papule blocks, acupuncture, and psychoprophylaxis.

### Overview of the Literature

Twenty-one publications representing 22 studies of distinct populations addressed the effectiveness of nitrous oxide.38, 40-41, 44-45, 47-49, 51, 53-54, 58, 62, 66, 68-70, 75-76, 78-79 Eight of these studies were conducted in the United Kingdom,48 38, 47, 53-54, 66, 78-79 five in the United States,40, 45, 49, 68-69 two in Sweden,70, 75 two in Finland,58, 76, two in Singapore,44 and one each in Canada,41 Ireland,62 and Norway.51 These studies included six RCTs,40, 44-45, 49, 53-54 six crossover RCTs,38, 41, 44, 47-48, 51 four cross-sectional studies,75-76, 78-79 two nonrandomized clinical trials,66, 68 two prospective cohort studies,58, 62 one case series,69 and one trend study.70 One study included an RCT and a crossover RCT with two distinct populations.44 Four studies were of fair quality,69-70, 75-76 and 17 were of poor quality.38, 40-41, 44-45, 47-49, 51, 53-54, 58, 62, 66, 68, 78-79

### Detailed Synthesis

#### Placebo

An RCT compared 50 percent nitrous oxide in oxygen with compressed air using a double-blind, crossover design.41 Participants (n = 26) self-administered nitrous oxide or placebo for five consecutive contractions then were switched to the other option for the next five contractions. Visual analog scale (specific numerical values not reported) scores to rate pain were obtained after each contraction. No statistically significant differences in the mean visual analogue scores were found between the two groups.

#### Inhalational Anesthetic Gases

Twelve studies compared nitrous oxide with various other inhalational anesthetic gases not currently used for management of labor pain in the United States, including six with methoxyflurane;51, 53-54, 66, 68-69 two with isoflurane;45, 47 two with enflurane;48-49 and one each with desflurane,40 sevoflurane,38 trichloroethylene,66 and cyclopropane.68 These studies are summarized in Table 6, with the exception of one study that did not contribute additional data.69 Studies are displayed in reverse chronological order.

Table 6 Effectiveness of inhalational anesthetic gases

Author Year Study Type N | Interventions | Other Labor Pain Management Method(s) | Findings
Yeo et al.,38 2007 Crossover RCT N = 32 | Entonox (nitrous oxide 50%) | None | - Women used both gases.; - Visual analogue scales with 100 mm rulers were used to assess pain relief, pain intensity, and sedation.; - Pain relief significantly better with sevoflurane than Entonox in the first (p = 0.01) and second (p < 0.001) crossovers.; - Pain intensity significantly higher with Entonox than sevoflurane in the first crossover (p = 0.04) but not different in the second crossover.; - Sedation significantly greater with sevoflurane than Entonox in both crossovers (p < 0.001). 97% of participants preferred sevoflurane over nitrous oxide (p < 0.001).
Yeo et al.,38 2007 Crossover RCT N = 32 | Sevoflurane 0.8% | None
Abboud et al.,40 1995 RCT N = 80 | Nitrous oxide 30% to 60%, usually 46% | Not reported | - Satisfactory analgesia scores were comparable among women, anesthesiologists, and obstetricians.
Abboud et al.,40 1995 RCT N = 80 | Desflurane 1% to 4.5%, usually 2% | Not reported | - Satisfactory analgesia scores were comparable among women, anesthesiologists, and obstetricians.
Abboud et al.,45 1989 RCT N = 60 | Nitrous oxide 30%-60%, usually 33% | Local infiltration, pudendal block, epidural | - Proportion of satisfactory pain scores did not differ significantly between groups among mothers (87% for nitrous oxide, 83% for isoflurane), anesthesiologists (97% for nitrous oxide, 90% for isoflurane), and obstetricians (83% for nitrous oxide, 87% for isoflurane).
Abboud et al.,45 1989 RCT N = 60 | Isoflurane 0.2%-0.7%, usually 0.4% | Local infiltration, pudendal block, epidural
McLeod et al.,47 1985 Crossover RCT N = 32 | Entonox (nitrous oxide 50%) | None | - Pain was assessed with a linear analogue scale (0-100). Mean pain scores were 63.0 (range 24-92) with Entonox and 46.6 (range 19-86) with isoflurane (p < 0.001).; - Drowsiness scores were higher with isoflurane than nitrous oxide.; - When women asked which agent they preferred at the end of the study, 69% chose isoflurane, 25% chose Entonox, and 6% were undecided.
McLeod et al.,47 1985 Crossover RCT N = 32 | Isoflurane 0.75% | None
McGuinness et al.,48 1984 Crossover RCT N = 20 | Nitrous oxide 50% | Pethidine | - Women used both gases.; - Pain assessed with linear analogue scores (0-100). Scores with enflurane (median 50, range 13-79) were significantly lower than the scores with nitrous oxide use (median 52, range 29-79, p < 0.02).; - Drowsiness scores for enflurane were significantly higher that the scores for nitrous oxide (p < 0.02).
McGuinness et al.,48 1984 Crossover RCT N = 20 | Enflurane 1% | Pethidine
Abboud et al.,49 1981 RCT N = 105 | Nitrous oxide 30% to 60%, usually 40% | Narcotic analgesia, local infiltration, pudendal block | - Most women had satisfactory analgesia according to scores from the women, anesthesiologists, and obstetricians.; - The difference in satisfactory analgesia scores for the two gases was significant only for the obstetricians (p < 0.05).
Abboud et al.,49 1981 RCT N = 105 | Enflurane 0.25% to 1.25%, usually 0.5% | Narcotic analgesia, local infiltration, pudendal block
Bergsjo et al.,51 1971 Crossover RCT N = 63 | Nitrous oxide 50% | None | - After using both, a higher proportion of mothers chose nitrous oxide (63%) than methoxyflurane (35%) with 2% undecided (p < 0.05).; - Analgesic effect of nitrous oxide (rated by physician): excellent for 8%, good for 82%, moderate for 4%, and poor for none.; - Analgesic effect of methoxyflurane (rated by physician): good for 95% and moderate for 5%.
Bergsjo et al.,51 1971 Crossover RCT N = 63 | Methoxyflurane 0.8% | None
Jones et al.,54 1969 RCT N = 48 | Nitrous oxide calibrated in 5% steps from 20% to 100% oxygen | Pethidine | - Mean proportion of time the anesthetists assessed the women's reactions to contractions as satisfactory did not differ significantly between groups.; - Most midwives and women reported pain relief was complete or considerable.
Jones et al.,54 1969 RCT N = 48 | Methoxyflurane with 40% oxygen | Pethidine
Jones et al.,53 1969 RCT N = 50 | Nitrous oxide 50% | Pethidine | - Mean proportion of time the anesthetists assessed the women's reactions to contractions as satisfactory was significantly (p < 0.05) higher for methoxyflurane (79.3 ± 20%) than nitrous oxide (62.3 ± 30%).; - Most midwives and women reported pain relief was complete or considerable.
Jones et al.,53 1969 RCT N = 50 | Methoxyflurane 0.35% | Pethidine
Rosen et al.,66 1969 Prospective cohort N = 1257 | Nitrous oxide 50% | Pethidine, morphine | - No significant difference between groups in the women's assessment of their pain relief in interviews immediately after the birth and two days later.; - Midwives rated pain relief good or excellent more frequently with methoxyflurane (53%, p < 0.01) and trichloroethylene (49%, p < 0.02) than nitrous oxide (42%).
Rosen et al.,66 1969 Prospective cohort N = 1257 | Trichloroethylene 0.35% or 0.5% | Pethidine, morphine
Rosen et al.,66 1969 Prospective cohort N = 1257 | Methoxyflurane 0.35% | Pethidine, morphine
Smith et al.,68 1968 Prospective cohort N = 1616 | Nitrous oxide 25% to 40% | Local or pudendal nerve block | - Participants and physician pain ratings did not differ significantly across groups.
Smith et al.,68 1968 Prospective cohort N = 1616 | Methoxyflurane 0.2% to 0.5% | Local or pudendal nerve block | - Participants and physician pain ratings did not differ significantly across groups.
Smith et al.,68 1968 Prospective cohort N = 1616 | Cyclopropane 1% to 5% | Local or pudendal nerve block | - Participants and physician pain ratings did not differ significantly across groups.

#### Transcutaneous Electric Nerve Stimulation

One publication comparing Entonox^®^ with TENS reported two studies.44 The first study was an RCT in which 101 women in early labor were randomized to Entonox or TENS as their initial pain management method. They could choose a different pain relief method if the initial method was inadequate, and the proportion of women who did this was comparable in the two groups (17% using Entonox vs. 19% using TENS, difference nonsignificant). On the first postpartum day, the woman rated her pain with Entonox or TENS on a scale of 0 to 10. The difference between groups was not statistically significant. The second study was a crossover RCT in which 20 nulliparous women undergoing induction of labor were randomized to Entonox or TENS for their first pain management method. When labor pain was no longer tolerable, the woman was asked to rate the pain relief as nil, partial, or complete then switched to the other method (Entonox or TENS). For their first method, women had more relief with TENS than Entonox, but this difference was not statistically significant and women in the Entonox group were having more frequent contractions. The difference in pain relief between groups was also nonsignificant for the second method used.

#### Observational Studies of Multiple Pain Management Methods

Two prospective cohort studies assessed the effectiveness of multiple pain management methods in women who chose their methods.58, 62 The first study (n = 170) included women whose initial pain management method choice was Entonox, TENS, pethidine and promazine, or epidural.62 Five-point scales were used to assess women's pain and midwives' evaluation of pain relief. Both groups rated epidural as providing the most pain relief, and pethidine and promazine as providing the least (p < 0.001 for participant and midwife ratings). Additional pain management methods were used by 5 percent of women in the nitrous group, 82 percent in the TENS group, 80 percent in the pethidine and promazine group, and none of the women in the epidural group. The second study (n = 833 with pain scores) included women who had 50 percent nitrous oxide, water blocks, pethidine, paracervical block, epidural, several methods, and no analgesia.58 During labor, a visual pain scale (0–10) was used. Median pain scores decreased significantly (p < 0.01) from pre-analgesia values with epidural and paracervical block, and increased significantly (p < 0.01) after water block, nitrous oxide, and pethidine. On their third day postpartum, women were asked to rate the adequacy of analgesia. None of the women who had epidural rated it as poor (p < 0.01 for comparison with other groups) compared with 28 percent who used nitrous oxide.

Five cross-sectional studies retrospectively assessed the effectiveness of labor pain management methods.70, 75-76, 78-79 In a study of 2,482 women, participants completed a questionnaire two months after their births that included assessment of their pain management methods as very effective, some effect, or no effect.70 Epidural had the highest percentage of very effective responses (84% of primiparas, 72% of multiparas) followed by nitrous oxide (38%of primiparas, 49%of multiparas), psychoprophylaxis (39% of primiparas, 47% of multiparas), pethidine (41% of primiparas and multiparas), bath or shower (29% of primiparas, 35% of multiparas), and acupuncture (10% of primiparas, 23% of multiparas). In another study, 1,000 women were interviewed within 48 hours after giving birth and asked to identify how much pain they experienced using a 10 cm linear analogue scale graded between 0 and 100 mm.78 Women who had epidurals had the lowest mean (± SD) pain score (29 ± 3.7) followed by pethidine plus epidural (30 ± 3.8), epidural plus Entonox (51 ± 4.2), pethidine plus Entonox (57 ± 3.4), pethidine (58 ± 3.1), Entonox (61 ± 3.1), pudendal block (68 ± 1.9), miscellaneous (69 ± 3.3), and no analgesia (70 ± 2.6). In one study, interviews were conducted 24 to 48 hours after birth in which women were asked to rate their pain relief with analgesia as complete, satisfactory, slight, or none.79 When nitrous oxide (n = 130) was compared with pethidine (n = 67), more women had complete (4% vs. 0) or satisfactory (46% vs. 22%) pain relief with nitrous oxide. Nearly half of the women who used pethidine reported no pain relief compared with one-third of the women who used nitrous oxide. Two studies did not contribute additional data.75-76

## KQ2 Effect of Nitrous Oxide on Women's Satisfaction

### Key Points

- The measures used to assess women's satisfaction with their birth experience and pain management were unique to each study, which makes synthesis challenging.
- The strength of the evidence is low for equivalence or superiority of nitrous oxide compared with other pain management methods for women's satisfaction with their birth experience and pain management.

This section presents the results of the literature search and findings about women's satisfaction with nitrous oxide as a labor analgesic compared with other pharmacologic and nonpharmacologic modalities for labor pain management. The pharmacologic modalities that were compared with nitrous oxide in the literature were epidural anesthesia; the narcotic pethidine/meperidine, which was sometimes used in conjunction with the antiemetic promazine; other inhalational anesthetic gases, including isoflurane, enflurane, and desflurane; and paracervical block. Nonpharmacologic modalities included TENS and water blocks.

### Overview of the Literature

Nine studies addressed the effectiveness of nitrous oxide on women's satisfaction.40, 45, 49, 56, 58, 62, 71, 74, 79 Three of these studies were conducted in the United States,40, 45, 49 and one each in Australia,71 the United Kingdom,79 Malaysia,56 Sweden,74 Ireland,62 and Finland.58 These studies included three RCTs,40, 45, 49 three prospective cohorts,56, 58, 62 and three cross-sectional studies.71, 74, 79 One study was of good quality,56 one of fair quality,74 and seven of poor quality.40, 45, 49, 58, 62, 71, 79

#### Women's Satisfaction with Their Birth Experience

Two studies assessed women's satisfaction with their birth experience.62, 74 The first was a prospective cohort study in which 170 women who chose Entonox, epidural, pethidine and promazine, or TENS as their first choice of analgesia were asked in the first 24 hours if they would use the same method again.62 The second was a cross-sectional study in which 1,111 women were asked about their birth experience at two months postpartum via questionnaire.74 The results for these studies are grouped by comparator.

##### Epidural

Of the women in the prospective cohort study who chose Entonox, 80 percent (16 of 20) would request Entonox again, compared with 88 percent (44 of 50) of women who chose epidural.62 In the postpartum survey, 57 percent of women who had nitrous oxide (n = 362) reported a positive or very positive birth experience compared with 34 percent of the women (n = 129) who had epidural analgesia.74

##### Pethidine

Eighty percent (16 of 20) of the women who chose Entonox in the prospective cohort study would request Entonox again compared with 38 percent (19 of 50) of women who chose pethidine and promazine.62 Of 362 women who had nitrous oxide, 57 percent reported a positive or very positive birth experience at two months postpartum compared with 49 percent of 94 women who had pethidine.74

##### Transcutaneous Electric Nerve Stimulation

Women in the prospective cohort study who chose Entonox more frequently (16 of 20, 80%) reported they would choose it again compared with women who chose TENS (30 of 50, 60%).62

#### Women's Satisfaction with Their Pain Management

##### Epidural

Four studies compared women's satisfaction with pain management with nitrous oxide or epidural.56, 58, 62, 71 In a prospective cohort study, only 5.5 percent (3 of 55) of women who had an epidural were not satisfied with the pain relief compared with 45.6 percent (31 of 68) of women who had Entonox and pethidine.56 Of the women who chose Entonox in another prospective cohort study, 60 percent (12 of 20) reported that the pain relief was adequate, compared with 98 percent (49 of 50) of women who chose epidural analgesia.62 In a third prospective cohort study, 33 percent (66 of 200) of women who chose Entonox rated the pain relief adequacy as good, compared with 94 percent (75 of 80) of those who chose an epidural.58 A cross-sectional study found 30 percent (40 of 115) of women who chose nitrous oxide were very satisfied with the relief of pain, compared with 49 percent (58 of 118) of those who chose an epidural.71

##### Pethidine

Three studies compared women's satisfaction with the pain management of Entonox and pethidine. Of the women who chose Entonox in a prospective cohort study, 60 percent (12 of 20) reported that the pain relief was adequate, compared with 18 percent (9 of 50) of women who chose pethidine-promazine.62 In another prospective cohort study, 33 percent (66 of 200) of women who chose Entonox rated the pain relief adequacy as good, compared with 60 percent (26 of 44) of those who chose pethidine.58 Of the women in a cross-sectional study who received Entonox, 50 percent (65 of 130) reported satisfactory or complete pain relief, compared with 22 percent (15 of 67) of those receiving pethidine alone.79

##### Inhalational Anesthetic Gases

Three RCTs (total n = 245) compared women's satisfaction with pain management with use of nitrous oxide (30% to 60% mix) with use of other inhalational anesthetic gases. The proportion of women who were satisfied or very satisfied with nitrous oxide was not statistically different than enflurane (76% vs. 89%),49 isoflurane (87% vs. 83%),45 and desflurane (63% for both).40

##### Paracervical Block

In a prospective cohort study, a lower proportion of women who chose Entonox (33%, 66 of 200) reported good pain relief adequacy compared with women who chose to receive paracervical block (59%, 70 of 119).58

##### Transcutaneous Electric Nerve Stimulation

An equal proportion of women in a prospective cohort study who chose Entonox (80%, 12 of 20) and TENS (80%, 40 of 50) reported that their pain relief was adequate.62

##### Water Blocks

The proportion of women who rated their pain relief adequacy as good was lower with Entonox (33%, 66 of 200) than among those who chose to receive injections of water (water blocks) in their lower back (59%, 40/68) in one prospective cohort study.58

## KQ3 Effect of Nitrous Oxide on the Route of Birth

### Key Points

- The strength of the evidence is insufficient to determine the effect of nitrous oxide on the route of birth because the studies are predominately of poor quality, use heterogenous outcome measures, and have inconsistent findings.

This section presents the results of the literature search and findings about the route of birth in women who used nitrous oxide as a labor analgesic compared with other pharmacologic and nonpharmacologic modalities for labor pain management. The pharmacologic modalities that were compared with nitrous oxide in the literature were epidural anesthesia; the narcotic pethidine/meperidine, which was sometimes used in conjunction with the antiemetic promazine; other inhalational anesthetic gases, including methoxyflurane, desflurane, and trichloroethylene; and paracervical block. Nonpharmacologic modalities included TENS and water blocks.

### Detailed Synthesis

Six studies compare the route of birth in women who used nitrous oxide with that in women who used other pain management methods.40, 54, 56, 58, 62, 66 Two studies were conducted in the United Kingdom,54, 66 one in Ireland,62 one in Finland,58 one in Malaysia,56 and one in the United States.40 Two studies are RCTs,40, 54 three are prospective cohort studies,56, 58, 62 and one is a nonrandomized clinical trial.66 One study was of good quality56 and five were of poor quality.40, 54, 58, 62, 66 Findings for route of birth are presented in Table 7. Studies are presented in reverse chronological order. Only two of the studies56, 62 had statistically significant findings. In one prospective cohort study the proportion who had an assisted vaginal birth was lower with Entonox plus pethidine (13%) than epidural (40%).56 Another prospective cohort study found the operative birth rate (which combined forceps-assisted, vacuum-assisted, cesarean, and breech births) was higher among women whose initial choice for pain management was epidural than those who chose nitrous oxide, TENS, or pethidine plus promazine.62

Table 7 Route of birth in women using nitrous oxide

Author Year Study Type | Intervention (N) | Vaginal Birth N (%) | Assisted Vaginal Birth N (%) | Cesarean Birth N (%)
Leong et al.,56 2000 Prospective cohort | Entonox plus IM pethidine (68) | 56 (82.4) | 9 (13.2) | 3 (4.4)
Leong et al.,56 2000 Prospective cohort | Bupivacaine epidural (55) | 28 (50.9) | 22 (40.1)^*^ | 5 (9.0)
Abboud et al.,40 1995 RCT | Nitrous oxide, 30-60% oxygen (40) | 35 (87.5) | 5 (12.5) | 0^
Abboud et al.,40 1995 RCT | Desflurane 1-4.5% and oxygen (40) | 31 (77.5) | 9 (22.5) | 0^
Ranta et al.,58 1994 Prospective cohort | Nitrous oxide 50% (210) | NR (95) | NR (2) | NR (3)
Ranta et al.,58 1994 Prospective cohort | Water blocks (69) | NR (90) | NR (3) | NR (7)
Ranta et al.,58 1994 Prospective cohort | Pethidine (50) | NR (91) | NR (2) | NR (7)
Ranta et al.,58 1994 Prospective cohort | Paracervical block (128) | NR (94) | NR (3) | NR (3)
Ranta et al.,58 1994 Prospective cohort | Epidural anesthesia (82) | NR (80) | NR (11) | NR (9)
Ranta et al.,58 1994 Prospective cohort | Several methods (339) | NR (86) | NR (7) | NR (7)
Ranta et al.,58 1994 Prospective cohort | No analgesia (213) | NR (94) | NR (1) | NR (5)
Harrison et al.,62 1987 Prospective cohort | Entonox (20)^†^ | 12 (60.0) | 7 (35.0) | 0
Harrison et al.,62 1987 Prospective cohort | TENS (50) | 32 (64.0) | 14 (28.0) | 4 (8.0)
Harrison et al.,62 1987 Prospective cohort | Pethidine plus promazine (50) | 32 (64.0) | 18 (36.0) | 0
Harrison et al.,62 1987 Prospective cohort | Lumbar epidural (50) † | 13 (26.0) | 31 (62.0)θ | 3 (6.0)θ
Rosen et al.,66 1969 Nonrandomized clinical trial | Nitrous oxide 50% (265) | 235 (88.7) | 30 (11.3) | 0
Rosen et al.,66 1969 Nonrandomized clinical trial | Trichloroethylene 0.35% or 0.5% (394) | 345 (87.5) | 46 (11.7) | 3 (0.8)
Rosen et al.,66 1969 Nonrandomized clinical trial | Methoxyflurane 0.35% (598) | 525 (87.8) | 68 (11.4) | 5 (0.8)
Jones et al.,54 1969 Quasi-RCT | Nitrous oxide calibrated in 5% steps from 20% to 100% oxygen (24) | 19 (79.2) | 5 (20.8) | 0^
Jones et al.,54 1969 Quasi-RCT | Methoxyflurane with 40% oxygen (24) | 19 (79.2) | 5 (20.8) | 0^

NR = not reported; RCT = randomized controlled trial

* p < 0.01

^ Study only included women with vaginal births.

† One woman in the Entonox group and three women in the lumbar epidural group had breech births that are not included in the table because the route of birth was not identified.

θ The operative birth rate (which included forceps- and vacuum-assisted births, cesarean births, and breech births) was higher for women whose initial choice was epidural than any of the other analgesia methods (p < 0.001).

## KQ4 Adverse Effects of Nitrous Oxide for Labor Pain Management

### Key Points

- When nitrous oxide was used as a sole agent, 0 to 28 percent of women experienced nausea and zero to 14 percent experienced vomiting.
- Three to 23 percent of women using nitrous oxide as a sole agent reported dizziness.
- Drowsiness occurred in 0 to 67 percent of women using nitrous oxide as a sole agent.
- Apgar scores in newborns whose mothers used nitrous oxide did not differ significantly from those of newborns whose mothers used other labor pain management methods or no analgesia.
- Limited data on occupational harms are available.
- The strength of evidence that adverse effects associated with nitrous oxide for labor pain management are primarily unpleasant side effects that affect tolerability is moderate.

In this section we present the results of the literature search and findings about maternal, fetal, neonatal, and occupational harms. Within each of these outcome categories we have organized the research findings by specific harms, with related or similar harms presented together.

### Overview of the Literature

Forty-nine publications addressed maternal, fetal, neonatal and occupational harms related to nitrous oxide for labor.12-13, 16, 26-30, 32-43, 45-61, 63-69, 72-73, 77, 80 Twenty-two of these studies were conducted in the United Kingdom,12-13, 16, 26, 31-32, 38, 42, 46-48, 50, 52-55, 57, 59, 65-66, 73, 77 ten in Sweden,27-30, 33-36, 39, 43 six in the United States,40, 45, 49, 68-69, 80 two in Australia,60, 72 and one each in Germany,61 Canada,41 Finland,58 Iran,37 Ireland,63 Japan,67 Malaysia,56 Nigeria,64 and Norway.51 These studies include 12 RCTs,12, 37, 39-40, 42, 45-46, 49-50, 52-54 six crossover RCTs,38, 41, 43, 47-48, 51 four case-control studies,33-36 four nonrandomized clinical trials,13, 66, 68-69 13 prospective cohorts,16, 30, 32, 55-61, 63-64, 67 one retrospective cohort,65 three case series,73, 77, 80 five cross-sectional studies,26-27, 29, 31, 72 and one trend study.28 Two were of good quality,36, 56 seven of fair quality,26, 30-32, 42, 69, 72 and forty of poor quality.12-13, 16, 27-29, 33-35, 37-41, 43, 45-55, 57-61, 63-68, 73, 77, 80

Where appropriate to specific harms, these studies are grouped according to co-administered agents given. The 49 studies include twenty studies of nitrous oxide administered as a sole analgesic agent;37-43, 45-48, 50, 55-60, 65, 72 seven studies of nitrous oxide administered with opioids;16, 49, 52, 61, 64, 66, 77 one study of nitrous oxide administered with another anesthetic gas;73 seven studies of nitrous oxide administered with opioids and sedatives or hypnotics;12-13, 51, 53-54, 63, 68 two studies of opioids and sedatives or hypnotics, or combination thereof;69, 80 and one of nitrous unspecified.67 Seven studies evaluated nitrous oxide as an occupational agent.26-32 Four case-control studies evaluated nitrous oxide use during labor as an independent risk factor.33-36

In the past, nitrous oxide for labor was co-administered with other analgesic, anesthetic, anxiolytic, and sedative agents in various combinations titrated to induce sedation and amnesia. These co-agents have a significant impact on the rate and degree of harms associated with nitrous oxide for labor analgesia. To maintain consistency with contemporary practice, thirteen studies published prior to 1980 in which nitrous oxide was given in combination with unspecified doses of narcotics, tranquilizers and sedatives are not included in the tables.12-13, 16, 50-54, 66-69, 80

### Detailed Synthesis

#### Maternal Harms

Thirty-two studies reported maternal harms related to nitrous oxide. The most clinically significant and frequently reported maternal harms were nausea, vomiting, dizziness, and drowsiness. These side effects are presented in Table 8. Within the table, studies are grouped by agent(s) administered. Studies of nitrous oxide as a sole agent are listed first, followed by nitrous/opioid, nitrous/other anesthetic, nitrous/opioid/sedatives, and nitrous/other anesthetic gases/opioids/sedatives or combinations thereof. Within each agent designation, RCTs are listed first followed by nonrandomized clinical trials and observational studies, and each group of study type is in reverse chronological order.

Table 8 Maternal adverse effects associated with nitrous oxide use during labor, side effects

Author Year Country Study Type | Intervention (N) | Nausea (%) | Vomiting (%) | Dizziness (%) | Drowsiness (%)
Talebi et al.,37 2009 Iran RCT | 50% nitrous in oxygen (260) | 8.4 | 2.3 | 23.0 | 8.3
Talebi et al.,37 2009 Iran RCT | 50% oxygen (249) | 0.0 | 0.0 | 0 | 0.0
Arora et al.,42 1992 U.K. RCT | Entonox (39) | NR | NR | 3.0 | NR
Arora et al.,42 1992 U.K. RCT | Entonox and 0.25% isoflurane (39) | 5.0 | NR | 10.0 | NR
Constantine et al.,46 1989 U.K. RCT | Entonox, via mask (49)^†^ | 45.0 | NR | NR | NR
Constantine et al.,46 1989 U.K. RCT | Entonox, via mask and humidifier (36)^†^ | 25.0 | NR | NR | NR
Constantine et al.,46 1989 U.K. RCT | Entonox, via mouthpiece (37)^†^ | 36.0 | NR | NR | NR
Constantine et al.,46 1989 U.K. RCT | Entonox, via mouthpiece and humidifier (27)^†^ | 41.0 | NR | NR | NR
Yeo et al.,38 2007 U.K. Crossover RCT | Entonox (22) | 28.0 | 14.0 | NR | 0.0
Yeo et al.,38 2007 U.K. Crossover RCT | Sevoflurane (22) | 3.0 | 0.0 | NR | 0.0
Westling et al.,43 1992 Sweden Crossover RCT | 40% nitrous oxide in oxygen, intermittent (24) | 0.0 | 0.0 | NR | NR
Westling et al.,43 1992 Sweden Crossover RCT | 70% nitrous oxide in oxygen, intermittent (24) | 0.0 | 0.0 | NR | NR
Westling et al.,43 1992 Sweden Crossover RCT | 40% nitrous oxide in oxygen, continuous (24) | 4.0 | 0.0 | NR | NR
Westling et al.,43 1992 Sweden Crossover RCT | Oxygen, intermittent (24) | 0.0 | 0.0 | NR | NR
McGuiness et al.,48 1984 U.K. Crossover RCT | 50% nitrous in oxygen (20) | 5.0 | NR | NR | NR
Paech,72 1991 Australia Cross-sectional | Nitrous oxide (220) | 13.0θ | 13.0θ | 5.0 | 4.0
Paech,72 1991 Australia Cross-sectional | Epidural (112) | 14.0θ | 14.0θ | 0.0 | 0.0
Paech,72 1991 Australia Cross-sectional | Pethidine (83) | 16.0θ | 16.0θ | 6.0 | 11.0
Paech,72 1991 Australia Cross-sectional | Non-pharmacological (140) | 0.0 | 0.0 | 0.0 | 0.0
Paech,72 1991 Australia Cross-sectional | Enflurane in air (20) | 15.0 | NR | NR | NR
McLeod et al.,47 1985 U.K. Prospective cohort | 50% nitrous oxide in oxygen (32) | 3.0 | NR | 6.0 | More drowsy with Entonox: 9.7
McLeod et al.,47 1985 U.K. Prospective cohort | 0.75% Isoflurane in oxygen (32) | 3.0 | NR | 0.0 | More drowsy with isoflurane: 58.1
Abboud et al.,49 1981 U.S. RCT | 30-60% nitrous in oxygen (50)^*^ | NR | 2.0 | NR | NR
Abboud et al.,49 1981 U.S. RCT | 0.25-1.25% Enflurane in oxygen (55)^*^ | NR | 0.0 | NR | NR
Soyannwo,64 1985 Nigeria Prospective cohort | Entonox (114) | NR | 4.0^ | NR | Mild: 66.7 Moderate: 31.6 Severe: 1.7
Soyannwo,64 1985 Nigeria Prospective cohort | Entonox with 100mg pethidine or pethilorphan (36) | NR | 4.0^ | NR | Mild: 55.6 Moderate: 44.4 Severe: 0.0

NR = not reported, RCT= randomized clinical trial

Note: Studies published prior to 1980 are not included in this table. Numerous studies did not provide the N for these outcomes; therefore, only percentages are reported in this table.

* Some patients used additional narcotics (meperidine or alphaprodine).

^ Results combined for entire study population.

† Some patients used pethidine.

θ Nausea and vomiting results combined.

In addition to the harms presented in Table 8, other infrequently reported maternal harms included restlessness,12-13, 16, 53-54, 66 dreams,12-13, 16, 53-54 dry mouth or nose,16, 37, 46, 51 tingling or pins and needles,37, 46 numbness,51 paresthesias,16 reduced awareness of experience,72 mask phobia,72 bothersome smell,51, 54 euphoria,51 and hiccups.51

Clinically relevant harms reported in included studies but not typically associated with nitrous oxide were backache and/or headache,56, 72, shivering,72 difficulty moving,72 and renal dysfunction.45, 49-50

Other findings associated with nitrous oxide of unknown clinical significance include inactivation of methionine synthase59 and effects on maternal circulation.37, 43

##### Nausea and Vomiting

Nausea and/or vomiting were reported in 17 studies,12-13, 16, 37-38, 42-43, 46-49, 51, 53-54, 64, 66, 68-69, 72 ten of which are presented in Table 8. In these ten studies, rates of nausea ranged from zero to 45 percent.

Studies in women receiving nitrous oxide as a sole agent reported nausea rates from zero to 28 percent.37-38, 42-43, 47-48, 64, 72 Three studies reported nausea data that include both nitrous oxide as a sole agent and an unmedicated control group.37, 43, 72 Nausea rates with nitrous oxide ranged from zero to 13 percent with no incidence of nausea in control groups. Nausea was reported to be more common with nitrous oxide than sevoflurane in a crossover RCT38 with a reported relative risk of 2.7 for nitrous oxide (p = 0.004). Nitrous oxide was associated with less nausea than enflurane in one study,48 and a comparable rate of nausea to isoflurane in another study.47 A cross-sectional study reported similar rates of nausea and vomiting with nitrous oxide (13%), epidural (14%), and pethidine (16%).72

Vomiting was reported in six studies presented in Table 8 with rates ranging from zero to 14 percent.37-38, 43, 49, 64, 72 Four studies using nitrous oxide as a sole agent reported vomiting data, with rates of 0 to 14 percent.37-38, 43, 72 Two studies addressed aspiration specifically.13, 49 One RCT reported no aspiration with one episode of vomiting in a woman receiving nitrous oxide.49 One nonrandomized trial reported no incidences of aspiration after vomiting in a series of 501 women receiving 50 to 80 percent nitrous oxide in conjunction with injected analgesics who had a combined nausea and vomiting rate of 15 to 22 percent across nitrous oxide concentrations.13

##### Dizziness and Lightheadedness

Dizziness was reported in seven studies,37, 42, 46-47, 51, 54, 72 four of which are presented in Table 8. In these four studies, nitrous oxide was used as a sole agent with rates of dizziness from three to 23 percent. One RCT reported lightheadedness with Entonox and found it was more common with a mouthpiece compared with face mask.46 Overall, 58 percent of women in the study had lightheadedness with Entonox, which some women were using in conjunction with pethidine.

##### Drowsiness and Sleepiness

Thirteen studies reported drowsiness,12, 16, 37-38, 47-48, 51, 54, 61, 64, 66, 72-73 of which six have outcomes presented in Table 8. Four studies reported drowsiness incidence rates of zero to 67 percent with nitrous oxide used as a sole agent.37-38, 64, 72 Two studies reported drowsiness data based upon a visual analog scale and do not report incidence rates.47-48 Three studies compared drowsiness reported with nitrous oxide with other inhalational anesthetic gases and found drowsiness with nitrous oxide was equal to sevoflurane38 and less than with isoflurane47 or enflurane.48 A cross-sectional study found nitrous oxide caused more drowsiness than epidural but less than pethidine.72

Sleepiness or sleep was reported as a side effect in older studies utilizing sedative analgesia.12, 53-54, 66 No studies reported sleepiness as an outcome for nitrous oxide administered as a sole agent.

##### Unconsciousness

Unconsciousness data were reported in eight studies, including one in which nitrous was the sole agent,43 three with nitrous/opioid,16, 64, 66 three with nitrous/opioid/sedatives,12-13, 53and one with nitrous/other anesthetic gas.73 Studies published prior to 1980 report low rates (0-1%) of unconsciousness with sedative polypharmacy.12-13, 53, 66, 73 In a study of 150 women, one woman became unconscious while breathing Entonox in conjunction with use of analgesics. No instances of unconsciousness were reported in a study of Entonox with and without continuous nitrous oxide supplement via nasal cannula,16 and a study of women breathing up to 70 percent concentrations of nitrous oxide.43

##### Amnesia and Hazy Memory of Labor

Amnesia or hazy memory of labor or birth was addressed in nine studies.12-13, 16, 40, 45, 49, 53-54, 68 Overall rates of amnesia ranged from zero to 16 percent.40, 45, 49, 68 Studies published since 1980 reported low to nonexistent rates of amnesia. In an RCT published in 1981, 10 percent of women receiving 30 to 60 percent nitrous oxide with narcotics reported amnesia for birth.49 In two subsequent RCTs, none of the women who used nitrous oxide reported amnesia.40, 45

Hazy memory of labor and birth was an outcome reported in older studies, and incidence ranged from eight to 60 percent.12-13, 16, 53 Hazy memory of labor was not reported as an outcome in any studies published since 1980.

##### Hypoxia, Maternal Oxygen Saturation, and Diffusion Hypoxia

Hypoxia and/or maternal oxygen saturation was reported as an outcome in eight studies.38-39, 41, 57, 60-61, 77 Hypoxia was not defined or inconsistently defined,39, 41, 57, 77 and studies reporting oxygen saturation values were inconsistent in their reporting of mean, median, and average values. Where desaturations were reported, they occurred in all groups studied including control (no analgesia) and epidural.57, 60, 77

In a crossover placebo-controlled RCT, comparable rates of desaturation occurred in women receiving nitrous oxide and compressed air.41 In another crossover RCT, there were no oxygen saturations less than 98 percent in women breathing Entonox or sevoflurane alone.38 Hypoxic episodes exceeding 10 seconds to saturations less than 90 percent occurred at similar rates for all groups in a case series including women using nitrous oxide, nitrous oxide with pethidine, pethidine only, and epidural.77 Maternal saturations did not differ between groups in an RCT comparing 50 and 70 percent nitrous oxide.39 Median maternal oxygen saturation was not statistically different between Entonox and control in a prospective cohort study.57 In another prospective cohort study, there were no significant difference in saturations between women using 50 percent nitrous oxide, epidural, pethidine, or no analgesia.60 The same study found a significant decrease in maternal saturations in women breathing nitrous oxide 50 percent with co-administration of pethidine compared with women in the control group (p < 0.05). The difference in mean lowest oxygen saturations between women receiving nitrous oxide with meperidine compared with peridural anesthesia was significant for primiparous, but not multiparous, women.61

Three studies evaluated diffusion hypoxia.16, 39, 41 Women who used nitrous oxide had no evidence of diffusion hypoxia when compared with a control group based upon analysis of end tidal nitrous oxide and carbon dioxide.39 Maternal end tidal nitrous oxide levels were assessed in a study of women breathing Entonox with and without a continuous supplement of nitrous oxide 50 percent via nasal cannula. Mean end tidal nitrous oxide levels were 14.8 percent in between contractions, and mean maximum end tidal nitrous oxide concentrations were 44 percent for all women.16 There was no evidence of diffusion hypoxia in a study of nitrous oxide compared with compressed air.41

##### Effects on Maternal Circulation

In a crossover RCT, nitrous oxide was reported to cause a clinically insignificant but statistically significant decrease in heart rate, cardiac output, and arterial pressure and increase in stroke volume (p < 0.01 for all) in laboring women while breathing nitrous oxide at 70 percent concentration compared with control (oxygen only).43

##### Biochemical Findings

Inhalational anesthetic gases have been associated with renal dysfunction. There was no significant difference in renal function indices in an RCT of women using methoxyflurane or nitrous oxide.50 In another RCT comparing nitrous oxide with enflurane, serum electrolyte levels and renal function were not significantly affected.49 Maternal and neonatal fluoride levels were assessed in an RCT comparing nitrous with isoflurane and were comparable.45

##### Inactivation of Methionine Synthase

The use of nitrous oxide by inhalation has been shown to inactivate methionine synthase activity (MSA) by binding to cobalamin, which is the central component of vitamin B12. Clinical implications of inactivation of methionine synthase have not been established. Landon measured methionine synthase in placental samples reporting a negative correlation between placental MSA and duration of exposure to nitrous oxide (p = 0.01).59 There was a more rapid decrease in MSA in women with reduced B12 levels, although the regression coefficients were not significantly different.

##### Restlessness

Restlessness was reported in six studies, including two with nitrous/opioid16, 66 and four with nitrous/opioid/sedatives.12-13, 53-54 No studies reporting restlessness included a group receiving nitrous oxide as a sole agent. All studies reporting restlessness data were published prior to 1980. Reported rates of restlessness for nitrous oxide with opioids with or without sedatives ranged from 5 percent to 59 percent.

##### Dreams

Dreams were reported in five studies,12-13, 16, 53-54 including four with nitrous/opioid/sedatives12-13, 53-54 and one with nitrous/opioid.16 All studies reporting dreams as a harm were published prior to 1980, and dreams were not reported in any studies of nitrous as a sole agent. Dreams were reported at rates of 10 percent to 26 percent of women breathing nitrous in combination with analgesic and sedative agents.

##### Other Maternal Side Effects

Dry mouth or nose was reported in four studies.16, 37, 46, 51 One study of nitrous oxide as a sole agent reported a rate of 8.3 percent for dry mouth in women breathing nitrous oxide alone.37 In one RCT dry mouth and nose were found to be more common with use of a mask compared with mouthpiece, and incidence was lowered by use of a humidifier.46 Dry nose was reported by 75 percent of women breathing nitrous oxide via nasal cannula in one study.16

In a crossover RCT, women reported a rate of dry mouth of 10 percent while using nitrous oxide combined with narcotics and sedatives.51

Tingling or “pins and needles” was reported in two RCTs with rates of 4.1 percent37 and 25 percent46 in women using nitrous oxide. In a crossover RCT, 1.6 percent of women using nitrous oxide reported numbness. In a prospective cohort study, 40 percent of women breathing Entonox alone and 33 percent of women breathing Entonox with a continuous supplement of nitrous oxide 50 percent via nasal cannula experienced paresthesia.

In a cross-sectional study, reduced awareness of experience was more frequently reported as a disliked side effect for nitrous (18%) and pethidine (16%) than epidural (2%) and control (zero).72

Backache and/or headache were reported in two studies.56, 72 In one prospective cohort study, women receiving epidural analgesia had a 3.6 percent incidence of spinal headache and 3.6 percent rate of persistent backache compared with zero incidence in women using nitrous oxide.56 No women in a cross-sectional study who used nitrous oxide reported back pain compared with 14 percent of those with an epidural.

Shivering was not reported as a side effect by women using nitrous oxide compared with eight percent of women receiving an epidural in a cross-sectional study.72

Fourteen percent of women with epidural analgesia reported difficulty moving as a disliked side effect compared with none of the women using nitrous oxide.72 Other side effects infrequently reported include mask phobia,72 bothersome smell,51, 54 euphoria,51 and hiccups.51

#### Fetal and Neonatal Harms

Twenty-nine studies include outcomes on fetal and neonatal harms. The most clinically significant and frequently reported outcomes for fetal harms were umbilical cord gases and Apgar scores, which are presented in Tables 9, 10, and 11. Studies are presented in reverse chronological order. Additional fetal and neonatal outcomes reported include placental transfer of nitrous oxide, assessment of neurobehavioral status, neonatal fluoride levels, and long-term outcomes.

Table 9 Fetal adverse effects, cord blood gases^*^

Author Year Country Study Type | Intervention (N) | Umbilical pH, Arterial | Umbilical pH, Venous | Base Excess, Arterial | Base Excess, Venous
Abboud et al.,45 1989 U.S. RCT | 30-60% nitrous oxide in oxygen (30) | 7.27 | 7.33 | -2.2 | -2.8
Abboud et al.,45 1989 U.S. RCT | 0.2-0.7% Isoflurane in oxygen (30) | 7.28 | 7.34 | -3.0 | -3.0
Deckhart et al.,61 1987 Germany Prospective cohort | 50% nitrous oxide in oxygen with meperidine (16 primip, 9 multip) | Primip:7.21^ Multip: 7.31 | NR | Primip: -9.5 Multip: -5.1 | NR
Deckhart et al.,61 1987 Germany Prospective cohort | Epidural (25 primip) | 7.29^ | NR | -6.4 | NR
Abboud et al.,49 1981 U.S. RCT | 30-60% nitrous oxide in oxygen (50) | 7.27 | 7.27 | -7.0 | -5.6
Abboud et al.,49 1981 U.S. RCT | 0.25-1.25% Enflurane in oxygen (55) | 7.26 | 7.34 | -6.3 | -6.3

multip = multiparous, NR = not reported, primip - primiparous, RCT = randomized controlled trial

Note: Studies published prior to 1980 are not included in this table.

* Umbilical pH < 7 and base deficit ≥ 12 indicate metabolic acidosis. Arterial values are the most accurate.81

^ Significant (p = 0.L01)

Table 10 Neonatal adverse effects, mean and median Apgar scores

Author Year Country Study Type | Intervention (N) | 1 Min, Mean | 5 Min, Mean | 10 Min, Mean | 1 Min, Median
Talebi et al.,37 2009 Iran RCT | 50% nitrous oxide in oxygen (260) | 8.5 | 9.5 | NR | NR
Talebi et al.,37 2009 Iran RCT | 50% oxygen (249) | 8.5 | 9.5 | NR | NR
Stirk et al.,55 2002 U.K. Prospective cohort | Entonox (45) | 8.2 | 9.6 | NR | NR
Stirk et al.,55 2002 U.K. Prospective cohort | Morphine (70) | 8.3 | 9.4 | NR | NR
Ross et al.,73 1999 U.K. Case series | 50% nitrous oxide in oxygen with 0.25% isoflurane (48) | NR | NR | NR | 9.0
Ross et al.,73 1999 U.K. Case series | 50% nitrous oxide in oxygen with 0.25% isoflurane; narcotic given > 5 hours before delivery (85) | NR | NR | NR | 9.0
Ross et al.,73 1999 U.K. Case series | 50% nitrous oxide in oxygen with 0.25% isoflurane, narcotic given < 5 hours before delivery (88) | NR | NR | NR | 8.0
Ross et al.,73 1999 U.K. Case series | Nitrous oxide stopped < 1 hour before delivery (174) | NR | NR | NR | 9.0
Ross et al.,73 1999 U.K. Case series | Nitrous oxide stopped > 1 hour before delivery (47) | NR | NR | NR | 9.0
Westling et al.,43 1992 Sweden Crossover RCT | 40% intermittent nitrous oxide in oxygen (24) | 9.2 (all groups) | 10.0 (all groups) | 10.0 (all groups) | NR
Westling et al.,43 1992 Sweden Crossover RCT | 70% intermittent nitrous oxide in oxygen (24) | 9.2 (all groups) | 10.0 (all groups) | 10.0 (all groups) | NR
Westling et al.,43 1992 Sweden Crossover RCT | 40% continuous nitrous oxide in oxygen (24) | 9.2 (all groups) | 10.0 (all groups) | 10.0 (all groups) | NR
Westling et al.,43 1992 Sweden Crossover RCT | Intermittent oxygen only (24) | 9.2 (all groups) | 10.0 (all groups) | 10.0 (all groups) | NR
Landon et al.,59 1992 U.K. Prospective cohort | Entonox for vaginal delivery (45) | 8.5 | 9.3 | NR | NR
Landon et al.,59 1992 U.K. Prospective cohort | Vaginal delivery without Entonox (13) | 8.5 | 9.4 | NR | NR
Landon et al.,59 1992 U.K. Prospective cohort | Epidural for cesarean section (13) | 8.1 | 9.0 | NR | NR
Landon et al.,59 1992 U.K. Prospective cohort | Cesarean section with general anesthesia and nitrous oxide (23) | 7.5 | 9.3 | NR | NR
Deckardt et al.,61 1987 Germany Prospective cohort | 50% nitrous oxide in oxygen with meperidine (25) | 8.1 | 9.7 | 10.0 | NR
Deckardt et al.,61 1987 Germany Prospective cohort | Epidural (25) | 8.9 | 10.0 | 10.0 | NR
Arthurs et al.,16 1979 U.K. Prospective cohort | 50% nitrous oxide in oxygen intermittent with continuous nitrous 50% via nasal cannula^*^ (24) | 7.8 | 9.6 | NR | NR
Arthurs et al.,16 1979 U.K. Prospective cohort | 50% nitrous oxide in oxygen, intermittent^*^ (25) | 7.7 | 9.3 | NR | NR

NR = not reported, RCT = randomized controlled trial

Note: No studies reported 5 or 10 minute median Apgar scores.

* Some participants used pethidine and/or epidural

Table 11 Neonatal adverse effects, range of Apgar scores

Author Year Country Study Type | Intervention (N) | 8-10, 1 Min (%) | <8, 1 Min (%) | 8-10, 5 Min (%) | <8, 5 Min (%)
Leong et al.,56 2000 Malaysia Prospective cohort | Entonox with pethidine (68) | NR | NR | 100 | 0
Leong et al.,56 2000 Malaysia Prospective cohort | Epidural (55) | NR | NR | 100 | 0
Ross et al.,73 1999 U.K. Case series | 50% nitrous oxide in oxygen with 0.25% isoflurane (48) | 83^*^ | 17.6^*^ | 97.3 | 2.7
Ross et al.,73 1999 U.K. Case series | 50% nitrous oxide in oxygen with 0.25% isoflurane; narcotic given > 5 hours before delivery (85) | 69 | 31 | NR | NR
Ross et al.,73 1999 U.K. Case series | 50% nitrous oxide in oxygen with 0.25% isoflurane, narcotic given < 5 hours before delivery (88) | 55 | 46 | NR | NR
Ross et al.,73 1999 U.K. Case series | Nitrous oxide stopped < 1 hour before delivery (174) | 67 | 33 | NR | NR
Ross et al.,73 1999 U.K. Case series | Nitrous oxide stopped > 1 hour before delivery (47) | 67^*^ | 36^*^ | NR | NR
Abboud et al.,40 1995 U.S. RCT | 30-60% nitrous oxide in oxygen (40) | 92 | 8 | 100 | 0
Abboud et al.,40 1995 U.S. RCT | 1-4.5% desflurane in oxygen (40) | 87 | 13 | 100 | 0
Ranta et al.,58 1994 Finland Prospective cohort | 50% nitrous oxide in oxygen (210) | 93 | 7 | 99 | 1
Ranta et al.,58 1994 Finland Prospective cohort | Water block (69) | 90 | 10 | 97 | 3
Ranta et al.,58 1994 Finland Prospective cohort | IM pethidine (50) | 91 | 9 | 100 | 0
Ranta et al.,58 1994 Finland Prospective cohort | Paracervical block (128) | 97 | 3 | 97 | 3
Ranta et al.,58 1994 Finland Prospective cohort | Epidural (82) | 94 | 6 | 96 | 4
Ranta et al.,58 1994 Finland Prospective cohort | Several forms of analgesia (339) | 94 | 6 | 97 | 3
Ranta et al.,58 1994 Finland Prospective cohort | No analgesia (213) | 89 | 11 | 99 | 1
Abboud et al.,45 1989 U.S. RCT | 30-60% nitrous oxide in oxygen (30) | 93 | 7 | 100 | 0
Abboud et al.,45 1989 U.S. RCT | 0.2-0.7% isoflurane in oxygen (30) | 93 | 7 | 100 | 0
Murphy et al.,65 1984 U.K. Retrospective cohort | Entonox, born 1970-1974 (3,697) | 87.8 | 12.3 | NR | NR
Murphy et al.,65 1984 U.K. Retrospective cohort | Entonox, born 1975-1979 (4,448) | 89.9 | 10.1 | NR | NR
Murphy et al.,65 1984 U.K. Retrospective cohort | Entonox and pethidine, born 1970-1974 (12,084) | 78.5 | 21.5 | NR | NR
Murphy et al.,65 1984 U.K. Retrospective cohort | Entonox and pethidine, born 1975-1979 (85,860) | 78.8 | 21.2 | NR | NR
Murphy et al.,65 1984 U.K. Retrospective cohort | Pethidine, born 1970-1975 (2,770) | 74.4 | 25.6 | NR | NR
Murphy et al.,65 1984 U.K. Retrospective cohort | Pethidine, born 1975-1979 (874) | 80.3 | 19.7 | NR | NR
Murphy et al.,65 1984 U.K. Retrospective cohort | Epidural, born 1970-1974 (1,223) | 74.5 | 25.4 | NR | NR
Murphy et al.,65 1984 U.K. Retrospective cohort | Epidural, born 1975-1979 (3,084) | 82.0 | 18.0 | NR | NR
Murphy et al.,65 1984 U.K. Retrospective cohort | No analgesia, born 1970-1974 (1,508) | 86.1 | 13.8 | NR | NR
Murphy et al.,65 1984 U.K. Retrospective cohort | No analgesia, born 1975-1979 (852) | 90.0 | 10.0 | NR | NR
Abboud et al.,49 1981 U.S. RCT | 30-60% nitrous oxide in oxygen (50) | 94 | 6 | 100 | 0
Abboud et al.,49 1981 U.S. RCT | 0.25-1.25% enflurane in oxygen (55) | 92 | 8 | 98 | 2

NR = not reported, RCT = randomized controlled trial

* As reported by publication; percentages do not tally to 100.

Neonatal intensive care unit (NICU) admission rates cannot be accurately reported because different countries vary in their definition of what constitutes a high acuity ward, and rates were not consistently reported. Three studies reported admission to a special care nursery56, 73 or neonatal unit.55 Other reported harms that suggest the need for NICU care included fetal resuscitation,64, 73 asphyxia,67 depressed babies,49 sleepy babies,67 prolonged time to sustained respiration,80 and treatment for apnea.73

##### Umbilical Arterial and Venous Blood Gases

Umbilical cord blood gases were reported in eight studies. Three of these reported neonatal outcomes presented in Table 9.^45, 49, 61^ The only significant finding was a lower mean umbilical artery pH in primiparous women who used nitrous oxide and meperidine compared with epidural (p = 0.01).61 The remaining five studies were excluded from the table because they reported data prior to 1980 with unspecified co-administration of narcotics and sedatives in all groups52, 68-69 or did not report actual cord blood gas values.40, 58

##### Apgar Scores

The Apgar score is used to assess the general condition of a newborn at 1 minute and 5 minutes after birth. A score of 0, 1, or 2 is given for each of five categories: heart rate, breathing effort, muscle tone, reflex response, and color. The highest possible score is 10, and a 5-minute score of 7 to 10 is considered normal.82 Pharmacologic labor pain management methods can affect the Apgar score.

Twenty-five studies reported Apgar score data,12-13, 16, 37, 40, 43, 45, 49, 51-56, 58-59, 61, 64-69, 73, 80 and 12 of these are presented in Tables 10 and 11. Studies that reported mean and/or median Apgar scores are presented in Table 10 while Table 11 presents studies that reported categorical Apgar scores (i.e., 8-10 and < 8). None of the studies reported in Tables 10 and 11 found significant differences in Apgar scores with nitrous oxide compared with other pain management methods or no labor analgesia. Apgar data were not included in table format for studies conducted prior to 1980 in which nitrous oxide was co-administered with unspecified and uncontrolled narcotics and/or sedatives. Two other studies were excluded from the table, one because neither treatment nor control group could be defined in terms of analgesia given83 and the other because the timing of the Apgar scores was not defined.64

##### Assessment of Neonatal Neurobehavioral Status

Neurobehavioral status has been studied in four studies using a variety of assessment tools.40, 45, 63, 67 Only one study compared newborns of women using nitrous oxide with a control group.63 In this prospective cohort study, neonates of mothers receiving a variety of analgesic agents in labor were evaluated with the Neonatal Psychological Assessment profile. Neonatal scores with Entonox were comparable with all other methods, including epidural, pethidine, TENS, and no analgesia. Neonatal Adaptive Capacity Scores (NACS) at 2 and 24 hours did not differ significantly between newborns whose mothers used nitrous oxide and desflurane.40 In another RCT, there were no significant differences in test item scores on the NACS between the nitrous oxide group and isoflurane group.45 One study reported Perez and Moro reflexes became positive more rapidly in newborns after maternal administration of nitrous oxide compared with trichloroethylene and halothane (no test of statistical significance reported).67

##### Long-Term Harms

Long-term offspring outcomes were addressed in four studies.33-36 All studies reporting long-term outcomes were retrospective; no prospective studies with regard to long-term harms were identified. Three poor-quality case-control studies from Sweden conducted by the same investigators with overlapping populations have investigated nitrous oxide use during labor and later addiction in offspring.33-35 One of these studies reported a risk ratio of 5.6 (95% CI 1.6 to16.9, p = 0.005) for amphetamine addiction after greater than 4.5 hours of nitrous oxide exposure in utero compared with less than 0.25 hours; however, many participants had missing data and women used pure nitrous oxide rather than a mix with oxygen as is current practice.35 The fourth case-control study investigated possible risk factors for childhood leukemia reporting an increased risk for all leukemias with in utero exposure to nitrous oxide (odds ratio 1.3, 95% CI 1.0 to 1.6), although the risk was not observed in all subgroups.36

#### Occupational Exposure

Occupational exposure in labor and birth settings was addressed in seven studies.26-32 Three of these were Swedish studies that examined occupational exposure related harms in midwives.27-29 One study focused on subfertility and found a decreased fecundability ratio in midwives who attended more than 30 births per month in which nitrous oxide was used (0.63, 95% CI 0.43 to 0.94).28 Another study reported no increased risk of spontaneous abortion with nitrous oxide exposure.29 In the third study, women exposed to nitrous oxide had newborns with reduced birth weight (-77 grams, 95% CI -129 to -24) and an increase in odds for small for gestational age (odds ratio 1.8, 95 % CI 1.1 to 2.8).27

The measurement of nitrous oxide exposure is addressed in four studies, which report nitrous oxide levels but not specific harms.26, 30-32 A study in the United Kingdom collected data on midwives wearing exposure badges for 242 shifts in labor wards without scavenging and with standard room ventilation only.32 Shifts ranged from 7.5 to 11 hours. Midwives had exposure greater than 100 ppm (the Swedish limit) during 23 percent of shifts and greater than 25 ppm (the U.S. limit) during 53 percent of shifts. An evaluation of scavenging systems in Swedish labor wards found a 4-fold reduction in nitrous oxide levels with use of efficient scavenging systems. Nitrous oxide concentrations in diffusive air samplers varied from 2.5 to 260 mg/m3, and mean 8-hour time-weighted averages were 17mg/m3 for midwives and 42mg/m3 for assistant midwives.30 The 8-hour-time-weighted-averages exceeded the American Conference of Industrial Hygienists' average threshold limit value (50 ppm or 90 mg/m3) in 16 percent of midwives and 45 percent of assistant midwives. The authors attribute these differences to the fact that assistant midwives have a longer average exposure time and are also working more closely with women earlier in labor when nitrous oxide is used more frequently.30 Another study in the United Kingdom correlated nitrous oxide exposure to urine nitrous oxide levels in a descriptive study of unscavenged and poorly-ventilated delivery suites.26 Environmental levels exceeded 100 ppm over 8-hour time-weighted averages in 35 of 46 midwife shifts monitored. It is notable that in this study 22 of 46 midwives had nonzero baseline values of nitrous oxide in their urine, which the authors propose may indicate tissue clearance occurs over a longer time period than previously thought. Newton et al evaluated 8-hour time-weighted average nitrous oxide exposure (in ppm) for 15 midwives at a newly built English hospital with a ventilation system incorporating six to ten air changes per hour, comparing the results with historical data from an older building in which ventilation did not exist (Entonox machines were unscavenged in both hospitals).31 Levels in the new hospital were significantly lower, and none of the 15 midwives in the new hospital was exposed to levels of nitrous oxide greater than 100 ppm. Six of the 15 midwives were exposed to levels of nitrous oxide greater than 25 ppm (the U.S. limit).

## KQ5 Effects of Provider and Health System Factors

No studies addressed KQ5. It is discussed as a part of future research.

## Grey Literature Search Results

Grey literature search methods are described in the Methods chapter of this review. No relevant articles were located.