# References and Included Studies

1 Martin JA, Hamilton BE, Sutton PD, et al. Births: Final Data for 2008. National Vital Statistics Reports. Released. December. 8. 2010;59(1):1-72. [pmid: 22145497].
2 Marmor TR, Krol DM. Labor pain management in the United States: understanding patterns and the issue of choice. Am J Obstet Gynecol. May. 2002;186(5 Suppl Nature):S173-80. [pmid: 12011881].
3 Declercq ER, Sakala C, Corry MP, et al. Listening to Mothers II: Report of the Second National US Survey of Women's Childbearing Experiences. New York. Childbirth Connection. 2006.
4 Rosen MA. Nitrous oxide for relief of labor pain: A systematic review. Am J Obst Gynecol. 2002;186(5 SUPPL):S110-S126. [pmid: 12011877].
5 Irestedt L. Current status of nitrous oxide for obstetric pain relief. Acta Anaesthesiol Scand. Nov. 1994;38(8):771-2. [pmid: 7887095].
6 Oyston J. Obstetrical anaesthesia in Ontario. Can J Anaesth. Dec. 1995;42(12):1117-25. [pmid: 8595688].
7 Bishop JT. Administration of nitrous oxide in labor: expanding the options for women. J Midwifery Womens Health. May-Jun. 2007;52(3):308-9. [pmid: 17467598].
8 Smith WD. A history of nitrous oxide and oxygen anaesthesia. I. Br J Anaesth. 1965;37(10):790-798. [pmid: 5321332].
9 Fujinaga M, Maze M. Neurobiology of nitrous oxide-induced antinociceptive effects. Mol Neurobiol. Apr. 2002;25(2):167-89. [pmid: 11936558].
10 Sanders RD, Weimann J, Maze M. Biologic effects of nitrous oxide: a mechanistic and toxicologic review. Anesthesiology. Oct. 2008;109(4):707-22. [pmid: 18813051].
11 Camann W, Alexander K. Easy labor: Every woman's guide to choosing less pain and more joy during childbirth. New York. Ballantine Books. 2007.
12 Clinical trials of different concentrations of oxygen and nitrous oxide for obstetric analgesia. Report to the Medical Research Council of the Committee on Nitrous Oxide and Oxygen Analgesia in Midwifery. Br Med J. Mar. 21. 1970;1(5698):709-13. [pmid: 5440545].
13 McAneny T, Doughty A. Self-administered nitrous-oxide/oxygen analgesia in obstetrics. Anaesthesia. 1963. 1963;18(4):488-497. [pmid: 14071377].
14 Rooks JP. Safety and risks of nitrous oxide labor analgesia: A review. J Midwifery Womens Health. 2011;56(6):557-565. [pmid: 22060215].
15 Arthurs GJ, Rosen M. Acceptability of continuous nasal nitrous oxide during labour--a field trial in six maternity hospitals. Anaesthesia. Apr. 1981;36(4):384-8. [pmid: 7246989].
16 Arthurs GJ, Rosen M. Self-administered intermittent nitrous oxide analgesia for labour. Enhancement of effect with continuous nasal inhalation of 50 per cent nitrous oxide (Entonox). Anaesthesia. Apr. 1979;34(4):301-9. [pmid: 378022].
17 Osterman MJ, Martin JA. Epidural and spinal anesthesia use during labor: 27-state reporting area, 2008. Natl Vital Stat Rep. Apr. 6. 2011;59(5):1-13, 16.
18 Anim-Somuah M, Smyth RM, Jones L. Epidural versus non-epidural or no analgesia in labour. Cochrane Database Syst Rev. 2011;12:CD000331. [pmid: 22161362].
19 Anim-Somuah M, Smyth R, Howell C. Epidural versus non-epidural or no analgesia in labour. Cochrane Database Syst Rev. 2005;(4):CD000331. [pmid: 16235275].
20 Hawkins JL. Epidural analgesia for labor and delivery. N Engl J Med. 2010;362(16):1503-1510. [pmid: 20410515].
21 From the American College of Nurse-Midwives. Nitrous oxide for labor analgesia. J Midwifery Womens Health. May-Jun. 2010;55(3):292-6. [pmid: 20437663].
22 Juni P, Holenstein F, Sterne J, et al. Direction and impact of language bias in meta-analyses of controlled trials: empirical study. Int J Epidemiol. Feb. 2002;31(1):115-23. [pmid: 11914306].
23 Higgins JPT, Altman DG, Sterne JAC. Chapter 8: Assessing risk of bias in included studies. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. (updated March 2011). The Cochrane Collaboration. 2011.
24 Wells GA, Shea B, O'Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. www.ohri.ca/programs/clinical_epidemiology/oxford.asp.
25 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville. AHRQ Publication. 2011. [updated 2011; cited]; 10: www.effectivehealthcare.ahrq.gov/methodsguide.cfm.
26 Henderson KA, Matthews IP, Adisesh A, et al. Occupational exposure of midwives to nitrous oxide on delivery suites. Occup Environ Med. Dec. 2003;60(12):958-61. [pmid: 14634189].
27 Bodin L, Axelsson G, Ahlborg G Jr. The association of shift work and nitrous oxide exposure in pregnancy with birth weight and gestational age. Epidemiology. Jul. 1999;10(4):429-36. [pmid: 10401879].
28 Ahlborg G Jr., Axelsson G, Bodin L. Shift work, nitrous oxide exposure and subfertility among Swedish midwives. Int J Epidemiol. Aug. 1996;25(4):783-90. [pmid: 8921457].
29 Axelsson G, Ahlborg G Jr., Bodin L. Shift work, nitrous oxide exposure, and spontaneous abortion among Swedish midwives. Occup Environ Med. Jun. 1996;53(6):374-8. [pmid: 8758031].
30 Westberg H, Egelrud L, Ohlson CG, et al. Exposure to nitrous oxide in delivery suites at six Swedish hospitals. Int Arch Occup Environ Health. 2008;81(7):829-836. [pmid: 17952690].
31 Newton C, Fitz-Henry J, Bogod D. The occupational exposure of midwives to nitrous oxide - a comparison between two labour suites. Int J Obstet Anesth. Jan. 1999;8(1):7-10. [pmid: 15321169].
32 Mills GH, Singh D, Longan M, et al. Nitrous oxide exposure on the labour ward. Int J Obstet Anesth. Jul. 1996;5(3):160-4. [pmid: 15321342].
33 Nyberg K, Allebeck P, Eklund G, et al. Socio-economic versus obstetric risk factors for drug addiction in offspring. Br J Addict. Dec. 1992;87(12):1669-76. [pmid: 1490081].
34 Jacobson B, Nyberg K, Gronbladh L, et al. Opiate addiction in adult offspring through possible imprinting after obstetric treatment. BMJ. Nov. 10. 1990;301(6760):1067-70. [pmid: 2249068].
35 Jacobson B, Nyberg K, Eklund G, et al. Obstetric pain medication and eventual adult amphetamine addiction in offspring. Acta Obstet Gynecol Scand. 1988;67(8):677-82. [pmid: 3250180].
36 Zack M, Adami HO, Ericson A. Maternal and perinatal risk factors for childhood leukemia. Cancer Res. Jul. 15. 1991;51(14):3696-701. [pmid: 2065325].
37 Talebi H, Nourozi A, Jamilian M, et al. Entonox for labor pain: a randomized placebo controlled trial. Pak J Biol Sci. Sep. 1. 2009;12(17):1217-21. [pmid: 19943458].
38 Yeo ST, Holdcroft A, Yentis SM, et al. Analgesia with sevoflurane during labour: ii. Sevoflurane compared with Entonox for labour analgesia. Br J Anaesth. Jan. 2007;98(1):110-5. [pmid: 17158129].
39 Einarsson S, Stenqvist O, Bengtsson A, et al. Gas kinetics during nitrous oxide analgesia for labour. Anaesthesia. May. 1996;51(5):449-52. [pmid: 8694158].
40 Abboud TK, Swart F, Zhu J, et al. Desflurane analgesia for vaginal delivery. Acta Anaesthesiol Scand. Feb. 1995;39(2):259-61. [pmid: 7793195].
41 Carstoniu J, Levytam S, Norman P, et al. Nitrous oxide in early labor. Safety and analgesic efficacy assessed by a double-blind, placebo-controlled study. Anesthesiology. Jan. 1994;80(1):30-5. [pmid: 8291726].
42 Arora S, Tunstall M, Ross J. Self-administered mixture of Entonox and isoflurane in labour. Int J Obstet Anesth. Sep. 1992;1(4):199-202. [pmid: 15636826].
43 Westling F, Milsom I, Zetterstrom H, et al. Effects of nitrous oxide/oxygen inhalation on the maternal circulation during vaginal delivery. Acta Anaesthesiol Scand. Feb. 1992;36(2):175-81. [pmid: 1549939].
44 Chia YT, Arulkumaran S, Chua S, et al. Effectiveness of transcutaneous electric nerve stimulator for pain relief in labour. Asia Oceania J Obstet Gynaecol. Jun. 1990;16(2):145-51. [pmid: 2378593].
45 Abboud TK, Gangolly J, Mosaad P, et al. Isoflurane in obstetrics. Anesth Analg. Mar. 1989;68(3):388-91. [pmid: 2919779].
46 Constantine G, Luesley DM, O'Connor A, et al. The use of Entonox in conjunction with a rebreathing humidifier. JObstet Gynaecol. 1989;10(1):23-25.
47 McLeod DD, Ramayya GP, Tunstall ME. Self-administered isoflurane in labour. A comparative study with Entonox. Anaesthesia. May. 1985;40(5):424-6. [pmid: 4014617].
48 McGuinness C, Rosen M. Enflurane as an analgesic in labour. Anaesthesia. Jan. 1984;39(1):24-6. [pmid: 6696214].
49 Abboud TK, Shnider SM, Wright RG, et al. Enflurane analgesia in obstetrics. Anesth Analg. Mar. 1981;60(3):133-7. [pmid: 7193989].
50 Rosen M, Latto P, Asscher AW. Kidney function after methoxyflurane analgesia during labour. Br Med J. Jan. 8. 1972;1(5792):81-3. [pmid: 5007074].
51 Bergsjo P, Lindbaek E. Comparison between nitrous oxide and methoxyflurane for obstetrical analgesia. Acta Obstet Gynecol Scand. 1971;50(3):285-90. [pmid: 4942713].
52 Phillips TJ, Macdonald RR. Comparative effect of pethidine, trichloroethylene, and Entonox on fetal and neonatal acid-base and PO2. Br Med J. Sep. 4. 1971;3(5774):558-60. [pmid: 5571451].
53 Jones PL, Rosen M, Mushin WW, et al. Methoxyflurane and nitrous oxide as obstetric analgesics. II. A comparison by self-administered intermittent inhalation. Br Med J. Aug. 2. 1969;3(5665):259-62. [pmid: 4895339].
54 Jones PL, Rosen M, Mushin WW, et al. Methoxyflurane and nitrous oxide as obstetric analgesics. I. A comparison by continuous administration. Br Med J. Aug. 2. 1969;3(5665):255-9. [pmid: 4895338].
55 Stirk P, Staines J, Brown DW. Maternal diamorphine administration during labour: the effect on neonate admissions to NNU. J Neonatal Nurs. 2002;8(2):56-7.
56 Leong EW, Sivanesaratnam V, Oh LL, et al. Epidural analgesia in primigravidae in spontaneous labour at term: a prospective study. J Obstet Gynaecol Res. Aug. 2000;26(4):271-5. [pmid: 11049237].
57 Arfeen Z, Armstrong PJ, Whitfield A. The effects of Entonox and epidural analgesia on arterial oxygen saturation of women in labour. Anaesthesia. Jan. 1994;49(1):32-4. [pmid: 8311209].
58 Ranta P, Jouppila P, Spalding M, et al. Parturients' assessment of water blocks, pethidine, nitrous oxide, paracervical and epidural blocks in labour. International Journal of Obstetric Anesthesia. 1994;3(4):193-198. [pmid: 15636949].
59 Landon MJ, Creagh-Barry P, McArthur S, et al. Influence of vitamin B12 status on the inactivation of methionine synthase by nitrous oxide. Br J Anaesth. Jul. 1992;69(1):81-6. [pmid: 1637609].
60 Zelcer J, Owers H, Paull JD. A controlled oximetric evaluation of inhalational, opioid and epidural analgesia in labour. Anaesth Intensive Care. Nov. 1989;17(4):418-21. [pmid: 2596676].
61 Deckardt R, Fembacher PM, Schneider KT, et al. Maternal arterial oxygen saturation during labor and delivery: pain-dependent alterations and effects on the newborn. Obstet Gynecol. Jul. 1987;70(1):21-5. [pmid: 3601266].
62 Harrison RF, Shore M, Woods T, et al. A comparative study of transcutaneous electrical nerve stimulation (TENS), Entonox, pethidine + promazine and lumbar epidural for pain relief in labor. Acta Obstet Gynecol Scand. 1987;66(1):9-14. [pmid: 3300138].
63 Harrison RF, Cullen R. A comparative study of the behaviour of the neonate following various forms of maternal intrapartum analgesia and anaesthesia. Ir JMed Sci. 1986;155(1):12-18. [pmid: 3700061].
64 Soyannwo OA. Self-administered Entonox (50% nitrous oxide in oxygen) in labour: report of the experience in Ibadan. Afr J Med Med Sci. Mar-Jun. 1985;14(1-2):95-8. [pmid: 2994447].
65 Murphy JF, Dauncey M, Rees GAD. Obstetric analgesia, anaesthesia and the Apgar score. Anaesthesia. 1984;39(8):760-763. [pmid: 6476311].
66 Rosen M, Mushin WW, Jones PL, et al. Field trial of methoxyflurane, nitrous oxide, and trichloroethylene as obstetric analgesics. Br Med J. Aug. 2. 1969;3(5665):263-7. [pmid: 4895340].
67 Beppu K. Transmission of the anesthetic agents through the placenta in painless delivery and their effects on newborn infants. Keio J Med. Jun. 1968;17(2):81-107. [pmid: 5727834].
68 Smith BE, Moya F. Inhalational analgesia with methoxyflurane for vaginal delivery. South Med J. Apr. 1968;61(4):386-90. [pmid: 5644074].
69 Clark RB, Cooper JO, Brown WE, et al. An evaluation of methoxyflurane analgesia and anesthesia for obstetrics. South Med J. Jul. 1968;61(7):687-91. [pmid: 5664516].
70 Waldenstrom U, Irestedt L. Obstetric pain relief and its association with remembrance of labor pain at two months and one year after birth. J Psychosom Obstet Gynaecol. Sep. 2006;27(3):147-56. [pmid: 17214449].
71 Henry A, Nand SL. Intrapartum pain management at the Royal Hospital for Women. Aust N Z J Obstet Gynaecol. Aug. 2004;44(4):307-13. [pmid: 15282001].
72 Paech MJ. The King Edward Memorial Hospital 1,000 mother survey of methods of pain relief in labour. Anaesth Intensive Care. Aug. 1991;19(3):393-9. [pmid: 1767909].
73 Ross JA, Tunstall ME, Campbell DM, et al. The use of 0.25% isoflurane premixed in 50% nitrous oxide and oxygen for pain relief in labour. Anaesthesia. Dec. 1999;54(12):1166-72. [pmid: 10594414].
74 Waldenstrom U. Experience of labor and birth in 1111 women. J Psychosom Res. Nov. 1999;47(5):471-82. [pmid: 10624845].
75 Waldenstrom U, Bergman V, Vasell G. The complexity of labor pain: Experiences of 278 women. JPsychosom Obstet Gynaecol. 1996;17(4):215-228. [pmid: 8997688].
76 Ranta P, Spalding M, Kangas-Saarela T, et al. Maternal expectations and experiences of labour pain — options of 1091 Finnish parturients. Acta Anaesthesiol Scand. 1995;39(1):60-66. [pmid: 7725885].
77 Reed PN, Colquhoun AD, Hanning CD. Maternal oxygenation during normal labour. Br J Anaesth. Mar. 1989;62(3):316-8. [pmid: 2930673].
78 Morgan B, Bulpitt CJ, Clifton P, et al. Effectiveness of pain relief in labour: survey of 1000 mothers. Br Med J (Clin Res Ed). Sep. 11. 1982;285(6343):689-90.
79 Holdcroft A, Morgan M. An assessment of the analgesic effect in labour of pethidine and 50 per cent nitrous oxide in oxygen (Entonox). J Obstet Gynaecol Br Commonw. Aug. 1974;81(8):603-7. [pmid: 4424256].
80 Marx GF, Joshi CW, Orkin LR. Placental transmission of nitrous oxide. Anesthesiology. May. 1970;32(5):429-32. [pmid: 5445031].
81 ACOG Committee Opinion No. 348, November 2006: Umbilical cord blood gas and acid-base analysis. Obstet Gynecol. Nov. 2006;108(5):1319-22. [pmid: 17077266].
82 The Apgar Score. Adv Neonatal Care. Aug. 2006;6(4):220-3. [pmid: 16890134].
83 Grant D, Haas C. Nitrous nightmares? Hygienists compare notes on N2O, pregnancy. RDH. 2009;29(12):40-4.