# Methods

In this chapter, we document the procedures that the Vanderbilt Evidence-based Practice Center used to produce a systematic review on the use of nitrous oxide for the management of labor pain. We first describe the assistance provided by the technical expert panel (TEP) throughout the topic refinement and review process. We then present the Key Questions and analytic framework. We also discuss our strategy for identifying articles relevant to our five Key Questions, our inclusion and exclusion criteria, and the process we used to abstract pertinent information from the eligible articles and generate our evidence tables. In addition, we discuss our method for grading the quality of individual articles and for rating the strength of the evidence. Finally, we describe the applicability of this report.

## Technical Expert Panel

We identified technical experts on the topic of the use of nitrous oxide for the management of labor pain in the fields of obstetrics and gynecology, anesthesiology, midwifery, nursing, pediatric care, primary care, and patient advocacy to provide assistance during the project. The TEP was expected to contribute to broader goals of the Agency for Healthcare Research and Quality (AHRQ), including (1) creating and maintaining science partnerships as well as public-private partnerships and (2) meeting the needs of an array of potential customers and users of its products. Thus, the TEP was both an additional resource and a sounding board during the project. The TEP included nine members serving as technical or clinical experts. To ensure robust scientifically relevant work, we called on the TEP to provide reactions to work in progress and advice on substantive issues or possibly overlooked areas of research. TEP members participated in conference calls and discussion through email to:

- Refine the analytic framework and Key Questions during topic refinement
- Discuss the preliminary assessment of the literature, including inclusion/exclusion criteria
- Provide input on the information and domains included in evidence tables
- Develop a hierarchy of participant characteristics and outcomes to systematically assess
- Advise about the clinical availability and use of nitrous oxide for the management of labor pain in the United States

Because of their extensive knowledge of the literature, including numerous articles authored by TEP members themselves, and their active involvement in professional societies and trial networks, and as practitioners in the field, we also asked TEP members to participate in the external peer review of the draft report.

## Analytic Framework for Nitrous Oxide for Labor Pain Management

The analytic framework in Figure 2 summarizes the conceptual model used to guide this systematic review by focusing the Key Questions on the critical health care related pathways and decision points. Our analytic framework emphasizes that care takes place at the interface of the health care system and the individual. The pathway through care is indicated in the boxes along the center line where the person and care meet. Each Key Question is indicated within the framework at the relevant point of influence in care. Each of the domains listed among individual and system factors, such as patient factors, use of cointerventions, provider factors and health system factors, has been shown to influence care trajectories and outcomes. Making these domains explicit as they influence the care pathway provides the framework in which the review team and technical expert panel conducted this review. To the degree that individuals or care settings vary in context-specific points of influence, this framework may or may not be applicable.

Figure 2 Analytic framework for nitrous oxide for the management of labor pain

The analytic framework outlines potential areas in which to target a review of the effectiveness of nitrous oxide for the management of labor pain in women intending a vaginal birth, whether labor is spontaneous, induced, or augmented. Multiple decision points for choosing a pain relief method are included to reflect the initial preference for pain relief as well as the decision to either alter or maintain the pain relief method during labor. Both pharmacologic and nonpharmacologic methods are included. External factors that influence the choice of pain relief method, such as health system factors (including availability and cost) and individual characteristics (including past experiences and knowledge of outcomes) are also illustrated. Intermediate and long-term outcomes associated with pain relief methods can include pain, coping, co-interventions, and satisfaction with birth experience and pain management. Adverse outcomes resulting from the initial choice of pain relief method and the secondary choice to modify or maintain the pain relief method are also illustrated.

Overall, the figure represents the population of interest, women intending a vaginal birth, and the factors and decision points that influence the use of nitrous oxide for the management of labor pain. The initial preference for pain management methods, which is often determined prior to the onset of labor, can be shaped by past birth experience, cultural or familial influence, and knowledge of various pain management options. Women acquire knowledge about pain management options from a variety of sources including health care providers, childbirth educators, patient education books and other materials, popular media, friends, and family. Once labor begins, health system factors such as availability, setting, and provider preference may affect the utilization of the desired pain management methods (Key Question 5). The first two decision points reflect the initial preference for and actual implementation of pain management methods. A third decision point occurs after the onset of labor but prior to birth, at which point the woman in labor may opt to modify the pain management method. We sought to examine how the administration of nitrous oxide at various mixes, routes, and intervals affects outcomes that occur during labor, after birth, and in the long term (Key Questions 1–3). Adverse effects of treatment are examined in Key Question 4. Portions of the framework that are unexplored in the scientific literature are highlighted in the discussion of future research needs.

## Literature Review Methods

### Literature Search and Retrieval Process

#### Databases

Our search included MEDLINE^®^, Embase, and Cumulative Index to Nursing and Allied Health Literature (CINAHL). Reviews conducted by the Cochrane Collaboration are indexed in the MEDLINE database and were also included in the search. We also hand-searched references of included articles to identify additional studies. We employed indexing terms within each database to exclude ineligible publication types and articles in languages other than English.

#### Search Terms

Controlled vocabulary terms served as the foundation of our search in each database, complemented by additional keyword phrases to represent the myriad ways in which nitrous oxide is referred to in the clinical literature. We limited the MEDLINE search strategy to exclude studies not relevant to human populations and non-English-language papers. We also used the search strategy to perform an initial exclusion of publications that lay beyond the scope of the review (letters, comments, case reports, reviews, news, editorials, historical articles, and meta-analyses), focusing on retaining items comprising primary data (prospective and retrospective studies).

We searched CINAHL and Embase to supplement the MEDLINE results with additional nursing and drug-focused results. Similarly, we used a combination of controlled vocabulary and keywords, limited to primary data, English-language reports, and human subjects. Our review process also allowed identification of additional articles which should be retained for hand searching of references. Appendix A outlines our search terms and results. Our searches were executed between July 2010 and July 2011 and were not limited by date.

#### Grey Literature

Grey literature was searched with a focus on background and regulatory material. Sources included websites and databases of the U.S. Food and Drug Administration (FDA), the Joint Commission, the Occupational Safety and Health Administration (OSHA), and the National Institute for Occupational Safety and Health (NIOSH); thesis/dissertation databases (ProQuest Dissertations and Theses A&I, Networked Digital Library of Theses & Dissertations, Index to Theses); New York Academy of Medicine's Grey Literature Report; PAIS International; Hazardous Substances Data Bank; legal resources (LexisNexis Academic, HeinOnline;, meeting/abstract databases (BIOSIS Previews, BioMed Central meeting abstracts); OpenDOAR open access repository; general web searching (Google, GoogleScholar, Scirus); and files posted to an email group focused on the use of nitrous oxide in labor (N2Oduringlabor Yahoo! Group).

#### Inclusion and Exclusion Criteria

Our inclusion and exclusion criteria and population, intervention, comparators, outcomes, timing, and setting (PICOTS) were developed in consultation with the TEP, to capture the literature most tightly related to the Key Questions. The PICOTS and criteria are summarized in Table 2.

Table 2 Inclusion and exclusion criteria

Category | Criteria
Study population | Pregnant women in first and second stages of labor (up to birth), other attendees and health care providers, and the fetus/neonate
Intervention | Nitrous oxide inhalation
Comparators | - No analgesic/anesthetic intervention, analgesia/anesthesia, other inhalational agents, and pharmacologic and nonpharmacologic pain management methods; ○ Pharmacologic pain management methods include, but are not limited to, epidural analgesia, paracervical block, pudendal block, and parenteral opioids; ○ Nonpharmacologic pain management methods include, but are not limited to, acupuncture, aromatherapy, continuous labor support, heat and cold, hydrotherapy, hypnosis, movement and positioning, music and audioanalgesia, patterned breathing and relaxation, sterile water injections, touch and massage, and transcutaneous electrical nerve stimulation (TENS)
Outcomes | - Primary outcomes:; ○ Pain reduction; ○ Satisfaction with pain management; ○ Satisfaction with birth experience; ○ Long-term maternal, child, and occupational health outcomes; - Other outcomes:; ○ Labor and intermediate outcomes; – Pain; – Coping; – Labor progress; – Satisfaction with pain management.; – Satisfaction with birth experience; – Availability and timeliness; – Cointerventions associated with the use of nitrous oxide or other pain management methods; ○ Birth and long-term outcomes; – Maternal outcomes, including but not limited to route of birth and postpartum course; – Child outcomes, including but not limited to Apgar scores, fetal cord blood gases, and neurobehavioral outcomes; – Health care provider outcomes (occupational health) from exposure; – Maternal satisfaction with pain management; – Maternal satisfaction with birth experience; ○ Adverse effects, including but not limited to:; – Maternal adverse effects, such as nausea and vomiting, dreams, dizziness, and unconsciousness; – Fetal/neonatal adverse effects, such as drug dependency; – Childhood adverse effects, such as drug dependency and developmental complications.; – Individuals present for labor adverse effects.; – Health care provider adverse effects (occupational health)
Timing | - Intermediate outcomes will include associated labor outcomes; - Long-term outcomes will include associated birth outcomes; - There will be no restriction on duration of follow-up
Setting | - All birth settings will be considered, including hospital, birth center, and home
Publication date | No limit
Publication languages | English only
Admissible evidence (study design and other criteria) | [underlined: Admissible designs]; - Study size ≥20 pregnant women using nitrous oxide during labor and reporting outcomes; - Addresses harms or occupational exposures; [underlined: Other criteria]; - Original research studies that provide sufficient detail regarding methods and results to enable use and adjustment of the data and results; - Studies with mixed patient populations must include ≥ 20 pregnant women in labor or provide extractable information addressing harms or occupational outcomes; - Studies must include at least one outcome measure of an outcome listed in the PICOTS; - Relevant outcomes must be extractable from data presented in the papers

The study population includes pregnant women in labor, birth attendees or health care providers who may be exposed to nitrous oxide during labor, and the fetus/neonate. We did not restrict by parity or risk status. The initial study size was set at greater than or equal to 20 women using any intervention for labor pain management, provided that nitrous oxide was included in the study (i.e. studies with multiple arms that include nitrous oxide as an intervention for labor pain management would be included if the total N was greater than or equal to 20). However, once we completed the data abstraction, we determined that a meta-analysis would not be feasible given the heterogeneity among included studies in several key areas, most notably nitrous oxide mix, outcome assessment methods, and comparators. The study size inclusion criterion was then amended to specify that included studies must report outcomes on greater than or equal 20 women using nitrous oxide for labor pain management. Studies with fewer than 20 women reporting outcomes related to nitrous oxide use are too small to provide meaningful results in the absence of a meta-analysis. We excluded four studies based on the amended study size criterion.

We did not have translation services available to us to review non-English papers, and our TEP agreed that the vast majority of the relevant literature would be published in English. Furthermore, this review is intended to inform U.S. health care, and most research in the population of pregnant women in the United States is published in English language journals. Empirical evidence on the potential for bias created by excluding non-English studies also suggests little effect.22

#### Article Selection Process

Once we identified articles through the electronic database searches, review articles, and bibliographies, we examined abstracts of articles to determine whether studies met our criteria. Two reviewers separately evaluated the abstracts for inclusion or exclusion, using an Abstract Review Form (Appendix B). If one reviewer concluded that the article could be eligible for the review based on the abstract, we retained it. Following abstract review, two reviewers independently assessed the full text of each included study using a standardized form (Appendix B) that included questions stemming from our inclusion/exclusion criteria. Disagreements between reviewers were resolved by a third-party adjudicator. The group of abstract and full text reviewers included three physicians (two obstetrician-gynecologists and an anesthesiologist), two certified nurse-midwives, two health services researchers, and two library scientists. Excluded studies, and the reasons for exclusion, are presented in Appendix E.

## Literature Synthesis

### Development of Evidence Tables and Data Abstraction Process

The staff members and clinical experts who conducted this review jointly developed the evidence tables. We designed the tables to provide sufficient information to enable readers to understand the studies and to determine their quality; we gave particular emphasis to essential information related to our Key Questions. We based the format of our evidence tables on successful designs used for prior systematic reviews.

The team was trained to abstract by abstracting several articles into evidence tables and then reconvening as a group to discuss the utility of the table design. We repeated this process through several iterations until we decided that the tables included the appropriate categories for gathering the information contained in the articles. All team members shared the task of initially entering information into the evidence tables. Another member of the team also reviewed the articles and edited all initial table entries for accuracy, completeness, and consistency. The two abstractors reconciled disagreements concerning the information reported in the evidence tables, the most common of which were study design and study setting. The full research team met regularly during the article abstraction period and discussed global issues related to the data abstraction process. In addition to outcomes related to intervention effectiveness, we abstracted all data available on harms. Harms encompass the full range of specific negative effects, including the narrower definition of adverse events.

The final evidence tables are presented in their entirety in Appendix C. Studies are presented in the evidence tables alphabetically by the last name of the first author. When possible, studies resulting from the same study population were grouped into a single evidence table. A list of abbreviations and acronyms used in the tables appears at the beginning of that appendix.

### Rating Quality of Individual Studies

To assess the quality of individual studies, the team considered both novel and existing rating tools. Two existing, widely accepted tools were selected to account for the variety of potentially included study types (e.g. randomized controlled trials [RCTs] and cohorts); specifically the Cochrane Risk of Bias tool23 and the Newcastle-Ottawa Quality Assessment Scale.24 The Cochrane Risk of Bias tool is designed for the assessment of studies with experimental designs and randomized participants. As such, we employed the Cochrane Risk of Bias tool to assess the quality of RCTs. Fundamental domains include sequence generation, allocation concealment, blinding, completeness of outcome data, and selective reporting bias. The Newcastle-Ottawa Quality Assessment Scale was used to assess the quality of nonrandomized studies (e.g. cohort and case-control studies). This scale assesses three broad perspectives: the selection of study groups, the comparability of study groups, and the ascertainment of either the exposure or outcome of interest for case-control or cohort studies, respectively. Both tools are presented in Appendix D.

Quality assessment of each study was conducted using the Distiller Systematic Review online reference manager (Evidence Partners Incorporated, Ottawa, Ontario). Web-based assessment forms were created using the tools provided in Appendix D as templates. Investigators did not rely on the study design as described by authors of individual papers; rather, the methods section of each paper was reviewed to determine which rating tool to employ. Four investigators independently assessed the quality of individual studies, with the Senior Scientist reviewing and resolving any discrepancies. Thresholds for converting the Cochrane Risk of Bias tool and Newcastle-Ottawa Quality Assessment Scale results to the AHRQ standard of “good,” “fair,” and “poor” quality designations are described in Appendix D.

### Grading Strength of Evidence

We evaluated the overall strength of the evidence for the primary outcomes. We used the approach to strength of evidence described in the EPCs' Methods Guide for Effectiveness and Comparative Effectiveness Reviews.25 We graded available evidence for each key outcome for each of the following domains:

- Risk of bias (low, medium, or high)
- Consistency of findings (inconsistency not present, inconsistency present, or unknown or not applicable)
- Directness (direct comparison of influence on outcomes in RCT, or indirect information from observational research)
- Precision (precise or imprecise based on outcomes rates, size of the individual studies and the total number of women in the studies for the category of intervention)

We combined the grades of each domain to develop the strength of evidence for each key outcome. Possible grades for each domain were: low, moderate, or high risk of bias; consistent or inconsistent; direct or indirect; and precise or imprecise. We considered additional domains, including publication bias and large effect size, on a per-Key Question basis.

We graded the body of literature for effectiveness of nitrous oxide for the management of labor pain, women's satisfaction with their birth experience and pain management, effect of nitrous oxide on route of birth, and adverse effects associated with nitrous oxide. We present those ratings as part of the discussion in the final chapter of the report. The possible grades were:

High: High confidence that the evidence reflects the true effect. Further research is unlikely to change estimates.

Moderate: Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.

Low: Low confidence that the evidence reflects the true effect. Further research is likely to change confidence in the estimate of effect and is also likely to change the estimate.

Insufficient: Evidence is either unavailable or does not permit a conclusion.

When no studies were available for an outcome or comparison of interest, we assessed the evidence as insufficient. Two reviewers independently graded the body of evidence; disagreements were resolved through discussion or a third reviewer adjudication.

### Applicability

For decision makers to use this report to inform clinical care, they need information clarifying the degree to which findings of the included research might be expected to apply in the types of populations and settings in which intrapartum care is provided in the United States. Our assessment of applicability implemented the PICOTS framework, as described in AHRQ's Methods Guide for Effectiveness and Comparative Effectiveness Reviews.25 Applicability tables depicting the similarity or lack of comparability of populations, interventions, comparison groups, outcomes, and settings represented in the available literature for each Key Question are presented in Appendix D.

Additionally, we used input from team and TEP members to identify study characteristics to be included in evidence tables and routinely abstracted. These characteristics were critical in highlighting limitations of current research, and in turn assessing applicability. We discuss applicability further in the Discussion chapter of the report.