# Peer Reviewers

William Camann, M.D.

Director of Obstetric Anesthesia

Brigham and Women's Hospital, Harvard Medical School

Boston, MA

Jo Davies, M.B.B.S., F.R.C.A.

Associate Professor, Anesthesiology and Pain Medicine

University of Washington

Seattle, WA

Jesse M. Ehrenfeld, M.D., M.P.H.

Director of the Center for Evidence Based Anesthesia

Vanderbilt University Medical Center

Nashville, TN

Ellice Lieberman, M.D., Dr.P.H.

Professor, Department of Society, Human Development, and Health, Department of Epidemiology

Brigham and Women's Hospital, Harvard Medical School

Boston, MA

Peter Norman, M.D., F.R.C.P.C.

Professor, Anesthesiology & Perioperative Medicine

The University of Texas

Houston, TX

Judith Rooks, C.N.M., M.P.H., F.A.C.N.M.

Courtesy Instructor, College of Public Health

University of South Florida

Tampa, FL

Mark Rosen, M.D.

Director of Obstetric Anesthesia

University of California San Francisco

San Francisco, CA

Carol Sakala, Ph.D., M.S.P.H.

Director of Programs

Childbirth Connection

New York, NY

Allison Shorten, Ph.D., R.N., R.M., F.A.C.M.

Associate Professor

Yale School of Nursing

New Haven, CT