# Technical Expert Panel

Judith Bishop, C.N.M., M.P.H.

Professor, Obstetrics, Gynecology, and Reproductive Sciences

University of California, San Francisco

San Francisco, CA

William Camann, M.D.

Director of Obstetric Anesthesia

Brigham and Women's Hospital, Harvard Medical School

Boston, MA

Jo Davies, M.B.B.S., F.R.C.A.

Associate Professor, Anesthesiology and Pain Medicine

University of Washington

Seattle, WA

Sharon Holley, D.N.P., C.N.M.

Instructor of Nursing

Vanderbilt University Nursing School

Nashville, TN

Lucky Jain, M.D.

Professor of Pediatrics, Executive Vice Chairman for Department of Pediatrics

Emory University School of Medicine

Atlanta, GA

Holly Powell Kennedy, C.N.M., Ph.D., F.A.C.N.M., F.A.A.N.

Helen Varney Professor of Midwifery

Yale University School of Nursing

President, American College of Nurse-Midwives

New Haven, CT

Ellice Lieberman, M.D., Dr.P.H.

Professor, Department of Society, Human Development, and Health, Department of Epidemiology

Brigham and Women's Hospital, Harvard Medical School

Boston, MA

Judith Rooks, C.N.M., M.P.H., F.A.C.N.M.

Courtesy Instructor, College of Public Health

University of South Florida

Tampa, FL

Carol Sakala, Ph.D., M.S.P.H.

Director of Programs

Childbirth Connection

New York, NY