# Acknowledgments

We are indebted to a tireless and exceptional group of colleagues who made this report possible. Each step of a systematic review draws on the skills and attention of an entire team.

Ms. Kerry Jordan served as project coordinator shepherding innumerable planning, implementation, and writing tasks to completion. She guided and contributed to production of the plethora of forms, spreadsheets, and tables that are required to produce reliable evidence tables and summary data. Her attentiveness to the needs of the investigator team and to pacing the work was especially valued.

Ms. Tracy Shields is a key member of the library science staff and her detailed approach to abstract and full text review, evidence table construction, and quality scoring was invaluable.

Ms. Kathy Lee was always willing to contribute time and effort when having extra assistance with tasks like printing and distributing articles and preparing meeting materials were a priority. We appreciate her generosity in helping while simultaneously assisting on several other major reports.