# Excluded Studies

Exclusion codes:

- X-1: Not original research (reviews, editorials, commentaries, letters to editor, etc)
- X-2: Ineligible study size
- X-3: Not related to the use of nitrous oxide for the management of labor pain
- X-4: Not published in English
- X-5: Did not address study questions

1 Penthrane for obstetrical anesthesia. Med Lett Drugs Ther. Mar. 24. 1967;9(6):23-4. X-3. [pmid: 5298499].
2 End of an era. Br Med J. Dec. 13. 1969;4(5684):636-7. X-1, X-2, X-3, X-5.
3 Editorial: Nitrous-oxide analgesia. Lancet. Oct. 20. 1973;2(7834):891. X-1, X-2, X-3, X-5.
4 Letter: Complication of laparoscopy during early pregnancy. Br Med J. Mar. 30. 1974;1(5908):637-8. X-1, X-2, X-3, X-5.
5 Occupational disease among operating room personnel: a national study. Report of an Ad Hoc Committee on the Effect of Trace Anesthetics on the Health of Operating Room Personnel, American Society of Anesthesiologists. Anesthesiology. Oct. 1974;41(4):321-40. X-3d, X-5. [pmid: 4414878].
6 Editorial: Pregnancy and anaesthesia. Lancet. Jul. 26. 1975;2(7926):169. X-1, X-2, X-3, X-5.
7 Editorial: Awareness during anaesthesia. Br Med J. Apr. 24. 1976;1(6016):977. X-1, X-2, X-3, X-5.
8 Intrauterine foetal death associated with dental anaesthesia. SAAD Dig. Jul. 1980;4(7):166-7. X-1, X-2, X-3, X-5. [pmid: 6934626].
9 Environmental hazards. Canadian Anaesthetists Society Journal. 1985;32(2):143-144. X-1, X-2, X-5.
10 Review of recommendations for labor and birth care. Am Fam Physician. 1992;45(2). X-1, X-2, X-3, X-5.
11 Controlling reproductive hazards: how to minimize harmful exposures. Hosp Employee Health. 1994;13(8):97-104. X-1, X-2, X-3, X-5.
12 Pain relief in labour: your guide to a comfortable birth. Modern Midwife. 1995;5(2):S1-4. X-1, X-2, X-5.
13 Plenty of scope for individualised pain control during labour and delivery. Drugs and Therapy Perspectives. 1996;7(4):7-10. X-1, X-2, X-5.
14 Practice advisory for intraoperative awareness and brain function monitoring: A report by the American Society of Anesthesiologists Task Force on Intraoperative Awareness. Anesthesiology. 2006;104(4):847-864. X-1, X-2, X-3d, X-5. [pmid: 16571982].
15 Midwifery and childbirth news. Midwifery Today. 2007;81:60-1. X-1, X-2, X-5.
16 From the American College of Nurse-Midwives. Nitrous oxide for labor analgesia. J Midwifery Womens Health. May-Jun. 2010;55(3):292-6. X-1, X-2, Background. [pmid: 20437663].
17 The most important goal in managing labour pain is patient satisfaction. Drugs & Therapy Perspectives. 2010;26(3):15-7. X-1, X-2, X-3, X-5.
18 Aalto Setala M, Heinonen J. Oxygen delivery during endobronchial anaesthesia: A comparison of halothane-oxygen and nitrous oxide-oxygen. Acta Anaesthesiol Scand. 1982;26(6):550-553. X-2, X-3. [pmid: 7158266].
19 Abboud TK, D'Onofrio L, Reyes A, et al. Isoflurane or halothane for cesarean section: comparative maternal and neonatal effects. Acta Anaesthesiol Scand. Oct. 1989;33(7):578-81. X-2, X-3d, X-5. [pmid: 2816239].
20 Abboud TK, Kim SH, Henriksen EH, et al. Comparative maternal and neonatal effects of halothane and enflurane for cesarean section. Acta Anaesthesiol Scand. Oct. 1985;29(7):663-8. X-2, X-3. [pmid: 4072589].
21 Abboud TK, Nagappala S, Murakawa K, et al. Comparison of the effects of general and regional anesthesia for cesarean section on neonatal neurologic and adaptive capacity scores. Anesth Analg. Oct. 1985;64(10):996-1000. X-2, X-3. [pmid: 4037398].
22 Abboud TK, Noueihed R, Khoo S, et al. Effects of induction of general and regional anesthesia for cesarean section on maternal plasma beta-endorphin levels. Am J Obstet Gynecol. Aug. 15. 1983;146(8):927-30. X-2, X-3. [pmid: 6309007].
23 Abboud TK, Zhu J, Richardson M, et al. Desflurane: a new volatile anesthetic for cesarean section. Maternal and neonatal effects. Acta Anaesthesiol Scand. Aug. 1995;39(6):723-6. X-2, X-3. [pmid: 7484023].
24 Abboud TK, Zhu J, Richardson M, et al. Intravenous propofol vs thiamylal-isoflurane for caesarean section, comparative maternal and neonatal effects. Acta Anaesthesiol Scand. Feb. 1995;39(2):205-9. X-2, X-3. [pmid: 7793188].
25 Abdulatif M, Taylouni E. Surgeon-controlled mivacurium administration during elective caesarean section. Can J Anaesth. Feb. 1995;42(2):96-102. X-2, X-3. [pmid: 7720168].
26 Abdul-Khaliq H, Uhlig R, Bottcher W, et al. Factors influencing the change in cerebral hemodynamics in pediatric patients during and after corrective cardiac surgery of congenital heart diseases by means of full-flow cardiopulmonary bypass. Perfusion. 2002;17(3):179-185. X-2, X-3. [pmid: 12017385].
27 Abouleish E, Abboud T, Lechevalier T, et al. Rocuronium (Org 9426) for caesarean section. Br J Anaesth. Sep. 1994;73(3):336-41. X-2, X-3. [pmid: 7946860].
28 Abouleish E, Taylor FH. Effect of morphine-diazepam on signs of anesthesia, awareness, and dreams of patients under N2O for cesarean section. Anesth Analg. Sep-Oct. 1976;55(5):702-5. X-2, X-3. [pmid: 987727].
29 Ackerman IWE. Anesthesia considerations for complicated hydatidiform molar pregnancies. Anesthesiology Review. 1984;11(7):20-24. X-1, X-2, X-3a, X-5.
30 Ademuyiwa O, Odusoga OL, Adebawo OO, et al. Endogenous antioxidant defences in plasma and erythrocytes of pregnant women during different trimesters of pregnancy. Acta Obstet Gynecol Scand. 1175. 86(10):1175-1180. X-2, X-3. [pmid: 17851796].
31 Adriani J. Analgesia and anesthesia in cesarean hysterectomy. Clin Obstet Gynecol. Sep. 1969;12(3):590-617. X-1, X-2, X-3a, X-3d, X-5. [pmid: 5347225].
32 Aghdashi MM, Abbasivash R, Hassani E, et al. Fatal respiratory thermal injury following accidental administration of carbon dioxide using the circle system for a cesarean delivery. Int J Obstet Anesth. 2009;18(4):400-402. X-2, X-3. [pmid: 19734035].
33 Aitkenhead AR. Complications following large-bowel surgery. Regional Anesthesia. 1982;7(Suppl. 4):S99-S104. X-1, X-2, X-3d.
34 Ajuzieogu OV, Ezike HA, Amucheazi AO, et al. A retrospective study of the outcome of cesarean section for women with severe pre-eclampsia in a third world setting. Saudi J Anaesthesia. 2011;5(1):15-18. X-3d.
35 Akimova E, Savli M, Haeusler D, et al. Increase of 5-HTT occupancy during escitalopram or citalopram treatment correlates with antidepressant efficacy in major depressive disorder. J Cancer Educ Conference: Joint Annual Meeting for AACE, CPEN, and EACE. 2009;24:S424-S425. X-2, X-3.
36 Al Zahrani T, Ibraheim O, Turkistani A, et al. Bispectral index profile during general anaesthesia using nitrous oxide for lower segment caesarean delivery. Internet JAnesthesiology. 2006;10(1). X-2, X-3, X-5.
37 Al-Areibi A, Coveney L, Singh S, et al. Case report: Anesthetic management for sequential Cesarean delivery and laminectomy. Can J Anaesth. 2007;54(6):471-474. X-2, X-3d. [pmid: 17541077].
38 Aldridge LM, Tunstall ME. Nitrous oxide and the fetus. A review and the results of a retrospective study of 175 cases of anaesthesia for insertion of Shirodkar suture. Br J Anaesth. Dec. 1986;58(12):1348-56. X-2, X-3, X-5. [pmid: 3790387].
39 Allahyary E, Zand F, Tabatabaee HR. Evaluation of the adequacy of general anesthesia in cesarean section by auditory evoked potential index: an observational study. Acta Anaesthesiol Taiwan. Mar. 2008;46(1):16-24. X-2, X-3. [pmid: 18390396].
40 Allen TK, George RB, Olufolabi AJ, et al. The management of Cesarean delivery in a parturient with paroxysmal nocturnal hemoglobinuria complicated by severe preeclampsia. Can J Anaesth. 2007;54(8):646-651. X-2, X-3d. [pmid: 17666718].
41 Alon E, Himmelseher S. Ondansetron in the treatment of postoperative vomiting: a randomized, double-blind comparison with droperidol and metoclopramide. Anesth Analg. Oct. 1992;75(4):561-5. X-2, X-3b, X-3d. [pmid: 1388337].
42 Andersen LW, Qvist T, Hertz J, et al. Concentrations of thiopentone in mature breast milk and colostrum following an induction dose. Acta Anaesthesiol Scand. 1987;31(1):30-32. X-2, X-3, X-5. [pmid: 3825473].
43 Anderson BJ, Dyson A, Henderson AM. Inspired oxygen and nitrous oxide concentrations in volunteers during nitrous oxide sedation with a Hudson mask. Anaesth Intensive Care. 1988;16(4):423-426. X-2, X-3, X-5. [pmid: 3232801].
44 Anil M, Helvaci M, Ozkalay N, et al. Salmonella typhimurium outbreak in a neonatal unit in Turkey. Indian J Pediatr. 2009;76(6):629-633. X-2, X-3d. [pmid: 19418032].
45 Antal M, Benko M. Introduction of anaesthesia in caesarean section by using ketamine and fazadinium. Acta Chirurgica Hungarica. 1986;27(1):19-25. X-2, X-3d, X-5. [pmid: 2872763].
46 Anwari JS, Ehsan FM, Al-Dar MM. Intravenous patient-controlled analgesia for labor pain. Saudi Med J. 2003;24(6):691-693. X-1, X-2, X-3, X-5. [pmid: 12847612].
47 Aoyama K, Yasunaga E, Takenaka I, et al. Positive pressure ventilation during fibreoptic intubation: Comparison of the laryngeal mask airway, intubating laryngeal mask and endoscopy mask techniques. Br J Anaesth. 2002;88(2):246-254. X-2, X-3. [pmid: 11878657].
48 Arai M, Nishijima M, Tatsumi H. Analgesia and anesthesia during labor in Japan and developed countries. Asia Oceania J Obstet Gynaecol. Sep. 1989;15(3):213-21. X-2, X-3d. [pmid: 2597085].
49 Arellano RJ, Pole ML, Rafuse SE, et al. Omission of nitrous oxide from a propofol-based anesthetic does not affect the recovery of women undergoing outpatient gynecologic surgery. Anesthesiology. Aug. 2000;93(2):332-9. X-2, X-3b, X-3d. [pmid: 10910478].
50 Arozenius S, Dahlgren BE, Lindwall L, et al. A comparison of the analgesic effects of methoxyflurane-nitrous oxide and nitrous oxide alone during labour related to the Eysenck personality inventory test. Acta Obstet Gynecol Scand. 1980;59(3):203-7. X-5. [pmid: 7424496].
51 Arthurs GJ, Rosen M. Acceptability of continuous nasal nitrous oxide during labour--a field trial in six maternity hospitals. Anaesthesia. Apr. 1981;36(4):384-8. X-5. [pmid: 7246989].
52 Axelsson G, Rylander R. Exposure to anaesthetic gases and spontaneous abortion: response bias in a postal questionnaire study. Int J Epidemiol. Sep. 1982;11(3):250-6. X-3, X-5. [pmid: 7129739].
53 Aydin GB, Coskun F, Sahin A, et al. Influence of sevoflurane and desflurane on neurological and adaptive capacity scores in newborns. Saudi Med J. Jun. 2008;29(6):841-6. X-2, X-3, X-5. [pmid: 18521462].
54 Baccetti B, Piomboni P, Bruni E, et al. Effect of follicle-stimulating hormone on sperm quality and pregnancy rate. Asian J Androl. 2004;6(2):133-137. X-2, X-3d. [pmid: 15154088].
55 Baden JM. Chronic toxicity of inhalation anaesthetics. Clin Anaesthesiol. 1983;1(2):441-454. X-1, X-2, X-3, X-5.
56 Bagshaw RJ, Smith DS, Young MS, et al. Anesthetic management of surgery in the vertebral canal. Anesthesiol Rev. 1985;12(2):13-32. X-1, X-2, X-3d.
57 Baird DD. Characteristics of fertile menstrual cycles. Scand J Work Environ Health. 1999;25(SUPPL. 1):20-22. X-2, X-3d, X-5. [pmid: 10235401].
58 Baird PA. Occupational exposure to nitrous oxide--not a laughing matter. N Engl J Med. Oct. 1. 1992;327(14):1026-7. X-1, X-2, X-3, X-5. [pmid: 1518538].
59 Baird WLM, Savage DS. Vecuronium - The first years. Clin Anaesthesiol. 1985;3(2):347-360. X-1, X-2, X-3a, X-3d.
60 Bajekal RR, Turner R, Yentis SM. Anti-infective measures and Entonox equipment: a survey. Anaesthesia. Feb. 2000;55(2):153-4. X-2, X-5. [pmid: 10651676].
61 Bajorek J, Walaszek M. Assessment of the condition of newborns delivered by caesarean section performed for intrauterine foetal distress in relation to the type of anaesthesia. Anaesth Resusc Intensive Ther. Apr-Jun. 1974;2(2):145-8. X-2, X-3, X-5. [pmid: 4476194].
62 Bajoria R, Ward S, Sooranna SR. Atrial natriuretic peptide mediated polyuria: Pathogenesis of polyhydramnios in the recipient twin of twin-twin transfusion syndrome. Placenta. 2001;22(8-9):716-724. X-2, X-3c. [pmid: 11597191].
63 Bamber J. Anaesthetist provided labour analgesia. Curr Anaesthesia Crit Care. 2006;17(3-4):131-141. X-1, X-2.
64 Bancroft GH, Lauria JI. Ketamine induction for cesarean section in a patient with acute intermittent porphyria and achondroplastic dwarfism. Anesthesiol. 1983;59(2):143-144. X-1, X-2, X-3a, X-3d, X-5.
65 Bannister CF, Brosius KK, Sigl JC, et al. The effect of bispectral index monitoring on anesthetic use and recovery in children anesthetized with sevoflurane in nitrous oxide. Anesth Analg. 2001;92(4):877-881. X-2, X-3. [pmid: 11273918].
66 Baraka A. Correlation between maternal and foetal PO2 and PCO2 during Caesarean section. Br J Anaesth. May. 1970;42(5):434-8. X-2, X-3, X-5. [pmid: 5431544].
67 Baraka A, Louis F, Noueihid R, et al. Awareness following different techniques of general anaesthesia for caesarean section. Br J Anaesth. Jun. 1989;62(6):645-8. X-2, X-3d, X-5. [pmid: 2502168].
68 Baraka A, O'Brien M, Aslanian E, et al. Propanidid versus thiopentone for induction of general anaesthesia in elective Caesarean section. Br J Anaesth. Jun. 1971;43(6):609-12. X-2, X-3a, X-3d, X-5. [pmid: 5089941].
69 Baraka A, Siddik S, Assaf B. Supplementation of general anaesthesia with tramadol or fentanyl in parturients undergoing elective caesarean section. Can J Anaesth. Jul. 1998;45(7):631-4. X-1, X-2, X-3a, X-3d, X-5. [pmid: 9717593].
70 Baraka A, Wakid N, Noueihed R. Pseudocholinesterase activity and atracurium v. Suxamethonium block. Br J Anaesth. 1986;58(SUPPL. 1). X-3a.
71 Barker TA, Cotter L. Pregnancy following heart trasplantation: A case report. Br J Cardiol. 2003;10(1):56-57. X-1, X-2, X-3, X-5.
72 Barrier G, Sureau C. Effects of anaesthetic and analgesic drugs on labour, fetus and neonate. Clin Obstet Gynaecol. 1982;9(2):351-367. X-1, X-2. [pmid: 7140118].
73 Bassell GM. Anesthesia for cesarean section. Clin Obstet Gynecol. 1985;28(4):722-734. X-3. [pmid: 4075625].
74 Baston H. Midwifery basics: care during labour: pharmacological methods of pain relief. Practising Midwife. 2003;6(11):31-6. X-1, X-2, X-5. [pmid: 14694880].
75 Basu A, Nishanth P, Ifaturoti O. Pregnancy in women with myotonia congenita. Int J Gynecol Obstet. 2009;106(1):62-63. X-1, X-2, X-3, X-5.
76 Batt B. Is halothane safe for surgical removal of retained products of conception?. Anesth Analg. May-Jun. 1969;48(3):338-40. X-2, X-3a, X-3d, X-5. [pmid: 5305879].
77 Baum JA. New and alternative delivery concepts and techniques. Best Pract Res Clin Anaesthesiol. 2005;19(3 SPEC. ISS):415-428. X-1, X-2. [pmid: 16013691].
78 Beeby D, Hughes JOM. Oxytocic drugs and anaesthesia. A controlled clinical trial of ergometrine, syntocinon and normal saline during evacuation of the uterus after spontaneous abortion. Anaesthesia. 1984;39(8):764-767. X-2, X-3a, X-3b. [pmid: 6383111].
79 Beilin Y, Bodian CA, Mukherjee T, et al. The use of propofol, nitrous oxide, or isoflurane does not affect the reproductive success rate following gamete intrafallopian transfer (GIFT): a multicenter pilot trial/survey. Anesthesiology. Jan. 1999;90(1):36-41. X-2, X-3, X-5. [pmid: 9915310].
80 Beke A, Takacs G, Sziller I, et al. Obstetric anaesthesia in Hungary. Int J Obstet Anesth. 1997;6(4):235-238. X-3, X-5. [pmid: 15321260].
81 Bell GT, Taylor JC. Subdural block - Further points. Anaesthesia. 1994;49(9):794-795. X-1, X-2, X-3, X-5. [pmid: 7978138].
82 Bellomo R, Goldsmith D, Uchino S, et al. A prospective before-and-after trial of a medical emergency team. Med J Aust. 2003;179(6):283-287. X-2, X-3d. [pmid: 12964909].
83 Bennett EJ, Ramamurthy S, Dalal FY, et al. Pancuronium and the neonate. Br J Anaesth. Jan. 1975;47(1):75-8. X-2, X-3. [pmid: 1148077].
84 Bennett JA, Lingaraju N, Horrow JC, et al. Elderly patients recover more rapidly from desflurane than from isoflurane anesthesia. J Clin Anesth. Sep-Oct. 1992;4(5):378-81. X-2, X-3. [pmid: 1389191].
85 Bennis J, Dottori O, Gundersen K, et al. Nitrous oxide-oxygen analgesia after denitrogenation with pure oxygen in Caesarean section. Acta Anaesthesiol Scand Suppl. 1969;37:212-9. X-2, X-3a, X-3d, X-5. [pmid: 5375259].
86 Benson KT, Dozier NJ, Goto H. Anesthesia for cesarean section in patient with spondylometepiphyseal dysplasia. Anesthesiology. 1985;63(5):548-550. X-2, X-3. [pmid: 4051217].
87 Berg TG, Rayburn WF. Effects of analgesia on labor. Clin Obstet Gynecol. 1992;35(3):457-463. X-1, X-2, X-3. [pmid: 1521375].
88 Berge JA, Gramstad L, Grimnes S. A simplified concept for controlling oxygen mixtures in the anaesthetic machine - Better, cheaper and more user-friendly?. Acta Anaesthesiol Scand. 1995;39(4):563-567. X-1, X-2, X-3. [pmid: 7676800].
89 Berger N, Vaillancourt C, Boksa P. Interactive effects of anoxia and general anesthesia during birth on the degree of CNS and systemic hypoxia produced in neonatal rats. Exp Brain Res. Apr. 2000;131(4):524-31. X-2, X-3d. [pmid: 10803420].
90 Berggren L, Eriksson I. Midazolam for induction of anaesthesia in outpatients: a comparison with thiopentone. Acta Anaesthesiol Scand. Dec. 1981;25(6):492-6. X-2, X-3. [pmid: 7051729].
91 Berghorn KA, Albrecht ED, Pepe GJ. Responsivity of the baboon fetal pituitary to corticotropin-releasing hormone in utero at midgestation. Endocrinology. Sep. 1991;129(3):1424-8. X-2, X-3. [pmid: 1651849].
92 Bergmans G, Vanacker B, Van Aken H, et al. Investigation of the pharmacokinetics and analgesic effects of an intramuscular injection of sustained-release sufentanil for postoperative pain: An open study. J Clin Anesth. 1994;6(6):462-468. X-2, X-3. [pmid: 7880508].
93 Bergstrom H, Bernstein K. Psychic reactions after analgesia with nitrous oxide for caesarean section. Lancet. Sep. 7. 1968;2(7567):541-2. X-2, X-3d, X-5. [pmid: 4175401].
94 Beringer RM, Patteril M. Puerperal uterine inversion and shock. Br J Anaesth. 2004;92(3):439-441. X-1, X-2, X-3. [pmid: 14970137].
95 Bernow J, Bjordal J, Wiklund KE. Pollution of delivery ward air by nitrous oxide. Effects of various modes of room ventilation, excess and close scavenging. Acta Anaesthesiol Scand. Feb. 1984;28(1):119-23. X-2, X-5. [pmid: 6711258].
96 Bernstein K, Gisselsson L, Jacobsson L, et al. Influence of two different anaesthetic agents on the newborn and the correlation between foetal oxygenation and induction-delivery time in elective caesarean section. Acta Anaesthesiol Scand. Feb. 1985;29(2):157-60. X-2, X-3a, X-5. [pmid: 3919523].
97 Bertucci F, Tarpin C, Charafe-Jauffret E, et al. Multivariate analysis of survival in inflammatory breast cancer: Impact of intensity of chemotherapy in multimodality treatment. Bone Marrow Transplant. 2004;33(9):913-920. X-2, X-3. [pmid: 15004544].
98 Bhadresha S, Enever G. A potted history of obstetric anaesthesia. CPD Anaesthesia. 2004;6(1):36-40. X-1, X-2, X-3.
99 Bhargava AK. First public demonstration of surgical anaesthesia. Med JArmed Forces India. 2003;59(4). X-1, X-2, X-3, X-5.
100 Bhattacharya S, Wang T, Knox F. Analgesia for labour pain - Analysis of the trends and associations in the Grampian region of Scotland between 1986 and 2001. BMC Pregnancy Childbirth. 2006;6(14). X-5.
101 Bhavani Shankar K, Moseley HSL, Mushlin PS, et al. Anaesthesia in Barbados. Can J Anaesth. 1997;44(5 I):559-568. X-1, X-2, X-3. [pmid: 9161753].
102 Billard V, Servin F, Guignard B, et al. Desflurane-remifentanil-nitrous oxide anaesthesia for abdominal surgery: Optimal concentrations and recovery features. Acta Anaesthesiol Scand. 2004;48(3):355-364. X-2, X-3. [pmid: 14982571].
103 Bishop JT. Administration of nitrous oxide in labor: expanding the options for women. J Midwifery Womens Health. May-Jun. 2007;52(3):308-9. X-1, X-2, X-5. [pmid: 17467598].
104 Biswas RG, Bandyopadhyay BK, Sarkar M, et al. Perioperative management of pregnant patients with heart disease for caesarian section under anaesthesia. J Indian Med Assoc. 2003;101(11). X-2, X-3.
105 Biswas TK, Hatch PD. A comparison of alfentanil, halothane and enflurane as supplements for outpatient urological surgery. Anaesth Intensive Care. Aug. 1989;17(3):275-9. X-2, X-3. [pmid: 2505631].
106 Blair JM, Dobson GT, Hill DA, et al. Patient controlled analgesia for labour: A comparison of remifentanil with pethidine. Anaesthesia. 2005;60(1):22-27. X-3. [pmid: 15601268].
107 Blair JM, Hill DA, Fee JPH. Patient-controlled analgesia for labour using remifentanil: A feasibility study. Br J Anaesth. 2001;87(3):415-420. X-2, X-3. [pmid: 11517125].
108 Bland BA, Lawes EG, Duncan PW, et al. Comparison of midazolam and thiopental for rapid sequence anesthetic induction for elective cesarean section. Anesth Analg. Nov. 1987;66(11):1165-8. X-2, X-3. [pmid: 3662061].
109 Blechner JN, Stenger VG, Eitzman DV, et al. Oxygenation of the human fetus and newborn infant during maternal metabolic acidosis. Am J Obstet Gynecol. Sep. 1. 1970;108(1):47-55. X-3. [pmid: 5454583].
110 Blechner JN, Stenger VG, Prystowsky H. Uterine blood flow in women at term. Am J Obstet Gynecol. Nov. 1. 1974;120(5):633-40. X-2, X-3d, X-5. [pmid: 4421293].
111 Blechner JN, Stenger VG, Prystowsky H. Blood flow to the human uterus during maternal metabolic acidosis. Am J Obstet Gynecol. Mar. 15. 1975;121(6):789-94. X-2, X-3. [pmid: 1119488].
112 Blincoe AJ. TENS machines and their use in managing labour pain. Br J Midwifery. 2007;15(8):518-9. X-1, X-2, X-3.
113 Blitt CD, Petty WC, Alberternst EE, et al. Correlation of plasma cholinesterase activity and duration of action of succinylcholine during pregnancy. Anesth Analg. Jan-Feb. 1977;56(1):78-83. X-2, X-3a. [pmid: 556913].
114 Blumgart CH, Hughes DG, Redfern N. Obstetric anaesthesia in dystrophia myotonica. Anaesthesia. 1990;45(1):26-29. X-1, X-2, X-3. [pmid: 1969250].
115 Bobak M. Outdoor air pollution, low birth weight, and prematurity. Environ Health Perspect. Feb. 2000;108(2):173-6. X-2, X-3d. [pmid: 10656859].
116 Bodner M, White PF. Antiemetic efficacy of ondansetron after outpatient laparoscopy. Anesth Analg. 1991;73(3):250-254. X-2, X-3a. [pmid: 1831016].
117 Boekstegers P, Weidenhofer S, Pilz G, et al. Peripheral oxygen availability within skeletal muscle in sepsis and septic shock: Comparison to limited infection and cardiogenic shock. Infection. 1991;19(5):317-323. X-2, X-3. [pmid: 1800370].
118 Bogod DG, Rosen M, Rees GA. Maximum FIO2 during caesarean section. Br J Anaesth. Sep. 1988;61(3):255-62. X-2, X-3a, X-3d. [pmid: 3140861].
119 Bohra U, Donnelly J, O'Connell MP, et al. Active management of labour revisited: The first 1000 primiparous labours in 2000. J Obstet Gynaecol. 2003;23(2):118-120. X-3, X-5. [pmid: 12745551].
120 Boker A, Ong BY. Anesthesia for Cesarean section and posterior fossa craniotomy in a patient with von Hippel-Lindau disease. Can J Anaesth. 2001;48(4):387-390. X-1, X-2, X-3. [pmid: 11339783].
121 Bonsu AK, Stead AL. Accidental cross-connexion of oxygen and nitrous oxide in an anaesthetic machine. Anaesthesia. 1983;38(8):767-769. X-1, X-2, X-3. [pmid: 6881500].
122 Borup L, Wurlitzer W, Hedegaard M, et al. Acupuncture as pain relief during delivery: a randomized controlled trial. Birth. Mar. 2009;36(1):5-12. X-3, X-5. [pmid: 19278378].
123 Botta G, D'Angelo A, D'Ari G, et al. Epidural anesthesia in an in vitro fertilization and embryo transfer program. J Assist Reprod Genet. Mar. 1995;12(3):187-90. X-2, X-3a, X-5. [pmid: 8520183].
124 Bovill JG, Coppel DL, Dundee JW, et al. Current status of ketamine anaesthesia. Lancet. Jun. 19. 1971;1(7712):1285-8. X-1, X-2, X-3a, X-5. [pmid: 4104731].
125 Bowen SE, Hannigan JH. Developmental toxicity of prenatal exposure to Toluene. AAPS Journal. 2006;8(2):E419-E424. X-1, X-2, X-3d. [pmid: 16808045].
126 Boyle RK. Intra- and postoperative anaesthetic management of an opioid addict undergoing caesarean section. Anaesth Intensive Care. 1991;19(2):276-279. X-3. [pmid: 2069256].
127 Bradbury CL, Christensen BK, Lau MA, et al. The Efficacy of Cognitive Behavior Therapy in the Treatment of Emotional Distress After Acquired Brain Injury. Arch Phy Med Rehabil. 2008;89(12 SUPPL):S61-S68. X-2, X-3.
128 Brady JP, Rigatto H. Pulmonary capillary flow in the newborn infant: a new method using the plethysmograph and nitrous oxide. Pediatrics. Aug. 1971;48(2):207-15. X-2, X-3d, X-5. [pmid: 5560615].
129 Breslin DS, Mirakhur RK, Reid JE, et al. Manual versus target-controlled infusions of propofol. Anaesthesia. 1059. 59(11):1059-1063. X-2, X-3a, X-3d. [pmid: 15479311].
130 Brinsmead M. Fetal and neonatal effects of drugs administered in labour. Med J Aust. May. 4. 1987;146(9):481-6. X-1, X-2, X-3, X-5. [pmid: 2886897].
131 Brito MB, Ferriani RA, Quintana SM, et al. Safety of the etonogestrel-releasing implant during the immediate postpartum period: a pilot study. Contraception. 2009;80(6):519-526. X-2, X-3d. [pmid: 19913145].
132 Brock-Utne JG, Love AJ, Mankowitz E, et al. Indoprofen - a new non-opioid analgesic. A comparison with pethidine. S Afr Med J. 1985;68(11):803-804. X-2, X-3a. [pmid: 3906942].
133 Brodsky JB. Anesthesia and surgery during early pregnancy and fetal outcome. Clin Obstet Gynecol. 1983;26(2):449-457. X-1, X-2, X-3, X-5. [pmid: 6851293].
134 Brodsky JB. Exposure to anesthetic gases: a controversy. AORN J. Jul. 1983;38(1):132-7. 140. 1. 144. X-1, X-2, X-5. [pmid: 6554056].
135 Brodsky JB, Cohen EN. Adverse effects of nitrous oxide. Med Toxicol. Sep-Oct. 1986;1(5):362-74. X-1, X-2, X-3, X-5. [pmid: 3537624].
136 Brown DR, Fishburne JI, Roberson VO, et al. Ventilatory and blood gas changes during laparoscopy with local anesthesia. Am J Obstet Gynecol. Apr. 1. 1976;124(7):741-5. X-2, X-3. [pmid: 3971].
137 Brown SC, Hart G, Chastain DP, et al. Reducing distress for children during invasive procedures: Randomized clinical trial of effectiveness of the PediSedate. Paediatr Anaesth. 2009;19(8):725-731. X-2, X-3, X-5. [pmid: 19624359].
138 Browning AJ, Butt WR, Lynch SS, et al. Maternal and cord plasma concentrations of beta-lipotrophin, beta-endorphin and gamma-lipotrophin at delivery; effect of analgesia. Br J Obstet Gynaecol. Dec. 1983;90(12):1152-6. X-3d. [pmid: 6317007].
139 Brownridge P. A three-year survey of an obstetric epidural service with top-up doses administered by midwives. Anaesth Intensive Care. 1982;10(4):298-308. X-3, X-5. [pmid: 7158748].
140 Brownridge P. Shivering related to epidural blockade with bupivacaine in labour, and the influence of epidural pethidine. Anaesth Intensive Care. Nov. 1986;14(4):412-7. X-3, X-5. [pmid: 3551675].
141 Brownridge P. Treatment options for the relief of pain during childbirth. Drugs. Jan. 1991;41(1):69-80. X-1, X-2, X-3, X-5. [pmid: 1706989].
142 Brownridge P, Frewin DB. A comparative study of techniques of postoperative analgesia following Caesarean section and lower abdominal surgery. Anaesth Intensive Care. 1985;13(2):123-130. X-2, X-3a, X-3d. [pmid: 3893208].
143 Bryant HE, Love EJ. Effect of employment and its correlates on spontaneous abortion risk. Soc Sci Med. 1991;33(7):795-800. X-2, X-3. [pmid: 1948170].
144 Bui TH, Grunewald C, Frenckner B, et al. Successful EXIT (Ex Utero Intrapartum Treatment) procedure in a fetus diagnosed prenatally with congenital high-airway obstruction syndrome due to laryngeal atresia. Eur J Pediatr Surg. 2000;10(5):328-333. X-1, X-2, X-3. [pmid: 11194545].
145 Bunatian A, Trekova N, Flerov E, et al. Oxygen delivery and consumption during open heart surgery: A comparison of combined inhalational and total intravenous anaesthesia. J Cardiothorac Vasc Anesth. 1994;8(3 SUPPL. 2). X-2, X-3a, X-5.
146 Bundsen P, Ericson K, Peterson LE, et al. Pain relief in labor by transcutaneous electrical nerve stimulation. Testing of a modified stimulation technique and evaluation of the neurological and biochemical condition of the newborn infant. Acta Obstet Gynecol Scand. 1982;61(2):129-36. X-5. [pmid: 7051741].
147 Bundsen P, Peterson LE, Selstam U. Pain relief in labor by transcutaneous electrical nerve stimulation. A prospective matched study. Acta Obstet Gynecol Scand. 1981;60(5):459-68. X-3, X-5. [pmid: 6975549].
148 Bundsen P, Peterson LE, Selstam U. Pain relief during delivery. An evaluation of conventional methods. Acta Obstet Gynecol Scand. 1982;61(4):289-97. X-5. [pmid: 7148402].
149 Burkhart JE, Stobbe TJ. Real-time measurement and control of waste anesthetic gases during veterinary surgeries. Am Ind Hyg Assoc J. 1990;51(12):640-645. X-2, X-3, X-5. [pmid: 2270831].
150 Burns AM, Dorje P, Lawes EG, et al. Anaesthetic management of caesarean section for a mother with pre-eclampsia, the Klippel-Feil syndrome and congential hydrocephalus. Br J Anaesth. 1988;61(3):350-354. X-1, X-2, X-3. [pmid: 3179155].
151 Burns SM, Barclay PM. Regional anaesthesia for Caesarean section. Curr Anaesth Crit Care. 2000;11(2):73-79. X-1, X-2, X-3.
152 Cade L, Ross AW. Is fentanyl effective for postoperative analgesia in day-surgery?. Anaesth Intensive Care. Feb. 1992;20(1):38-40. X-2, X-3a, X-3b. [pmid: 1609939].
153 Calleja MA. Extradural analgesia and previous spinal surgery. A radiological appraisal. Anaesthesia. 1991;46(11):946-947. X-1, X-2, X-3, X-5. [pmid: 1750597].
154 Camous J, N'Da A, Etienne-Julan M, et al. Anesthetic management of pregnant women with sickle cell disease - Effect on postnatal sickling complications. Can J Anaesth. 2008;55(5):276-283. X-2, X-3d. [pmid: 18451115].
155 Candido R, Toffoli B, Bernardi S, et al. Systemic osteoprotegerin delivery induces pancreatic islet structural and functional alterations in non-diabetic mice. Diabetologia. Conference: 45th EASD Annual Meeting of the European Association for the Study of Diabetes. Vienna Austria. Conference Start. 2009. 52(S1). X-2, X-3.
156 Capogna G, Alahuhtat S, Celleno D, et al. Maternal expectations and experiences of labour pain and analgesia: a multicentre study of nulliparous women. Int J Obstet Anesth. Oct. 1996;5(4):229-35. X-5. [pmid: 15321321].
157 Carli F, Creagh-Barry P, Gordon H, et al. Does epidural analgesia influence the mode of delivery in primiparae managed actively? A preliminary study of 1250 women. Int J Obstet Anesth. 1993;2(1):15-20. X-3, X-5. [pmid: 15636843].
158 Carlsson C, Nybell-Lindahl G, Ingemarsson I. Extradural block in patients who have previously undergone caesarean section. Br J Anaesth. Aug. 1980;52(8):827-30. X-3d, X-5. [pmid: 7426260].
159 Carnie JC, Perks D. The pattern of postoperative analgesic administration in non-English speaking Asian women following Caesarean section. Ann R Coll Surg Engl. 1984;66(5):365-366. X-2, X-3a, X-3d. [pmid: 6486675].
160 Carnie JC, Street MK, Kumar B. Emergency intubation of the trachea facilitated by suxamethonium. Observations in obstetric and general surgical patients. Br J Anaesth. 1986;58(5):498-501. X-2, X-3a. [pmid: 3964514].
161 Carr D. Epidural analgesia in labor--why not? The patient's point of view. Proc R Soc Med. Sep. 1972;65(9):758. X-1, X-2, X-3, X-5. [pmid: 5085058].
162 Carson RJ. Clinical The administration of analgesics. Modern Midwife. 1996;6(11):12-6. X-1, X-2, X-5. [pmid: 9052149].
163 Carter JA, Dye AM, Cooper GM. Recovery from day-case anaesthesia. The effect of different inhalational anaesthetic agents. Anaesthesia. Jun. 1985;40(6):545-8. X-2, X-3a. [pmid: 4025747].
164 Carvalho B, Mirikitani EJ, Lyell D, et al. Neonatal chest wall rigidity following the use of remifentanil for cesarean delivery in a patient with autoimmune hepatitis and thrombocytopenia. Int J Obstet Anesth. 2004;13(1):53-56. X-1, X-2, X-3. [pmid: 15321443].
165 Caton D, Corry MP, Frigoletto FD, et al. The nature and management of labor pain: Executive summary. Am J Obstet Gynecol. 2002;186(5 SUPPL):S1-S15. X-1, X-2, X-3. [pmid: 12011869].
166 Celeski D, Micho J, Walters L. Anesthetic implications of a partial molar pregnancy and associated complications. J Am Assoc Nurse Anesth. 2001;69(1):49-53. X-2, X-3b, X-3d.
167 Celik-Ozenci C, Tekcan M, Sati L, et al. Abamectin pesticide exposure and male infertility: Human exposure studies supported by animal studies point out a considerable relationship. Fertility and Sterility. Conference: 65th Annual Meeting of the American Society for Reproductive Medicine, ASRM. 2009. 92(3 SUPPL. 1). X-2, X-3.
168 Cesur M, Alici HA, Erdem AF, et al. Decreased incidence of headache after unintentional dural puncture in patients with cesarean delivery administered with postoperative epidural analgesia. J Anesth. 2009;23(1):31-35. X-2, X-3d. [pmid: 19234819].
169 Chambers JA, Guly HR. The need for better pre-hospital analgesia. Arch Emerg Med. 1993;10(3):187-192. X-2, X-3, X-5. [pmid: 8216592].
170 Chan CS, Lo JR, Wong KC. Vomiting after anaesthesia for termination of pregnancy in Chinese. Singapore Med J. 1984;25(3):173-175. X-2, X-3a, X-3b, X-5. [pmid: 6484587].
171 Chan SC, Lo JR, Wong KC. Vomiting after anaesthesia for termination of pregnancy in Chinese. Singapore Med J. 1983;24(6):360-362. X-2, X-3a, X-3b, X-5. [pmid: 6681491].
172 Chan SY, Chiu JW. Intrathecal labor analgesia using levobupivacaine 2.5 mg with fentanyl 25 mug - Would half the dose suffice?. Med Sci Monit. 2004;10(10):I110-PI114. X-3a, X-3d.
173 Chance DKE, Alderson JD. Adult spina bifida. Care of the Critically Ill. 1999;15(5):176-179. X-1, X-2, X-3d.
174 Chandler M. Pressure changes in tracheal tube cuffs. Anaesthesia. 1986;41(3):287-293. X-1, X-2, X-3d. [pmid: 3963332].
175 Chang L, Looi-Lyons L, Bartosik L, et al. Anesthesia for cesarean section in two patients with brain tumours. Can J Anaesth. 1999;46(1):61-65. X-2, X-3d. [pmid: 10078406].
176 Chapman AB, Zamudio S, Woodmansee W, et al. Systemic and renal hemodynamic changes in the luteal phase of the menstrual cycle mimic early pregnancy. Am J Physiol Renal Physiol. 1997;273(5 42-5):F777-F782. X-2, X-3.
177 Chatterjee DJ, Bukunola B, Samuels TL, et al. Resuscitation in massive obstetric haemorrhage using an intraosseous needle. Anaesthesia. 2011;66(4):306-310. X-1, X-2, X-3d. [pmid: 21401545].
178 Chauhan G, Verma Y, Sood A, et al. Full term secondary abdominal pregnancy and its anaesthetic management. J Anaesthesiol Clin Pharmacol. 2003;19(1):73-75. X-2, X-3d.
179 Chessor E, Verhoeven M, Hon CY, et al. Evaluation of a modified scavenging system to reduce occupational exposure to nitrous oxide in labor and delivery rooms. J Occup Environ Hyg. Jun. 2005;2(6):314-22. X-5. [pmid: 16020092].
180 Chestnut DH. Effect of anesthesia for repeat cesarean section on postoperative infectious morbidity. Obstet Gynecol. 1985;66(2):199-202. X-2, X-3, X-5. [pmid: 4022483].
181 Chestnut DH, Noe AL. Effect of anesthesia for primary cesarean section on postoperative infectious morbidity. Obstet Gynecol. 1986;68(5):667-670. X-2, X-3d, X-5. [pmid: 3763081].
182 Chi C, Lee CA, England A, et al. Obstetric analgesia and anaesthesia in women with inherited bleeding disorders. Thromb Haemost. Jun. 2009;101(6):1104-11. X-3, X-5. [pmid: 19492155].
183 Chilvers RJ, Weisz M. Entonox equipment as a potential source of cross-infection. Anaesthesia. Feb. 2000;55(2):176-9. X-2, X-3, X-5. [pmid: 10651683].
184 Chin KJ, Yeo SW. A BIS-guided study of sevoflurane requirements for adequate depth of anaesthesia in Caesarean section. Anaesthesia. 1064. 59(11):1064-1068. X-2, X-3d. [pmid: 15479312].
185 Chin KJ, Yeo SW. Bispectral index values at sevoflurane concentrations of 1% and 1.5% in lower segment cesarean delivery. Anesth Analg. Apr. 2004;98(4):1140-4. table of contents. X-2, X-3, X-5. [pmid: 15041614].
186 Chiodo GT, Rosenstein DI. Pregnancy and risks in the dental office. Dent Assist. Mar-Apr. 1986;55(2):9-12. X-1, X-2, X-3d, X-5. [pmid: 3457723].
187 Chortkoff BS, Gonsowski CT, Bennett HL, et al. Subanesthetic concentrations of desflurane and propofol suppress recall of emotionally charged information. Anesth Analg. 1995;81(4):728-736. X-2, X-3d. [pmid: 7574002].
188 Cieslak GD, Watcha MF, Phillips MB, et al. The dose-response relation and cost-effectiveness of granisetron for the prophylaxis of pediatric postoperative emesis. Anesthesiol. 1076. 85(5):1076-1085. X-2, X-3d.
189 Clark AJ, Hurtig JB. Premedication with meperidine and atropine does not prolong recovery to street fitness after out-patient surgery. Can Anaesth Soc J. Jul. 1981;28(4):390-3. X-2, X-3b, X-3d. [pmid: 7260717].
190 Clark RB, Cooper JO, Stephens SR, et al. Neonatal acid-base studies. II. Effect of a heavy medication-narcotic antagonists regimen for labor and delivery. Obstet Gynecol. Jan. 1969;33(1):30-4. X-3, X-5. [pmid: 5773867].
191 Clark V. Women should be told ALL risks before regional anaesthesia is performed. Int J Obstet Anesth. 2006;15(4):303-305. X-1, X-2, X-3, X-5. [pmid: 16949274].
192 Clarke RB, Cooper JO, Brown WE, et al. The effect of methoxyflurane on the foetus. Br J Anaesth. Apr. 1970;42(4):286-94. X-3, X-5. [pmid: 5427261].
193 Cluett E. Analgesia in labour: a review of the TENS method. Prof Care Mother Child. Mar. 1994;4(2):50-2. X-1, X-2, X-3d. [pmid: 8680162].
194 Coad NR, Mills PJ, Verma R, et al. Evaluation of blood loss during suction termination of pregnancy: Ketamine compared with methohexitone. Acta Anaesthesiol Scand. 1986;30(3):253-255. X-2, X-3b. [pmid: 3739583].
195 Coen VLMA, Marijnissen JPA, Ligthart JMR, et al. Inaccuracy in manual multisegmental irradiation in coronary arteries. Radiother Oncol. 2002;63(1):89-95. X-2, X-3. [pmid: 12065108].
196 Coffey PS, Kilbourne-Brook M. Wear and care of the SILCS diaphragm: Experience from three countries. Sex Health. 2010;7(2):159-164. X-2, X-3. [pmid: 20465980].
197 Cohen E, Eisenkraft JB, Thys DM, et al. Oyxgenation and hemodynamic changes during one-lung ventilation: Effects of CPAP10, PEEP10, and CPAP10/PEEP10. J Cardiothorac Anesth. 1988;2(1):34-40. X-2, X-3. [pmid: 2979130].
198 Cohen EN, Bellville JW, Brown BW Jr. Anesthesia, pregnancy, and miscarriage: a study of operating room nurses and anesthetists. Anesthesiology. Oct. 1971;35(4):343-7. X-3a, X-5. [pmid: 5114397].
199 Cohen EN, Gift HC, Brown BW, et al. Occupational disease in dentistry and chronic exposure to trace anesthetic gases. J Am Dent Assoc. Jul. 1980;101(1):21-31. X-2, X-3, X-5. [pmid: 6930434].
200 Cohen LB. Fospropofol disodium: New perspectives on endoscopic procedures. Rev Gastroenterol Disord. 2008;8(3):213-216. X-1, X-2, X-3, X-5. [pmid: 18957928].
201 Coker A, Govindan DSOT, Richardson RE, et al. Antenatal care and delivery of a patient with a ventriculo-peritoneal shunt. J Obstet Gynaecol. 1997;17(5):489-490. X-1, X-2, X-3, X-5. [pmid: 15511934].
202 Cole PV. The problem of pollution in the dental surgery. SAAD Dig. Jan. 1981;4(9):210-6. X-1, X-2, X-3d, X-5. [pmid: 6940249].
203 Cole PV, Crawford JS, Doughty AG, et al. Specifications and recommendations for nitrous oxide-oxygen apparatus to be used in obstetric analgesis. Anaesthesia. Jul. 1970;25(3):317-27. X-1, X-2, X-5. [pmid: 5431056].
204 Coleman AJ, Downing JW. Ethrane anaesthesia for caesarean section. S Afr Med J. Nov. 1. 1975;49(46):1927-9. X-2, X-3d. [pmid: 1198216].
205 Coleman P. McArdle's disease. Problems of anaesthetic management for Caesarean section. Anaesthesia. 1984;39(8):784-787. X-2, X-3d. [pmid: 6591841].
206 Colle I, Van Steenkiste C, Geerts A, et al. Hepatopulmonary Syndrome and Portopulmonary Hypertension: What's new?. Acta Gastroenterol Belg. 2007;70(2):203-209. X-1, X-2, X-3d. [pmid: 17715635].
207 Collins KM, Plantevin OM. Use of alfentanil in short anaesthetic procedures. J R Soc Med. 1985;78(6):456-458. X-1, X-2, X-3d. [pmid: 3923191].
208 Collins KM, Plantevin OM, Whitburn RH, et al. Outpatient termination of pregnancy: Halothane or alfentanil-supplemented anaesthesia. Br J Anaesth. 1226. 57(12):1226-1231. X-2, X-3b. [pmid: 3936528].
209 Collis R. Combined spinal epidural (CSE) analgesia is the preferred technique for labour pain relief. Acta Anaesthesiol Belg. 2002;53(4):283-287. X-1, X-2, X-3a, X-5. [pmid: 12503351].
210 Colohan DP. Nitrous oxide: A nonnarcotic analgesic for emergency use. Med Instrum. 1982;16(6):293-294. X-2, X-3d. [pmid: 7155020].
211 Compagnoni G, Lista G, Giuffre B, et al. Coenzyme Q10 levels in maternal plasma and cord blood:correlations with mode of delivery. Biol Neonate. 2004;86(2):104-7. X-3a, X-3d, X-5. [pmid: 15133315].
212 Condie RG, Tunstall ME. Chlormethiazole as a sedative in normal labour. Acta Anaesthesiol Scand Suppl. 1969;37:192-7. X-3a, X-3d, X-5. [pmid: 4912111].
213 Conkin KA, Herr G, Fung D. Anaesthesia for Caesarean section and cerebral aneurysm clipping. Canadian Anaesthetists Society Journal. 1984;31(4):451-454. X-2, X-3d. [pmid: 6744094].
214 Connell H, Dalgleish JG, Downing JW. General anaesthesia in mothers with severe pre-eclampsia/eclampsia. Br J Anaesth. 1375. 59(11):1375-1380. X-2, X-3d. [pmid: 3689611].
215 Constantine G, Luesley DM, Redman CW, et al. Racial variations in the choice of analgesia in labour. J Obstet Gynaecol. 1989;9(3):189-192. X-5.
216 Cook DJ, Oliver WC Jr, Orszulak TA, et al. Cardiopulmonary bypass temperature, hematocrit, and cerebral oxygen delivery in humans. Ann Thorac Surg. 1671. 60(6):1671-1677. X-2, X-3. [pmid: 8787461].
217 Cook IHE. Cesarean section in a patient with brain tumor: A clinical report. Military Medicine. 1989;154(6):330-331. X-2, X-3a, X-3d. [pmid: 2498772].
218 Cook WP, Shultetus RR, Caton D. A comparison of d-tubocurarine pretreatment and no pretreatment of obstetric patients. Anesth Analg. 1987;66(8):756-760. X-2, X-3a, X-3d. [pmid: 3605694].
219 Cooper GM, MacArthur C, Wilson MJA, et al. Satisfaction, control and pain relief: short- and long-term assessments in a randomised controlled trial of low-dose and traditional epidurals and a non-epidural comparison group. Int J Obstet Anesth. 2010;19(1):31-37. X-5. [pmid: 19945274].
220 Corbett TH. Anesthetics as a cause of abortion. Fertil Steril. Nov. 1972;23(11):866-9. X-1, X-2, X-3, X-5. [pmid: 5082621].
221 Corbett TH, Cornell RG, Endres JL, et al. Birth defects among children of nurse-anesthetists. Anesthesiology. Oct. 1974;41(4):341-4. X-3d, X-5. [pmid: 4412215].
222 Corbett WL, Reiter CM, Schultz JR, et al. Anaesthetic management of a parturient with the postural orthostatic tachycardia syndrome: A case report. Br J Anaesth. 2006;97(2):196-199. X-2, X-3a, X-3d. [pmid: 16698864].
223 Corriveau S, Berthiaume M, Rousseau E, et al. Is it possible to improve the tocolytic effect of indomethacine by inhibition of eicosanoids metabolic pathways in pregnant women uterus?. Am J Obstet Gynecol Conference. 2010;201(6 SUPPL. 1). X-2, X-3d.
224 Corssen G. Ketamine in obstetric anesthesia. Clin Obstet Gynecol. Jun. 1974;17(2):249-58. X-1, X-2, X-3, X-5. [pmid: 4844201].
225 Corssen G. Neuroleptanalgesia and anesthesia in obstetrics. Clin Obstet Gynecol. Jun. 1974;17(2):241-8. X-1, X-2, X-3, X-5. [pmid: 4844200].
226 Cosmi EV, Marx GF. Acid-base status of the fetus and clinical condition of the newborn following cesarean section. Am J Obstet Gynecol. Oct. 1. 1968;102(3):378-82. X-3. [pmid: 5675887].
227 Cousins MJ, Plummer JL, De la Hall MP. Toxicity of volatile anaesthetic agents. Clin Anaesthesiol. 1984;2(3):551-575. X-1, X-2, X-3d.
228 Craig J, Cooper GM, Sear JW. Recovery from day-case anaesthesia. Comparison between methohexitone, Althesin and etomidate. Br J Anaesth. Apr. 1982;54(4):447-51. X-2, X-3d. [pmid: 7066142].
229 Cravello L, D'Ercole C, Roger V, et al. Laparoscopic surgery in gynecology: Randomized prospective study comparing pneumoperitoneum and abdominal wall suspension. Eur J Obstet Gynecol Reprod Biol. 1999;83(1):9-14. X-2, X-3a, X-3d. [pmid: 10221603].
230 Crawford JS. Analgesia and anaesthesia in labour. Practitioner. May. 1974;212(1271):677-88. X-1, X-2, X-5. [pmid: 4462714].
231 Crawford JS. Premedication for elective caesarean section. Anaesthesia. 1979;34(9):892-897. X-2, X-3d. [pmid: 43682].
232 Crawford JS. General analgesia and anaesthesia in obstetrics. Clinics in Anaesthesiology. 1986;4(1):157-169. X-1, X-2, X-3, X-5.
233 Crawford JS, Burton M, Davies P. Anaesthesia for section: further refinements of a technique. Br J Anaesth. Jul. 1973;45(7):726-32. X-2, X-3a, X-3d, X-5. [pmid: 4730165].
234 Crawford JS, Ellis DB, Hill DW, et al. Effects of cooling on the safety of premixed gases. Br Med J. Apr. 15. 1967;2(5545):138-42. X-2, X-3, X-5. [pmid: 6021311].
235 Crawford JS, Lewis M. Nitrous oxide in early human pregnancy. Anaesthesia. Sep. 1986;41(9):900-5. X-2, X-3d. [pmid: 3777393].
236 Crawford JS, Lewis M, Davies P. Maternal and neonatal responses related to the volatile agent used to maintain anaesthesia at Caesarean section. Br J Anaesth. 1985;57(5):482-487. X-2, X-3a, X-3d. [pmid: 3994881].
237 Crawford JS, Tunstall ME. Notes on respiratory performance during labour. Br J Anaesth. Aug. 1968;40(8):612-4. X-3d, X-5. [pmid: 5667306].
238 Crawford ME, Carl P, Andersen RS, et al. Comparison between midazolam and thiopentone-based balanced anaesthesia for day-case surgery. Br J Anaesth. Feb. 1984;56(2):165-9. X-2, X-3b, X-3d. [pmid: 6691877].
239 Crawford ME, Carl P, Bach V, et al. A randomized comparison between midazolam and thiopental for elective cesarean section anesthesia. I. Mothers. Anesth Analg. Mar. 1989;68(3):229-33. X-2, X-3a, X-3d. [pmid: 2919758].
240 Crimi E, Baggish A, Leffert L, et al. Acute reversible stress-induced cardiomyopathy associated with cesarean delivery under spinal anesthesia. Circulation. 3052. 117(23):3052-3053. X-1, X-2, X-3, X-5. [pmid: 18541755].
241 Critchlow BM, Ibrahim Z, Pollard BJ. General anaesthesia for gamete intra-fallopian transfer. Eur J Anaesthesiol. Sep. 1991;8(5):381-4. X-2, X-3a, X-3d. [pmid: 1935926].
242 Crowhurst JA, Rosen M. General anaesthesia for caesarean section in severe pre-eclampsia. Comparison of the renal and hepatic effects of enflurane and halothane. Br J Anaesth. Jun. 1984;56(6):587-97. X-2, X-3, X-5. [pmid: 6721970].
243 Cui T, Liu Y, Men X, et al. Bile acid transport correlative protein mRNA expression profile in human placenta with intrahepatic cholestasis of pregnancy. Saudi Med J. 1406. 30(11):1406-1410. X-2, X-3d. [pmid: 19882051].
244 Cullen BF, Margolis AJ, Eger EI 2nd. The effects of anesthesia and pulmonary ventilation on blood loss during elective therapeutic abortion. Anesthesiology. Feb. 1970;32(2):108-13. X-2, X-3b, X-5. [pmid: 4391841].
245 Cundy JM, Arunasalam K. Use of an emulsion formulation of propofol (‘Diprivan’) in intravenous anaesthesia for termination of pregnancy. A comparison with methohexitone. Postgrad Med J. 1985;61(SUPPL. 3):129-131. X-2, X-3b, X-3d. [pmid: 3877280].
246 Cundy JM, Read PJ. The acceptability of day stay for termination of pregnancy. Br J Clin Pract. Jun. 1981;35(6):215-8. X-1, X-2, X-3b, X-5. [pmid: 7306456].
247 Cunningham AJ, Crowley KJ, Tierney E. Elderly parturient with rheumatic heart disease presenting for caesarean section: Haemodynamic monitoring and anaesthesia management. Irish Medical Journal. 1985;78(11):333-337. X-1, X-2, X-3d. [pmid: 4077464].
248 Curatolo M, Derighetti M, Petersen-Felix S, et al. Fuzzy logic control of inspired isoflurane and oxygen concentrations using minimal flow anaesthesia. Br J Anaesth. 1996;76(2):245-250. X-2, X-3d. [pmid: 8777105].
249 Curran MJ, Donati F, Bevan DR. Onset and recovery of atracurium and suxamethonium-induced neuromuscular blockade with simultaneous train-of-four and single twitch stimulation. Br J Anaesth. 1987;59(8):989-994. X-2, X-3d. [pmid: 3651281].
250 Dabo F, Nyberg F, Qin Z, et al. Plasma levels of beta-endorphin during pregnancy and use of labor analgesia. Reprod Sci. Aug. 2010;17(8):742-7. X-3d, X-5. [pmid: 20595705].
251 Dahl V, Fjellanger F, Raeder JC. No effect of preoperative paracetamol and codeine suppositories for pain after termination of pregnancies in general anaesthesia. Eur J Pain. 2000;4(2):211-215. X-2, X-3b, X-3d. [pmid: 10957701].
252 Dahlgren BE. Influence of methoxyflurane-nitrous oxide analgesia during childbirth on renal and hepatic function. Br J Anaesth. Dec. 1977;49(12):1271-7. X-5. [pmid: 588403].
253 Dahlgren BE. Urinary fluoride concentration in mothers and neonates after methoxyflurane-nitrous oxide analgesia during labour. Acta Pharm Suec. 1978;15(3):211-7. X-3, X-5. [pmid: 716954].
254 Dahlgren BE. Fluoride concentrations in urine of delivery ward personnel following exposure to low concentrations of methoxyflurane. J Occup Med. Sep. 1979;21(9):624-6. X-5. [pmid: 490224].
255 Dahlgren BE, Olander L, Ovrum P. Pollution of delivery ward air by nitrous oxide--methoxyflurane. Am Ind Hyg Assoc J. Aug. 1979;40(8):666-72. X-3, X-5. [pmid: 495468].
256 Dahlgren G, Tornberg DC, Pregner K, et al. Four cases of the ex utero intrapartum treatment (EXIT) procedure: Anesthetic implications. Int J Obstet Anesth. 2004;13(3):178-182. X-1, X-2, X-3d. [pmid: 15321398].
257 Dailey PA, Fisher DM, Shnider SM. Pharmacokinetics, placental transfer, and neonatal effects of vecuronium and pancuronium administered during cesarean section. Anesthesiology. 1984;60(6):569-574. X-2, X-3d. [pmid: 6145374].
258 Dailland P, Cockshott ID, Lirzin JD, et al. Intravenous propofol during cesarean section: placental transfer, concentrations in breast milk, and neonatal effects. A preliminary study. Anesthesiology. Dec. 1989;71(6):827-34. X-2, X-3d. [pmid: 2589672].
259 Dale O, Husum B. Nitrous oxide: at threat to personnel and global environment?. Acta Anaesthesiol Scand. Nov. 1994;38(8):777-9. X-1, X-2, X-5. [pmid: 7887098].
260 Daniel-Spiegel E, Weiner Z, Ben-Shlomo I, et al. For how long should oxytocin be continued during induction of labour?. BJOG. 2004;111(4):331-334. X-2, X-3d. [pmid: 15008768].
261 Dannecker C, Lienemann A, Fischer T, et al. Influence of spontaneous and instrumental vaginal delivery on objective measures of pelvic organ support: Assessment with the pelvic organ prolapse quantification (POPQ) technique and functional cine magnetic resonance imaging. Eur J Obstet Gynecol Reprod Biol. 2004;115(1):32-38. X-2, X-3d, X-5. [pmid: 15223162].
262 Daponte A, Nzewenga G, Dimopoulos KD, et al. The use of vaginal misoprostol for second-trimester pregnancy termination in women with previous single cesarean section. Contraception. 2006;74(4):324-327. X-2, X-3b. [pmid: 16982234].
263 Das S, Mitra S. A comparative apgar score study on neonates born by caesarean section under general anaesthesia and epidural analgesia. J Indian Med Assoc. 1988;86(6):149-151. X-2, X-3, X-5. [pmid: 3241085].
264 Datta S, Brown WU Jr. Acid-base status in diabetic mothers and their infants following general or spinal anesthesia for cesarean section. Anesthesiology. Sep. 1977;47(3):272-6. X-2, X-3d. [pmid: 18953].
265 David AL, Kotecha M, Girling JC. Factors influencing postnatal liver function tests. BJOG. Nov. 2000;107(11):1421-6. X-2, X-3a, X-3d, X-5. [pmid: 11117773].
266 Davies CK. Anaesthesia for an obstetric flying squad. Br J Anaesth. Jun. 1969;41(6):545-50. X-1, X-2, X-3, X-5. [pmid: 4893423].
267 Davies JM, Hogg M, Rosen M. Maternal arterial oxygen tension during intermittent inhalation analgesia. Br J Anaesth. Mar. 1975;47(3):370-8. X-2. [pmid: 237516].
268 Davies JM, Hogg M, Rosen M, et al. Upper limits of resistance of apparatus used for inhalation analgesia during labour: response of mothers. Br J Anaesth. Jan. 1973;45(1):116. X-3, X-5. [pmid: 4696422].
269 Davies JM, Hogg MI, Rosen M. The resistance of Entonox valves. Br J Anaesth. Feb. 1974;46(2):145-8. X-2, X-3, X-5. [pmid: 4525177].
270 Davies JM, Hogg MI, Rosen M. Upper limits of resistance of apparatus for inhalation analgesia during labour. Response of mothers to increasing apparatus resistance. Br J Anaesth. Feb. 1974;46(2):136-44. X-3d, X-5. [pmid: 4525176].
271 Davies JM, Willis BA, Rosen M. Entonox analgesia in labour. A pilot study to reduce the delay between demand and supply. Anaesthesia. Jun. 1978;33(6):545-7. X-2. [pmid: 686318].
272 Davis AG, Moir DD. Anaesthesia during pregnancy. Clin Anaesthesiol. 1986;4(2):233-245. X-1, X-2, X-3, X-5.
273 De Assuncao Braga ADF, Sampaio Rousselet M, Zambelli H, et al. Anesthesia for intrauterine myelomeningocele correction. Case report. [Portuguese, English]. Rev Bras Anestesiol. 2005;55(3):329-335. X-1, X-2, X-3. [pmid: 19471837].
274 De Cooman S, De Mey N, Dewulf BBC, et al. Desflurane consumption during automated closed-circuit delivery is higher than when a conventional anesthesia machine is used with a simple vaporizer-O2-N2O fresh gas flow sequence. BMC Anesthesiology. 2008;8(4). X-2, X-3.
275 De Cooman S, De Mey N, Dewulf BBC, et al. Desflurane consumption during automated closed-circuit delivery is higher than when a conventional anesthesia machine is used with a simple vaporizer-O<sub>2</sub>-N<sub>2</sub>O fresh gas flow sequence. BMC Anesthesiology. 2008;8(4). X-2, X-3.
276 de Costa CM. Snow - At Christmas. Med J Aust. 2007;187(11-12):690-692. X-1, X-2, X-3, X-5. [pmid: 18072924].
277 De Jongh RF, Bosmans EP, Puylaert MJ, et al. The influence of anaesthetic techniques and type of delivery on peripartum serum interleukin-6 concentrations. Acta Anaesthesiol Scand. 1997;41(7):853-860. X-3d, X-5. [pmid: 9265928].
278 De Oliveira Rodrigues, Filho G, Gesser N, Ghellar MR, et al. Minimum analgesic concentration of bupivacaine after continuous epidural infusion following spinal anesthesia in the postoperative period of leg, ankle and foot surgery. [Portuguese, English]. Rev Bras Anestesiol. 2001;51(5):385-393. X-2, X-3.
279 Delaney AG. Anesthesia in the pregnant woman. Clin Obstet Gynecol. 1983;26(4):795-800. X-1, X-2, X-3. [pmid: 6661835].
280 Delis KT, Knaggs AL, Mason P, et al. Effects of epidural-and-general anesthesia combined versus general anesthesia alone on the venous hemodynamics of the lower limb. A randomized study. Thromb Haemost. 1003. 92(5):1003-1011. X-2, X-3. [pmid: 15543327].
281 Denison FC, Kelly RW, Calder AA, et al. Secretory leukocyte protease inhibitor concentration increases in amniotic fluid with the onset of labour in women: Characterization of sites of release within the uterus. J Endocrinol. 1999;161(2):299-306. X-2, X-3. [pmid: 10320828].
282 Dermitzaki E, Staikou C, Petropoulos G, et al. A randomized study of maternal serum cytokine levels following cesarean section under general or neuraxial anesthesia. Int J Obstet Anesth. Jan. 2009;18(1):33-7. X-2, X-3. [pmid: 19026531].
283 Derom R, Thiery M, Rolly G. Effects of general anesthesia on the acid-base balance of the human fetus during elective caesarean section. Acta Anaesthesiol Belg. 1974;25(1):33-5. X-2, X-3a, X-3d, X-5. [pmid: 4407428].
284 Desai S, Leong SB, Yvonne L, et al. Chronobiology of parturients receiving neuraxial labour analgesia with ropivacaine and fentanyl: a prospective cohort study. Int J Obstet Anesth. 2009;18(1):43-47. X-3. [pmid: 19046873].
285 Desai SK, Nariani CM, Allahbadia GN, et al. Fallopian tube sperm perfusion versus intrauterine insemination: A preliminary report from a University teaching hospital. Middle East Fertil Soc J. 1998;3(3):267-271. X-2, X-3.
286 Deschler PE. Anesthetic assessment and management of the pregnant renal transplant recipient. J Am Assoc Nurse Anesth. 1983;51(5):511-520. X-1, X-2, X-3d, X-5.
287 Dewan DM, Floyd HM, Thistlewood JM. Sodium citrate pretreatment in elective cesarean section patients. Anesth Analg. 1985;64(1):34-37. X-2, X-3. [pmid: 3966649].
288 Dewan DM, Wheeler AS, James FM 3rd, et al. Antacid anticholinergic regimens in patients undergoing elective caesarean section. Can Anaesth Soc J. Jan. 1982;29(1):27-30. X-2, X-3. [pmid: 7055741].
289 Dewan DM, Writer WD, Wheeler AS, et al. Sodium citrate premedication in elective caesarean section patients. Can Anaesth Soc J. Jul. 1982;29(4):355-8. X-2, X-3. [pmid: 7104805].
290 Dich-Nielsen J, Holasek J. Ketamine as induction agent for caesarean section. Acta Anaesthesiol Scand. Apr. 1982;26(2):139-42. X-2, X-3a, X-3d, X-5. [pmid: 7102236].
291 Dick W, Traub E, Kraus H, et al. General anaesthesia versus epidural anaesthesia for primary caesarean section--a comparative study. Eur J Anaesthesiol. Jan. 1992;9(1):15-21. X-2, X-3. [pmid: 1735394].
292 Dickinson JE, Godfrey M, Evans SF, et al. Factors influencing the selection of analgesia in spontaneously labouring nulliparous women at term. Aust N Z J Obstet Gynaecol. Aug. 1997;37(3):289-93. X-3a, X-5. [pmid: 9325507].
293 Dickinson JE, Paech MJ, McDonald SJ, et al. The impact of intrapartum analgesia on labour and delivery outcomes in nulliparous women. Aust NZ J Obstet Gynaecol. 2002;42(1):59-66. X-5.
294 Dickinson JE, Paech MJ, McDonald SJ, et al. Maternal satisfaction with childbirth and intrapartum analgesia in nulliparous labour. Aust N Z J Obstet Gynaecol. Dec. 2003;43(6):463-8. X-3a, X-5. [pmid: 14712952].
295 Ding Y, Fredman B, White PF. Use of ketorolac and fentanyl during outpatient gynecologic surgery. Anesth Analg. 1993;77(2):205-210. X-2, X-3. [pmid: 8346816].
296 Dingley J, Hughes LG. Xenon: A replacement for nitrous oxide. Curr Opin Anaesthesiol. 2000;13(4):443-447. X-1, X-2, X-3, X-5. [pmid: 17016339].
297 Dinwiddie R, Russell G. The measurement of effective pulmonary capillary blood flow in the newborn, using low concentrations of nitrous oxide. Biol Neonate. 1972;21(1):83-9. X-2, X-3, X-5. [pmid: 4651154].
298 Dixon JB, Dixon ME, O'Brien PE. Pregnancy after Lap-Band surgery: Management of the band to achieve healthy weight outcomes. Obes Surg. 2001;11(1):59-65. X-2, X-3. [pmid: 11361170].
299 Dob DP, Yentis SM. UK registry of high-risk obstetric anaesthesia: Report on cardiorespiratory disease. Int J Obstet Anesth. 2001;10(4):267-272. X-1, X-2, X-3, X-5. [pmid: 15321583].
300 Dogan R, Birdane A, Bilir A, et al. Frequency of electrocardiographic changes indicating myocardial ischemia during elective cesarean delivery with regional and general anesthesia: detection based on continuous Holter monitoring and serum markers of ischemia. J Clin Anesth. 2008;20(5):347-351. X-2, X-3. [pmid: 18761242].
301 Dolan PF, Rosen M. Inhalational analgesia in labour: facemask or mouthpiece. Lancet. Nov. 22. 1975;2(7943):1030-1. X-3d, X-5. [pmid: 53506].
302 Dolan WM, Eger EI 2nd, Margolis AJ. Forane increases bleeding in therapeutic suction abortion. Anesthesiology. Jan. 1972;36(1):96-7. X-1, X-3b, X-5. [pmid: 5006994].
303 Dolk A, Cannerfelt R, Anderson RE, et al. Inhalation anaesthesia is cost-effective for ambulatory surgery: A clinical comparison with propofol during elective knee arthroscopy. Eur J Anaesthesiol. 2002;19(2):88-92. X-2, X-3d. [pmid: 11999607].
304 Donvig M, Secher O, Ovlisen B. The influence of enibomalum on infants delivered by Caesarean section. Acta Anaesthesiol Scand Suppl. 1966;23:133-7. X-2, X-3a, X-5. [pmid: 6003628].
305 Douglas MJ, Gunka VB, Von Dadelszen P. Anesthesia for the parturient with pseudoxanthoma elasticum. Int J Obstet Anesth. 2003;12(1):45-47. X-2, X-3. [pmid: 15676320].
306 Downing JW, Coleman AJ, Mahomedy MC, et al. General anaesthesia for caesarean section. I. A review of the special problems confronting the obstetric anaesthetist. S Afr Med J. Jul. 20. 1974;48(35):1497-9. X-1, X-2, X-3a, X-5. [pmid: 4852142].
307 Downing JW, Fairbrother PE, Buley RJ, et al. Hypothesis: volatile anaesthetic agents enhance transplacental exchange between mother and fetus. A preliminary study of fetal scalp blood gas changes associated with enflurane anaesthesia. S Afr Med J. Jan. 6. 1979;55(1):17-20. X-3a, X-5. [pmid: 34236].
308 Downing JW, Mahomedy MC, Jeal DE, et al. Anaesthesia for Caesarean section with ketamine. Anaesthesia. Sep. 1976;31(7):883-92. X-2, X-3. [pmid: 9839].
309 Driessen JJ, Gielen MJM, Nijhuis GMM. Epidural anesthesia with plain bupivacaine 0.75% for elective caesarean section. Acta Anaesthesiol Belg. 1984;35(2):145-154. X-2, X-3, X-5. [pmid: 6496024].
310 Drongowski RA, Smith RK Jr, Goran AG, et al. Contribution of demographic and environmental factors to the etiology of gastroschisis: A hypothesis. Fetal Diagn Ther. 1991;6(1-2):14-27. X-2, X-3. [pmid: 1837456].
311 Drover DR, Lemmens HJ, Pierce ET, et al. Patient State Index. Anesthesiology. 2002;97(1):82-89. X-2, X-3. [pmid: 12131107].
312 Drury WL, LaVallee DA, Vacanti CJ. Effects of laparoscopic tubal ligation on arterial blood gases. Anesth Analg. May-Jun. 1971;50(3):349-51. X-2, X-3a, X-5. [pmid: 5280870].
313 Du Plessis L, Langley N, Slabbert C, et al. Enhancement of the in vitro antimalarial efficacy of atemisinins and quinolines by Pheroid vesicles. Tropical Medicine and International Health. Conference: 6th European Congress on Tropical Medicine and International Health and 1st Mediterranean Conference on Migration and Travel Health. Verona Italy. Conference Start. 2009. 14:128. X-2, X-3.
314 Dubey PK, Tulika Singh AK, et al. Anaesthesia for adrenalectomy in a patient of Von Hippel-Lindau disease with pregnancy. J Anaesthesiol Clin Pharmacol. 2005;21(3):329-332. X-2, X-3.
315 Dubois L, Girard M, Tatone-Tokuda F. Determinants of high birth weight by geographic region in Canada. Chronic Dis Can. 2007;28(1-2):63-70. X-2, X-3. [pmid: 17953799].
316 Dubus JC, Guillot C, Badier M. Electrostatic charge on spacer devices and salbutamol response in young children. Int J Pharm. 2003;261(1-2):159-164. X-2, X-3. [pmid: 12878405].
317 Duffy BL, Lee JS. Intravenous access: a comparison of two methods. Anaesth Intensive Care. May. 1983;11(2):135-7. X-3. [pmid: 6869776].
318 Duffy BL, Woodhouse PC, Schramm MD, et al. Ranitidine prophylaxis before anaesthesia in early pregnancy. Anaesth Intensive Care. 1985;13(1):29-32. X-2, X-3. [pmid: 3977064].
319 Dugas G, Fuller J, Singh S, et al. Pheochromocytoma and pregnancy: A case report and review of anesthetic management. Can J Anaesth. 2004;51(2):134-138. X-2, X-3. [pmid: 14766689].
320 Duggan AB, Katz SG. Combined spinal and epidural anaesthesia for caesarean section in a parturient with severe primary pulmonary hypertension. Anaesth Intensive Care. 2003;31(5):565-569. X-2, X-3. [pmid: 14601281].
321 Dullenkopf A, Lohmeyer U, Salgo B, et al. Non-invasive monitoring of haemoglobin concentration in paediatric surgical patients using near-infrared spectroscopy. Anaesthesia. 2004;59(5):453-458. X-2, X-3. [pmid: 15096239].
322 Duncan T, McEwan A. An evidence-based approach to the management of abnormal labour. Curr Obstet Gynaecol. 2004;14(4):277-284. X-1, X-2, X-3.
323 Duncanson E, Richards V, Luce KM, et al. Medical homicide and extreme negligence. Am J Forensic Med Pathol. 2009;30(1):18-22. X-1, X-2, X-3, X-5. [pmid: 19237847].
324 Dunn A, Davies A, Eckert G. Intraoperative death during Caesarian section in a patient with sickle-cell trait. Can J Anaesth. 1987;34(1):67-70. X-2, X-3. [pmid: 3829288].
325 Dunn GL, Houlton PJ, Morison DH, et al. A comparative assessment of alfathesin for use in outpatient anaesthesia. Can Anaesth Soc J. Mar. 1978;25(2):125-9. X-2, X-3. [pmid: 638824].
326 Dunn SR, Walker JS, Aston DL, et al. Effect of anaesthetic technique on blood loss in termination of pregnancy. Br J Anaesth. Jun. 1973;45(6):633-7. X-2, X-3b, X-5. [pmid: 4577941].
327 Dunson DB, Neelon B. Bayesian inference on order-constrained parameters in generalized linear models. Biometrics. Jun. 2003;59(2):286-95. X-2, X-3. [pmid: 12926713].
328 Dwyer R, Fee JP, Moore J. Uptake of halothane and isoflurane by mother and baby during caesarean section. Br J Anaesth. Apr. 1995;74(4):379-83. X-2, X-3a, X-3d, X-5. [pmid: 7734253].
329 Dyer RA, Els I, Farbas J, et al. Prospective, randomized trial comparing general with spinal anesthesia for cesarean delivery in preeclamptic patients with a nonreassuring fetal heart trace. Anesthesiology. Sep. 2003;99(3):561-9. discussion 5A-6A. X-2, X-3. [pmid: 12960539].
330 Eason JR, Swaine CN, Jones PIE. Unstable cervical fracture. Anaesthetic management for an urgent Caesarean section. Anaesthesia. 1987;42(7):745-749. X-1, X-2, X-3a, X-5. [pmid: 3631474].
331 Edelist G. A comparison of propofol and thiopentone as induction agents in outpatient surgery. Can J Anaesth. Mar. 1987;34(2):110-6. X-2, X-3. [pmid: 3493852].
332 Edwards R. Anaesthesia for caesarean section in haemoglobin SC disease complicated by eclampsia: a case report. Br J Anaesth. Jul. 1973;45(7):757-8. X-1, X-2, X-3a, X-3d, X-5. [pmid: 4730170].
333 Edwards RD, Hansel NK, Pruessner HT, et al. Intrathecal morphine sulfate for labor pain. Tex Med. 1985;81(11):46-48. X-3. [pmid: 3906998].
334 Edwards RD, Hansel NK, Pruessner HT, et al. Intrathecal morphine as analgesia for labor pain. J Am Board Fam Pract. Oct-Dec. 1988;1(4):245-50. X-3d, X-5. [pmid: 3223345].
335 Eger EI 2nd. Fetal injury and abortion associated with occupational exposure to inhaled anesthetics. AANA J. Aug. 1991;59(4):309-12. X-1, X-5. [pmid: 1891967].
336 Eger EI 2nd, Gaskey NJ. A review of the present status of nitrous oxide. AANA J. Feb. 1986;54(1):29-36. X-1, X-2, X-5. [pmid: 3635333].
337 Eger EI, White PF, Bogetz MS. Clinical and economic factors important to anaesthetic choice for day- case surgery. PharmacoEconomics. 2000;17(3):245-262. X-1, X-2. [pmid: 10947300].
338 Eger IEI. Current and future perspectives on inhaled anesthetics. Pharmacotherapy. 1998;18(5):895-910. X-1. [pmid: 9758304].
339 Eid L, Ginosar Y, Elchalal U, et al. Caesarean section following the Fontan procedure: Two different deliveries and different anaesthetic choices in the same patient. Anaesthesia. 1137. 60(11):1137-1140. X-2, X-3. [pmid: 16229700].
340 Eide BI, Nilsen AB, Rasmussen S. Births in two different delivery units in the same clinic--a prospective study of healthy primiparous women. BMC Pregnancy Childbirth. 2009;9:25. X-5. [pmid: 19545412].
341 Einarsson S, Stenqvist O, Bengtsson A, et al. Nitrous oxide elimination and diffusion hypoxia during normo-and hypoventilation. Br J Anaesth. Aug. 1993;71(2):189-93. X-2, X-3d. [pmid: 8123390].
342 Elden H, Ostgaard HC, Fagevik-Olsen M, et al. Treatments of pelvic girdle pain in pregnant women: Adverse effects of standard treatment, acupuncture and stabilising exercises on the pregnancy, mother, delivery and the fetus/neonate. BMC Complement Altern Med. 2008;8(34). X-3.
343 Elhakim M, el-Sebiae S, Kaschef N, et al. Intravenous fluid and postoperative nausea and vomiting after day-case termination of pregnancy. Acta Anaesthesiol Scand. Feb. 1998;42(2):216-9. X-3. [pmid: 9509206].
344 Elhakim M, Kamel M, Moursi GE. Effects of thiopentone and propofol on uterine activity during day case abortion surgery. Acta Anaesthesiol Ital. 1992;43(SUPPL. 2):155-160. X-2, X-3, X-5.
345 Elias S, Simpson JL, Martin AO. Chorionic villus sampling for first-trimester prenatal diagnosis: Northwestern University Program. Am J Obstet Gynecol. 1985;152(2):204-213. X-2, X-3d. [pmid: 3890545].
346 Ellingson A, Haram K, Sagen N. Ketamine and diazepam as anaesthesia for forceps delivery. A comparative study. Acta Anaesthesiol Scand. 1977;21(1):37-40. X-3, X-5. [pmid: 320809].
347 Elmfors B, Stormby N. A study of cryosurgery for dysplasia and carcinoma in situ of the uterine cervix. Br J Obstet Gynaecol. Dec. 1979;86(12):917-21. X-2, X-3d. [pmid: 526449].
348 El-Tahan MR, Warda OM, Diab DG, et al. A randomized study of the effects of perioperative i.v. lidocaine on hemodynamic and hormonal responses for cesarean section. J Anesth. 2009;23(2):215-21. X-2, X-3a, X-3d, X-5. [pmid: 19444560].
349 El-Tahan MR, Warda OM, Yasseen AM, et al. A randomized study of the effects of preoperative ketorolac on general anaesthesia for caesarean section. Int J Obstet Anesth. Jul. 2007;16(3):214-20. X-2, X-3a, X-3d. [pmid: 17459695].
350 El-Wahab N, Robinson N. Analgesia and anaesthesia in labour. Obstet Gynaecol Reprod Med. 2011;21(5):137-141. X-1, X-2, X-5.
351 Emenius G, Svartengren M, Korsgaard J, et al. Indoor exposures and recurrent wheezing in infants: a study in the BAMSE cohort. Acta Paediatr. Jul. 2004;93(7):899-905. X-2, X-3d, X-5. [pmid: 15303804].
352 Enlund M, Kobosko P, Rhodin A. A cost-benefit evaluation of using propofol and alfentanil for a short gynecological procedure. Acta Anaesthesiol Scand. Apr. 1996;40(4):416-20. X-2, X-3. [pmid: 8738684].
353 Enright AB, Parker JB. Double blind comparison of alfentanil N2O and fentanyl N2O for outpatient surgical procedures. Can J Anaesth. Sep. 1988;35(5):462-7. X-2, X-3. [pmid: 3139310].
354 Enting RH, Oldenmenger WH, van der Rijt CCD, et al. Nitrous oxide is not beneficial for breakthrough cancer pain. Palliat Med. 2002;16(3):257-259. X-1, X-2, X-3a, X-5. [pmid: 12047005].
355 Eom M, Lee JH, Chung JH, et al. An autopsy case of postpartum acute myocardial infarction associated with postpartum ergot alkaloids administration in old-aged pregnant women. Yonsei Med J. 2005;46(6):866-869. X-2, X-3. [pmid: 16385667].
356 Erden V, Erkalp K, Yangin Z, et al. The effect of labor on sevoflurane requirements during cesarean delivery. Int J Obstet Anesth. 2011;20(1):17-21. X-3d, X-5. [pmid: 21112762].
357 Ericson A, Kallen B. Survey of infants born in 1973 or 1975 to Swedish women working in operating rooms during their pregnancies. Anesth Analg. Jul-Aug. 1979;58(4):302-5. X-3a, X-5. [pmid: 572175].
358 Ericson HA, Kallen AJ. Hospitalization for miscarriage and delivery outcome among Swedish nurses working in operating rooms 1973-1978. Anesth Analg. Oct. 1985;64(10):981-8. X-3a, X-5. [pmid: 4037396].
359 Eriksson H, Haasio J, Korttila K. Comparison of eltanolone and thiopental in anaesthesia for termination of pregnancy. Acta Anaesthesiol Scand. May. 1995;39(4):479-84. X-2, X-3. [pmid: 7676782].
360 Euliano TY, Yeager A. Cesarean section combined with splenectomy in a parturient with immune thrombocytopenic purpura. J Clin Anesth. 2001;13(4):313-318. X-1, X-2, X-3d. [pmid: 11435059].
361 Evans JM. Anesthesia for in vitro fertilization oocyte retrieval. Infertility. 1983;6(1-4):97-106. X-1, X-2, X-3d, X-5.
362 Evans NR, Skowno JJ, Bennett PJ, et al. A prospective observational study of the use of the Proseal<sup>TM</sup> laryngeal mask airway for postpartum tubal ligation. Int J Obstet Anesth. 2005;14(2):90-95. X-2, X-3. [pmid: 15795142].
363 Everitt I, Younge P, Barnett P. Paediatric sedation in emergency departments: What is our practice?. Emergency Medicine. 2002;14(1):62-66. X-2, X-3. [pmid: 11993837].
364 Evron S, Samueloff A, Sadovsky E. The effect of phenoxybenzamine on postoperative urinary complications during extradural morphine analgesia. Eur J Anaesthesiol. 1984;1(1):45-54. X-2, X-3a, X-5. [pmid: 6536506].
365 Eyres R. Update on TIVA. Paediatric Anaesthesia. 2004;14(5):374-379. X-1, X-2, X-3, X-5. [pmid: 15086846].
366 Fadl ET, Utting JE. A study of maternal acid-base state during labour. Br J Anaesth. Apr. 1969;41(4):327-37. X-5, No accurate data. [pmid: 5780738].
367 Famewo CE. Awareness and dreams during general anaesthesia for Caesarian section a study of incidence. Can Anaesth Soc J. Nov. 1976;23(6):636-9. X-2, X-3. [pmid: 990980].
368 Fanning J. Safety and the gas supply: Focus on anesthesia systems. Biomed Instrum Technol. 2005;39(2):141-142. X-1, X-2, X-3, X-5. [pmid: 15810787].
369 Fassoulaki A, Gatzou V, Petropoulos G, et al. Spread of subarachnoid block, intraoperative local anaesthetic requirements and postoperative analgesic requirements in Caesarean section and total abdominal hysterectomy. Br J Anaesth. 2004;93(5):678-682. X-2, X-3. [pmid: 15347609].
370 Fava M, Loyola S, Papapavlou P, et al. Cryoplasty for femoropopliteal arterial disease: Late angiographic results of initial human experience. J Vasc Interv Radiol. 1239. 15(11):1239-1243. X-2, X-3. [pmid: 15525742].
371 Feigal RJ. Nitrous oxide: potential hazards to health professionals. Northwest Dent. Sep-Oct. 1977;56(5):232-5. X-1, X-2, X-5. [pmid: 273884].
372 Feldman JM. Cardiac arrest after succinylcholine administration in a pregnant patient recovered from Guillain-Barre syndrome. Anesthesiology. 1990;72(5):942-944. X-2, X-3. [pmid: 2339807].
373 Ferguson A, Whittaker M, Britten JJ, et al. Suxamethonium apnoea associated with pregnancy and liver dysfunction in a treated cretin. Anaesthesia. 1983;38(6):567-571. X-1, X-2, X-3a, X-5. [pmid: 6869716].
374 Filos KS, Goudas LC, Patroni O, et al. Intrathecal clonidine as a sole analgesic for pain relief after cesarean section. Anesthesiology. 1992;77(2):267-274. X-2, X-3. [pmid: 1642346].
375 Filos KS, Goudas LC, Patroni O, et al. Hemodynamic and analgesic profile after intrathecal clonidine in humans. A dose-response study. Anesthesiology. Sep. 1994;81(3):591-601. discussion 27A-28A. X-2, X-3. [pmid: 8092504].
376 Findlay JY, Jankowski CJ, Vasdev GM, et al. Fast track anesthesia for liver transplantation reduces postoperative ventilation time but not intensive care unit stay. Liver Transplantation. 2002;8(8):670-675. X-2, X-3. [pmid: 12149758].
377 Findley I, Chamberlain G. ABC of labour care: Relief of pain. BMJ. 1999;318(7188):927-930. X-1, X-2, X-5. [pmid: 10102864].
378 Fineberg HV, Gabel RA, Sosman MB. Acquisition and application of new medical knowledge by anesthesiologists: three recent examples. Anesthesiology. Jun. 1978;48(6):430-6. X-1, X-2, X-3a, X-3d, X-5. [pmid: 666026].
379 Finkelstein SE, Carey T, Fricke I, et al. Changes in dendritic cell phenotype after a new high-dose weekly schedule of interleukin-2 therapy for kidney cancer and melanoma. J Immunother. 2010;33(8):817-827. X-2, X-3. [pmid: 20842055].
380 Finster M, Mark LC, Morishima HO, et al. Plasma thiopental concentrations in the newborn following delivery under thiopental--nitrous oxide anesthesia. Am J Obstet Gynecol. Jul. 1. 1966;95(5):621-9. X-5. [pmid: 5949476].
381 Finster M, Morishima HO, Mark LC, et al. Thiopental and the fetal liver. Anesthesiology. Nov. 1972;37(5):571-2. X-1, X-2, X-3, X-5. [pmid: 4673019].
382 Finucane BT, Symbas PN, Braswell R. Ligation of patent ductus arteriosus in premature neonates: anesthetic management. South Med J. Jan. 1981;74(1):21-3. X-2, X-3. [pmid: 7455735].
383 Fischerstrom A, Ohqvist G, Settergren G. Comparison of fentanyl and halothane as supplement to nitrous-oxide-oxygen anaesthesia for coronary artery surgery. Acta Anaesthesiol Scand. 1985;29(1):16-21. X-2, X-3. [pmid: 3872000].
384 Fisher JT, Mortola JP, Smith B, et al. Neonatal pattern of breathing following cesarean section: epidural versus general anesthesia. Anesthesiology. Nov. 1983;59(5):385-9. X-2, X-3. [pmid: 6638544].
385 Fletcher G. On ethics in human experimentation. Anesthesiology. May. 1970;32(5):471-2. X-1, X-2, X-3d, X-5. [pmid: 4915723].
386 Fletcher GC, Beck SA, Goudie TA. Labour analgesia - Can prospective mothers predict their needs?. Int J Obstet Anesth. 1994;3(3):176-177. X-3, X-5.
387 Floyd RL, Belodoff B, Sidhu J, et al. A survey of obstetrician-gynecologists on their patients' use of tobacco and other drugs during pregnancy. Prenat Neonatal Med. 2001;6(4):201-207. X-2, X-3.
388 Fox GS, Houle GL. Acid-base studies in elective caesarean sections during epidural and general anaesthesia. Can Anaesth Soc J. Jan. 1971;18(1):60-71. X-3. [pmid: 5545736].
389 Frank M, Evans M, Flynn P, et al. Comparison of the prophylactic use of magnesium trisilicate mixtures B.P.C., sodium citrate mixture or cimetidine in obstetrics. Br J Anaesth. 1984;56(4):355-362. X-2, X-3. [pmid: 6324832].
390 Fretzin S, Beeson WH, Hanke CW. Ignition potential of the 585-nm pulsed-dye laser: Review of the literature and safety recommendations. Dermatol Surg. 1996;22(8):699-702. X-2, X-3. [pmid: 8780762].
391 Fryer ME, Boulton TB. Apparatus for emergency anaesthesia outside main hospitals. Anaesthesia. Feb. 1977;32(2):189-96. X-1, X-2, X-3. [pmid: 848719].
392 Fujii Y, Tanaka H, Somekawa Y. A randomized, double-blind, placebo-controlled trial of ramosetron for preventing nausea and vomiting during termination of pregnancy. Int J Obstet Anesth. 2004;13(1):15-18. X-2, X-3. [pmid: 15321434].
393 Furst SR, Reisner LS. Risk of high spinal anesthesia following failed epidural block for cesarean delivery. J Clin Anesth. 1995;7(1):71-74. X-2, X-3. [pmid: 7772363].
394 Furuya A, Matsukawa T, Ozaki M, et al. Propofol anesthesia for cesarean section successfully managed in a patient with moyamoya disease. J Clin Anesth. 1998;10(3):242-245. X-1, X-2, X-3a. [pmid: 9603597].
395 Fyneface-Ogan S, Uzoigwe SA. Caesarean section outcome in eclamptic patients: A comparison of infiltration and general anaesthesia. West Afr J Med. 2008;27(4):250-254. X-2, X-3. [pmid: 19469405].
396 Gaiser RR, Cheek TG, Kurth CD. Anesthetic management of cesarean delivery complicated by ex utero intrapartum treatment of the fetus. Anesth Analg. 1150. 84(5):1150-1153. X-3. [pmid: 9141951].
397 Galbert MW, Gardner AE. Use of halothane in a balanced technic for cesarean section. Anesth Analg. Sep-Oct. 1972;51(5):701-4. X-3. [pmid: 4672162].
398 Gale T, Leslie K, Kluger M. Propofol anaesthesia via target controlled infusion or manually controlled infusion: Effects on the bispectral index as a measure of anaesthetic depth. Anaesth Intensive Care. 2001;29(6):579-584. X-2, X-3. [pmid: 11771598].
399 Galletly DC, Yee P, Maling TJB. Anaesthetic management of combined caesarean section and phaeochromocytoma removal. Anaesth Intensive Care. 1983;11(3):249-253. X-2, X-3. [pmid: 6614435].
400 Gambling DR, Sharma SK, White PF, et al. Use of sevoflurane during elective cesarean birth: a comparison with isoflurane and spinal anesthesia. Anesth Analg. Jul. 1995;81(1):90-5. X-2, X-3. [pmid: 7598289].
401 Gan TJ, El-Molem H, Ray J, et al. Patient-controlled antiemesis: A randomized, double-blind comparison of two doses of propofol versus placebo. Anesthesiology. 1564. 90(6):1564-1570. X-2, X-3. [pmid: 10360853].
402 Gant NF, Wallace DH. Pregnancy-induced hypertension and the anaesthetic management of the patient. Clin Anaesthesiol. 1986;4(2):321-350. X-1, X-2, X-3, X-5.
403 Gardosi J. Fetal monitoring during labour. Curr Anaesth Crit Care. 1991;2(3):187-193. X-1, X-2, X-3, X-5.
404 Garrioch MA, McClure JH, Wildsmith JAW. Haemodynamic effects of diaspirin crosslinked haemoglobin (DCLHb) given before abdominal aortic aneurysm surgery. Br J Anaesth. 1999;83(5):702-707. X-2, X-3. [pmid: 10690130].
405 Gaspar LS. Hamman's syndrome: Pneumomediastinum and subcutaneous emphysema occurring in labour. Int J Obstet Anesth. 1997;6(1):55-58. X-1, X-2, X-3, X-5. [pmid: 15321313].
406 Gasparoni A, Chirico G, De Amici D, et al. Neutrophil chemotaxis in infants delivered by caesarean section. Eur J Pediatr. May. 1991;150(7):481-2. X-2, X-3d, X-5. [pmid: 1915500].
407 Gauert WB, Hustead RF. Differences in metered and measured oxygen concentrations during nitrous oxide analgesia. Anesth Analg. Jul-Aug. 1968;47(4):441-5. X-2, X-3, X-5. [pmid: 5690535].
408 Geary M, Fanagan M, Boylan P. Maternal satisfaction with management in labour and preference for mode of delivery. J Perinat Med. 1997;25(5):433-9. X-3a, X-5. [pmid: 9438948].
409 Gejervall AL, Lundin K, Stener-Victorin E, et al. Effect of alfentanil dosage during oocyte retrieval on fertilization and embryo quality. Eur J Obstet Gynecol Reprod Biol. 2010;150(1):66-71. X-2, X-3. [pmid: 20226584].
410 Gepts E, Heytens L, Camu F. Pharmacokinetics and placental transfer of intravenous and epidural alfentanil in parturient women. Anesth Analg. 1155. 65(11):1155-1160. X-2, X-3. [pmid: 2876662].
411 Gerges FJ, Dalal AR, Robelen GT, et al. Anesthesia for cesarean section in a patient with placenta previa and methylenetetrahydrofolate reductase deficiency. J Clin Anesth. 2006;18(6):455-459. X-2, X-3. [pmid: 16980165].
412 Gerhardt RT, King KM, Wiegert RS. Inhaled nitrous oxide versus placebo as an analgesic and anxiolytic adjunct to peripheral intravenous cannulation. Am J Emerg Med. Oct. 2001;19(6):492-4. X-2, X-3. [pmid: 11593469].
413 Ghaly RG, Flynn RJ, Moore J. Isoflurane as an alternative to halothane for caesarean section. Anaesthesia. Jan. 1988;43(1):5-7. X-2, X-3. [pmid: 3344947].
414 Ghazi M, Seibel RE, Courey NG. Pelvic pneumography. Diagnostic aid in gynecology. Obstet Gynecol. Dec. 1970;36(6):827-34. X-1, X-2, X-3, X-5. [pmid: 5487733].
415 Ghods AA, Soleimani M, Narimani M. Effect of postoperative supplemental oxygen on nausea and vomiting after cesarean birth. J Perianesth Nurs. Jun. 2005;20(3):200-5. X-2, X-3. [pmid: 15933967].
416 Ghosh S, Marton S. Anesthetic management for cesarean delivery in a patient with severe aortic stenosis and severe obesity. Obes Surg. 2011;21(2):264-266. X-1, X-2, X-3. [pmid: 19727983].
417 Gibbs CP, Munson ES, Tham MK. Anesthetic solubility coefficients for maternal and fetal blood. Anesthesiology. Jul. 1975;43(1):100-3. X-5. [pmid: 238431].
418 Gillett GB, Watson JD, Langford RM. Ranitidine and single-dose antacid therapy as prophylaxis against acid aspiration syndrome in obstetric practice. Anaesthesia. 1984;39(7):638-644. X-2, X-3. [pmid: 6087692].
419 Gilmer T. An analysis of the effects of organization and financing on the utilization and costs of public mental health services in San Diego County. J Ment Health Policy Econ. 2007;10(3):123-132. X-2, X-3. [pmid: 17890829].
420 Gilstrap LC 3rd, Hauth JC, Hankins GD, et al. Effect of type of anesthesia on blood loss at cesarean section. Obstet Gynecol. Mar. 1987;69(3 Pt 1):328-32. X-2, X-3. [pmid: 3822280].
421 Gin T, Derrick JL, Chan MT, et al. Postpartum patients have slightly prolonged neuromuscular block after mivacurium. Anesth Analg. Jan. 1998;86(1):82-5. X-2, X-3. [pmid: 9428856].
422 Gin T, Kan AF, Lam KK, et al. Analgesia after caesarean section with intramuscular ketorolac or pethidine. Anaesth Intensive Care. Aug. 1993;21(4):420-3. X-2, X-3. [pmid: 8214547].
423 Gin T, Ngan-Kee WD, Siu YK, et al. Alfentanil given immediately before the induction of anesthesia for elective cesarean delivery. Anesth Analg. May. 2000;90(5):1167-72. X-2, X-3. [pmid: 10781473].
424 Gin T, O'Meara ME, Kan AF, et al. Plasma catecholamines and neonatal condition after induction of anaesthesia with propofol or thiopentone at caesarean section. Br J Anaesth. Mar. 1993;70(3):311-6. X-2, X-3. [pmid: 8471376].
425 Gin T, Yau G, Chan K, et al. Disposition of propofol infusions for caesarean section. Can J Anaesth. Jan. 1991;38(1):31-6. X-2, X-3. [pmid: 1989737].
426 Giorgino FL, Mega M, Agnello A, et al. Beta-endorphin levels and general anaesthesia for cesarean section. Preliminary report. Clin Exp Obstet Gynecol. 1984;11(4):165-167. X-2, X-3. [pmid: 6149826].
427 Glen JB, Jewell WH. Halothane vapour warnings. Vet Rec. May. 19. 1973;92(20):544. X-1, X-2, X-3, X-5. [pmid: 4737283].
428 Glen JB, Servin F. Evaluation of the predictive performance of four pharmacokinetic models for propofol. Br J Anaesth. 2009;102(5):626-632. X-2, X-3. [pmid: 19297371].
429 Goetz LM. ACOG practice bulletin: No 36, July 2002, obstetrics analgesia and anesthesia. Int J Gynaecol Obstet. 2002;78(3):321-335. X-2, X-3. [pmid: 12452132].
430 Goff LC, Pratt RR, Madrigal JL. Music listening and S-IgA levels in patients undergoing a dental procedure. International Journal of Arts Medicine. 1997;5(2):22-6. X-2, X-3d, X-5.
431 Goldstein BD, Paz J, Giuffrida JG, et al. Atmospheric derivatives of anaesthetic gases as a possible hazard to operating-room personnel. Lancet. Jul. 31. 1976;2(7979):235-7. X-2, X-3, X-5. [pmid: 59246].
432 Gonen O, Shulman A, Ghetler Y, et al. The impact of different types of anesthesia on in vitro fertilization-embryo transfer treatment outcome. J Assist Reprod Genet. Nov. 1995;12(10):678-82. X-2, X-3. [pmid: 8624422].
433 Gong TK, Kim SS. Combined epidural anesthesia and ultrasound guided peripheral nerve block for wound revision in a patient with peripartum cardiomyopathy -A case report. Korean J Anesthesiol. 2010;59(5):353-358. X-1, X-2, X-3. [pmid: 21179300].
434 Gonzalez RM, Bjerke RJ, Drobycki T, et al. Prevention of endotracheal tube-induced coughing during emergence from general anesthesia. Anesth Analg. 1994;79(4):792-795. X-3. [pmid: 7943794].
435 Goodyear-Smith F, Knowles A, Masters J. First trimester medical termination of pregnancy: An alternative for New Zealand women. Aust N Z J Obstet Gynaecol. 2006;46(3):193-198. X-2, X-3. [pmid: 16704471].
436 Gorelick M, Nagler J, Losek JD, et al. Pediatric Sedation Pearls. Clin Pediatr Emerg Med. 2007;8(4):268-278. X-1, X-2, X-3.
437 Goto T, Saito H, Nakata Y, et al. Emergence times from xenon anaesthesia are independent of the duration of anaesthesia. Br J Anaesth. Nov. 1997;79(5):595-9. X-2, X-3. [pmid: 9422897].
438 Goto T, Saito H, Shinkai M, et al. Xenon provides faster emergence from anesthesia than does nitrous oxide-sevoflurane or nitrous oxide-isoflurane. Anesthesiology. Jun. 1997;86(6):1273-8. X-2, X-3. [pmid: 9197295].
439 Gotsch F, Romero R, Kusanovic JP, et al. The anti-inflammatory limb of the immune response in preterm labor, intra-amniotic infection/inflammation, and spontaneous parturition at term: A role for interleukin-10. J Matern Fetal Neonatal Med. 2008;21(8):529-547. X-2, X-3. [pmid: 18609361].
440 Gozdemir M, Sert H, Yilmaz N, et al. Remifentanil-propofol in vertebral disk operations: hemodynamics and recovery versus desflurane-n(2)o inhalation anesthesia. Adv Ther. May-Jun. 2007;24(3):622-31. X-2, X-3. [pmid: 17660173].
441 Grant D, Haas C. Nitrous nightmares? Hygienists compare notes on N2O, pregnancy. Rdh. 2009;29(12):40-4. X-1, X-2, X-3d, X-5.
442 Grant IS. Anaesthesia for termination of pregnancy. Br J Anaesth. Aug. 1980;52(8):711-3. X-1, X-2, X-3b, X-5. [pmid: 7426250].
443 Graulau MF, Phelps M Jr. Bilateral pneumothorax and cardiovascular collapse on induction of anesthesia. Anesth Analg. Sep-Oct. 1972;51(5):671-5. X-3. [pmid: 4403567].
444 Gray RH. Nitrous oxide and fertility. N Engl J Med. Jan. 28. 1993;328(4):284. X-3d, X-5. [pmid: 8466571].
445 Gray WM. Occupational exposure to nitrous oxide in four hospitals. Anaesthesia. Jun. 1989;44(6):511-4. X-5. [pmid: 2757159].
446 Gregoretti S, Gelman S, Dimick A, et al. Total body oxygen supply-demand balance in burned patients under enflurane anesthesia. J Trauma. 1987;27(2):158-160. X-2, X-3. [pmid: 3820351].
447 Gregory MA, Gin T, Yau G, et al. Propofol infusion anaesthesia for caesarean section. Can J Anaesth. Jul. 1990;37(5):514-20. X-2, X-3. [pmid: 2197002].
448 Gregory TL, Hughes S, Coleman MA, et al. Acute fatty liver of pregnancy; three cases and discussion of analgesia and anaesthesia. Int J Obstet Anesth. 2007;16(2):175-179. X-2, X-3. [pmid: 17275281].
449 Griffin RP, Reynolds F. Maternal hypoxaemia during labour and delivery: The influence of analgesia and effect on neonatal outcome. Int J Obstet Anesth. 1994;3(3):171-172. X-1.
450 Griffin RP, Reynolds F. Maternal hypoxaemia during labour and delivery: the influence of analgesia and effect on neonatal outcome. Anaesthesia. Feb. 1995;50(2):151-6. X-2. [pmid: 7710029].
451 Gruss M, Bushell TJ, Bright DP, et al. Two-Pore-Domain K<sup>+</sup> Channels Are a Novel Target for the Anesthetic Gases Xenon, Nitrous Oxide, and Cyclopropane. Mol Pharmacol. 2004;65(2):443-452. X-2, X-3. [pmid: 14742687].
452 Guirguis SS, Pelmear PL, Roy ML, et al. Health effects associated with exposure to anaesthetic gases in Ontario hospital personnel. Br J Ind Med. Jul. 1990;47(7):490-7. X-3a, X-5. [pmid: 2383519].
453 Gunaydin B, Candan N, Onan A, et al. Anesthesia for cesarean delivery in the term pregnant following acute onset severe intracranial superior sagittal sinus thrombosis. Acta Anaesthesiol Belg. 2009;60(3):189-190. X-1, X-2, X-3. [pmid: 19961118].
454 Guo X, Jiang Y, Lu Y. Applying of N2O inhalation for analgesia and nursing care of patients undergoing artificial abortion. [Chinese]. Chin Nurs Res. 2004;18(3B):509-10. X-2, X-3b, X-4.
455 Gupta A, Kullander M, Ekberg K, et al. Anaesthesia for day-care arthroscopy. A comparison between desflurane and isoflurane. Anaesthesia. Jan. 1996;51(1):56-62. X-2, X-3a. [pmid: 8669568].
456 Gupta B, Prakash S, Gujral K. Anaesthetic management of the parturient with protein S deficiency and lumboperitoneal shunt. Anaesth Intensive Care. 2003;31(5):573-575. X-1, X-2, X-3. [pmid: 14601283].
457 Habib AS, Helsley SE, Millar S, et al. Anesthesia for cesarean section in a patient with spinal muscular atrophy. J Clin Anesth. 2004;16(3):217-219. X-1, X-2, X-3. [pmid: 15217664].
458 Hagnevik K, Lagercrantz H, Sjoqvist BA. Establishment of functional residual capacity in infants delivered vaginally and by elective cesarean section. Early Human Development. 1991;27(1-2):103-110. X-2, X-3d. [pmid: 1802657].
459 Hahn CEW, Palayiwa E, Sugg BR, et al. A microprocessor-controlled anaesthetic vaporizer. Br J Anaesth. 1161. 58(10):1161-1166. X-1, X-2, X-3d. [pmid: 3768229].
460 Hall JE, Ng WS, Smith S. Blood loss during first trimester termination of pregnancy: Comparison of two anaesthetic techniques. Br J Anaesth. 1997;78(2):172-174. X-2, X-3b. [pmid: 9068336].
461 Halpern S. Low concentration epidural infusion increases the risk of instrumental vaginal delivery, but not cesarean delivery - Meta-analysis. Evid Based Obstet Gynecol. 2005;7(2):66-67. X-1, X-2, X-3, X-5.
462 Hamilton A, Sirrs S, Schmidt N, et al. Anaesthesia for phaeochromocytoma in pregnancy. Can J Anaesth. 1997;44(6):654-657. X-1, X-2, X-3d. [pmid: 9187786].
463 Hammadeh ME, Wilhelm W, Huppert A, et al. Effects of general anaesthesia vs. sedation on fertilization, cleavage and pregnancy rates in an IVF program. Arch Gynecol Obstet. Nov. 1999;263(1-2):56-9. X-2, X-3a, X-3d. [pmid: 10728631].
464 Han TH, Brimacombe J, Lee EJ, et al. The laryngeal mask airway is effective (and probably safe) in selected healthy parturients for elective Cesarean section: A prospective study of 1067 cases. Can J Anaesth. 1117. 48(11):1117-1121. X-2, X-3d. [pmid: 11744589].
465 Hanisch EC, Sankawa H, Gauert WB, et al. Clinical and mechanical evaluation of an A.E. gas machine for obstetric analgesia and anesthesia. Anesth Analg. Mar-Apr. 1971;50(2):190-4. X-2, X-3, X-5. [pmid: 5279729].
466 Hara K, Saito Y, Morimoto N, et al. Anaesthetic management of Caesarean section in a patient with myelodysplastic syndrome. Can J Anaesth. 1998;45(2):157-163. X-1, X-2, X-3d. [pmid: 9512852].
467 Haram K, Bakke OM. Diazepam as an induction agent for caesarean section: a clinical and pharmacokinetic study of fetal drug exposure. Br J Obstet Gynaecol. Jun. 1980;87(6):506-12. X-2, X-3d. [pmid: 7397084].
468 Haram K, Bakke OM, Sandvei R, et al. Foetal drug exposure following intravenous injection of diazepam immediately before breech delivery. Ann Chir Gynaecol. 1979;68(3):104-8. X-2, X-3d. [pmid: 533212].
469 Haram K, Lund T, Sagen N, et al. Comparison of thiopentone and diazepam as induction agents of anaesthesia for Caesarean section. Acta Anaesthesiol Scand. Dec. 1981;25(6):470-6. X-2, X-3d. [pmid: 7347074].
470 Harrad J, Howell P. General anaesthesia for Caesarean section. Curr Anaesth Crit Care. 2000;11(2):66-72. X-1, X-2, X-3d.
471 Harrison JM, Girling KJ, Mahajan RP. Effects of propofol and nitrous oxide on middle cerebral artery flow velocity and cerebral autoregulation. Anaesthesia. 2002;57(1):27-32. X-2, X-3a, X-3d. [pmid: 11843738].
472 Hartsilver EL, Vanner RG, Bewley J, et al. Gastric pressure during emergency Caesarean section under general anaesthesia. Br J Anaesth. 1999;82(5):752-754. X-2, X-3. [pmid: 10536555].
473 Hasan SS, Khan FH, Ahmed M. Comparison of Ketorolac with Morphine for Intra-operative Analgesia in Patients undergoing total Abdominal Hysterectomy. Journal of the Pakistan Medical Association. 2003;53(10):467-471. X-2, X-3a, X-3d. [pmid: 14696887].
474 Hawkins JL. Epidural analgesia for labor and delivery. N Engl J Med. 2010;362(16):1503-1510. X-1, X-2. [pmid: 20410515].
475 Hay DM. Nitrous oxide transfer across the placenta and condition of the newborn at delivery. Br J Obstet Gynaecol. Apr. 1978;85(4):299-302. X-2, X-3a, X-3d. [pmid: 638097].
476 Hayes NE, Aslani A, McCaul CL. Anaesthetic management of a patient with Liddle's syndrome for emergency caesarean hysterectomy. Int J Obstet Anesth. 2011;20(2):178-180. X-1, X-2, X-3. [pmid: 21183332].
477 Hazama A, Kinouchi K, Kitamura S, et al. Brachial plexus birth injuries: anaesthesia for surgical nerve reconstruction and preoperative myelography and computed tomographic myelography. Paediatr Anaesth. 1999;9(5):403-7. X-2, X-3a, X-3d. [pmid: 10447902].
478 Hearn M. Black rubber or clear plastic delivery tubing for nitrous oxide: Patient preference. Int J Obstet Anesth. 1993;2(1):39-40. X-3d, X-5. [pmid: 15636847].
479 Heath BJ, Done M, Balog O, et al. The effect of scavenging on nitrous oxide pollution in the delivery suite. Aust N Z J Obstet Gynaecol. Aug. 1994;34(4):484-6. X-5. [pmid: 7848248].
480 Heather DJ, Martin-Sheridan D. Discharge time in patients who receive fentanyl or alfentanil for general anesthesia. Nurse Anesth. Dec. 1993;4(4):160-5. X-2, X-3b. [pmid: 8136396].
481 Heese Hde V, Davey DA, Rorke M, et al. Effect of maternal anaesthesia on oxygenation and acid-base status of the newborn infant. S Afr Med J. Oct. 27. 1973;47(42):1991-9. X-2, X-3, X-5. [pmid: 4755010].
482 Hegarty KL, Taft AJ. Overcoming the barriers to disclosure and inquiry of partner abuse for women attending general practice. Aust N Z J Public Health. 2001;25(5):433-437. X-2, X-3. [pmid: 11688623].
483 Heidam LZ. Spontaneous abortions among dental assistants, factory workers, painters, and gardening workers: a follow up study. J Epidemiol Community Health. Jun. 1984;38(2):149-55. X-3d, X-5. [pmid: 6747515].
484 Hein A, Jakobsson J, Ryberg G. Paracetamol 1 g given rectally at the end of minor gynaecological surgery is not efficacious in reducing postoperative pain. Acta Anaesthesiol Scand. Mar. 1999;43(3):248-51. X-2, X-3b. [pmid: 10081528].
485 Hein A, Norlander C, Blom L, et al. Is pain prophylaxis in minor gynaecological surgery of clinical value? A double-blind placebo controlled study of paracetamol 1 g versus lornoxicam 8 mg given orally. Ambulatory Surgery. 2001;9(2):91-4. X-2, X-3b. [pmid: 11454488].
486 Heinrichs WL. Reproductive hazards of the workplace and the home. Clin Obstet Gynecol. 1983;26(2):429-436. X-1, X-2, X-3, X-5. [pmid: 6851291].
487 Heller ML. Nitrous oxide--relaxant anesthesia in cesarean section. Trans N Engl Obstet Gynecol Soc. 1965;19:43-7. X-1, X-2, X-3, X-5. [pmid: 5872592].
488 Hemminki K, Kyyronen P, Lindbohm ML. Spontaneous abortions and malformations in the offspring of nurses exposed to anaesthetic gases, cytostatic drugs, and other potential hazards in hospitals, based on registered information of outcome. J Epidemiol Community Health. 1985;39(2):141-147. X-2, X-3a, X-5. [pmid: 3925060].
489 Henderson JJ, Dickinson JE, Evans SF, et al. Impact of intrapartum epidural analgesia on breast-feeding duration. Aust N Z J Obstet Gynaecol. 2003;43(5):372-377. X-5. [pmid: 14717315].
490 Henderson KA, Matthews IP. Staff exposure to anaesthetic gases in theatre and non theatre areas. Eur J Anaesthesiol. 2000;17(3):149-151. X-3d, X-5. [pmid: 10758462].
491 Hendrickx JFA, Cardinael S, Carette R, et al. The ideal oxygen/nitrous oxide fresh gas flow sequence with the Anesthesia Delivery Unit machine. J Clin Anesth. 2007;19(4):274-279. X-2, X-3a. [pmid: 17572322].
492 Hendrickx JFA, Coddens J, Callebaut F, et al. Effect of N<sub>2</sub>O on sevoflurane vaporizer settings during minimal-and low-flow anesthesia. Anesthesiology. 2002;97(2):400-404. X-2, X-3a. [pmid: 12151930].
493 Hendrickx JFA, Dewulf BBC, De Mey N, et al. Development and performance of a two-step desflurane-O2/N2O fresh gas flow sequence. J Clin Anesth. 2008;20(7):501-507. X-2, X-3. [pmid: 19019658].
494 Hendrickx JFA, Dewulf BBC, De Mey N, et al. Development and performance of a two-step desflurane-O<sub>2</sub>/N<sub>2</sub>O fresh gas flow sequence. J Clin Anesth. 2008;20(7):501-507. X-2, X-3a. [pmid: 19019658].
495 Henry A, Nand SL. Women's antenatal knowledge and plans regarding intrapartum pain management at the Royal Hospital for Women. Aust N Z J Obstet Gynaecol. 2004;44(4):314-317. X-2, X-3, X-5. [pmid: 15282002].
496 Henry RJ. Assessing environmental health concerns associated with nitrous oxide. J Am Dent Assoc. Dec. 1992;123(12):41-7. X-1, X-2. [pmid: 1484134].
497 Herff H, Paal P, Von Goedecke A, et al. Fatal errors in nitrous oxide delivery. Anaesthesia. 1202. 62(12):1202-1206. X-1, X-2, X-3a, X-5. [pmid: 17991254].
498 Herrmann W, Hubner U, Koch I, et al. Alteration of homocysteine catabolism in pre-eclampsia, HELLP syndrome and placental insufficiency. Clin Chem Lab Med. 1109. 42(10):1109-1116. X-1, X-2, X-3. [pmid: 15552268].
499 Hervey WH, Hustead RF. Ketamine for dilatation and currettage procedures: patient acceptance. Anesth Analg. Jul-Aug. 1972;51(4):647-55. X-3. [pmid: 5064798].
500 Herzog S, Cunze T, Martin M, et al. Pulsatile vs. continuous parenteral tocolysis: comparison of side effects. Eur J Obstet Gynecol Reprod Biol. 1999;85(2):199-204. X-2, X-3. [pmid: 10584635].
501 Heytens L, Camu F. Pulmonary edema during cesarean section related to the use of oxytocic drugs. Acta Anaesthesiol Belg. 1984;35(2):155-164. X-1, X-2, X-3a, X-5. [pmid: 6593995].
502 Higuma T, Oikawa K, Kato T, et al. Comparison of the effects of long-acting nifedipine CR and diltiazem R in patients with vasospastic angina: Aomori coronary spastic angina study. Journal of Cardiology. 2010;56(3):354-360. X-2, X-3. [pmid: 20884177].
503 Hildingsson I, Karlstrom A, Nystedt A. Women's experiences of induction of labour - Findings from a Swedish regional study. Aust N Z J Obstet Gynaecol. 2011;51(2):151-157. X-2, X-3. [pmid: 21466518].
504 Hildingsson IM, Lindgren HE, Haglund B, et al. Characteristics of women giving birth at home in Sweden: A national register study. Am J Obstet Gynecol. 1366. 195(5):1366-1372. X-2, X-3, X-5. [pmid: 16707081].
505 Hill RP, Lubarsky DA, Phillips-Bute B, et al. Cost-effectiveness of prophylactic antiemetic therapy with ondansetron, droperidol, or placebo. Anesthesiology. Apr. 2000;92(4):958-67. X-2, X-3d. [pmid: 10754614].
506 Hiltunen P, Raudaskoski T, Ebeling H, et al. Does pain relief during delivery decrease the risk of postnatal depression?. Acta Obstet Gynecol Scand. Mar. 2004;83(3):257-61. X-2, X-5. [pmid: 14995921].
507 Hines RS, Hines SH, Isaacs JD Jr. Anesthetic effects on reproductive outcome. Assisted Reproduction Reviews. 1998;8(1):47-50. X-1, X-2, X-3a.
508 Hla Yee Y, Shirley DG, Singer DRJ, et al. Is renal lithium clearance altered in essential hypertension?. Journal of Hypertension. 1989;7(12):955-960. X-2, X-3. [pmid: 2516863].
509 Ho AMH, Ngan Kee WD, Chung DC. Should laboring parturients with Harrington rods receive lumbar epidural analgesia?. Int J Gynaecol Obstet. 1999;67(1):41-43. X-1, X-2, X-3, X-5. [pmid: 10576239].
510 Hodgkinson R, Bhatt M, Kim SS, et al. Neonatal neurobehavioral tests following cesarean section under general and spinal anesthesia. Am J Obstet Gynecol. Nov. 15. 1978;132(6):670-4. X-2, X-3d. [pmid: 717473].
511 Hodgkinson R, Bhatt M, Wang CN. Double-blind comparison of the neurobehaviour of neonates following the administration of different doses of meperidine to the mother. Can Anaesth Soc J. Sep. 1978;25(5):405-11. X-2, X-3, X-5. [pmid: 359110].
512 Hodgkinson R, Husain FJ, Hayashi RH. Systemic and pulmonary blood pressure during caesarean section in parturients with gestational hypertension. Can Anaesth Soc J. Jul. 1980;27(4):389-94. X-2, X-3d. [pmid: 7407669].
513 Hodgkinson R, Marx GF, Kim SS, et al. Neonatal neurobehabioral tests following vaginal delivery under ketamine, thiopental, and extradural anesthesia. Anesth Analg. Jul-Aug. 1977;56(4):548A. X-3a, X-5.
514 Hogg MI, Davies JM, Mapleson WW, et al. Proposed upper limit of respiratory resistance for inhalation apparatus used in labour. Br J Anaesth. Feb. 1974;46(2):149-52. X-1, X-2, X-3, X-5. [pmid: 4525502].
515 Holdcroft A. UK drug analysis prints and anaesthetic adverse drug reactions. Pharmacoepidemiol Drug Saf. 2007;16(3):316-328. X-2, X-3d, X-5. [pmid: 16767795].
516 Holdcroft A, Gibberd FB, Hargrove RL, et al. Neurological complications associated with pregnancy. Br J Anaesth. 1995;75(5):522-526. X-2, X-3, X-5. [pmid: 7577273].
517 Holdcroft A, Robinson MJ, Gordon H, et al. Comparison of effect of two induction doses of methohexitone on infants delivered by elective caesarean section. Br Med J. Jun. 1. 1974;2(5917):472-5. X-2, X-3a, X-5. [pmid: 4834097].
518 Holland R. The Inventors. Anaesthesia and Intensive Care. 2006;34(SUPPL. 1):33-38. X-1, X-2. [pmid: 16800226].
519 Hollenbeck AR, Smith RF, Edens ES, et al. Early trimester anesthetic exposure: Incidence rates in an urban hospital population. Child Psychiatry Hum Dev. 1985;16(2):126-134. X-3a, X-3d, X-5. [pmid: 4075862].
520 Hollmen A. Neurobehavioural effects of drugs and anaesthetics on the neonate. Eur J Obstet Gynecol Reprod Biol. 1983;15(4-6):362-364. X-1, X-2, X-5.
521 Hollmen A, Jagerhorn M. Does increased maternal Pa CO2 during general anaesthesia for caesarean section improve foetal acid-base parameters? Comparison of patients with normal and suspected pathological uteroplacental circulation. Acta Anaesthesiol Scand. 1972;16(4):221-9. X-3. [pmid: 4651739].
522 Hollmen AI, Eskelinen P, Tolonen U. Effects of anaesthesia for Caesarean section on the computerized EEG of the neonate. Eur J Anaesthesiol. 1985;2(1):39-51. X-2, X-3, X-5. [pmid: 4018040].
523 Hollmen AI, Jouppila R, Koivisto M, et al. Neurologic activity of infants following anesthesia for cesarean section. Anesthesiology. May. 1978;48(5):350-6. X-2, X-3a, X-3d, X-5. [pmid: 646154].
524 Holmdahl MH. Demand-flow apparatus with control of preset N2O-O2 mixture for use in labour. Acta Anaesthesiol Scand Suppl. 1969;37:188-91. X-1, X-2, X-3, X-5. [pmid: 5375255].
525 Holmes GL, Harden C, Liporace J, et al. Postnatal concerns in children born to women with epilepsy. Epilepsy Behav. 2007;11(3):270-276. X-1, X-2, X-3d. [pmid: 17996634].
526 Holmes JL, Hooper MJ, Barraclough BH, et al. Anaesthesia for thyroid surgery. Anaesth Intensive Care. Feb. 1973;1(3):218-25. X-3. [pmid: 4797030].
527 Holzman RS, Riley LE, Aron E, et al. Perioperative care of a patient with acute fatty liver of pregnancy. Anesth Analg. 1268. 92(5):1268-1270. X-3. [pmid: 11323360].
528 Hong JY, Jung WP, Jong IO. Comparison of preoperative gastric contents and serum gastrin concentrations in pregnant and nonpregnant women. J Clin Anesth. 2005;17(6):451-455. X-1, X-2, X-3a, X-3d. [pmid: 16171666].
529 Hood DD, Dewan DM, James IFM. The use of nitroglycerin in preventing the hypertensive response to tracheal intubation in severe preeclampsia. Anesthesiology. 1985;63(3):329-332. X-2, X-3d, X-5. [pmid: 3927785].
530 Hood DD, Holubec DM. Elective repeat cesarean section. Effect of anesthesia type on blood loss. J Reprod Med. Apr. 1990;35(4):368-72. X-2, X-3, X-5. [pmid: 2352227].
531 Horrigan BJ. Institute for alternative futures seeks input. Explore (NY). 2006;2(5):388-393. X-3d, X-5. [pmid: 16979100].
532 Hosoda R, Hattori M, Shimada Y. Favorable effects of epidural analgesia on hemodynamics, oxygenation and metabolic variables in the immediate post-anesthetic period. Acta Anaesthesiol Scand. 1993;37(5):469-474. X-2, X-3. [pmid: 8356859].
533 Houghton IT. The Marrett apparatus: Is hospital anaesthetic equipment compatible with field use?. Anaesthe Intensive Care. 2005;33(SUPPL. 1):7-13. X-1, X-2, X-3.
534 Hovorka J, Korttila K, Erkola O. Nitrous oxide does not increase nausea and vomiting following gynaecological laparoscopy. Can J Anaesth. Mar. 1989;36(2):145-8. X-2, X-3a, X-3d, X-5. [pmid: 2523250].
535 Howell CJ, Chalmers I. A review of prospectively controlled comparisons of epidural with non-epidural forms of pain relief during labour. Int J Obstet Anesth. Jan. 1992;1(2):93-110. X-1, X-2. [pmid: 15636806].
536 Howell CJ, Kidd C, Roberts W, et al. A randomised controlled trial of epidural compared with non-epidural analgesia in labour. BJOG. 2001;108(1):27-33. X-5. [pmid: 11213000].
537 Howorth FH. Air flow patterns in the operating theatre. Eng Med. Apr. 1980;9(2):87-92. X-1, X-2, X-3, X-5. [pmid: 10273193].
538 Hsu SH, Shalansky SJ. Pharmacoeconomics of propofol versus thiopental for induction of anaesthesia in short procedures. Can J Hosp Pharm. Aug. 1995;48(4):208-13. X-2, X-3. [pmid: 10145070].
539 Hu Y, Zhou J, Hao S, et al. Changes in the ratio of Tc1/Tc2 and Th1/Th2 cells but not in subtypes of NK-cells in preeclampsia. Int J Mol Sci. 2007;8(6):492-504. X-2, X-3.
540 Hudome SM, Ergenekon EN, Darrow KA, et al. Precise control of nitric oxide concentration in the inspired gas of continuous flow respiratory devices. Pediatr Pulmonol. 1996;22(3):182-187. X-2, X-3. [pmid: 8893257].
541 Hudson RJ, Stanski DR. Barbiturates - Pharmacokinetics and pharmacodynamics. Clin Anaesthesiol. 1984;2(1):27-41. X-1, X-2, X-3.
542 Huebner CE, Milgrom P, Conrad D, et al. Providing dental care to pregnant patients: a survey of Oregon general dentists. J Am Dent Assoc. Feb. 2009;140(2):211-22. X-2, X-3. [pmid: 19188418].
543 Hughes R. Atracurium - The first years. Clinics in Anaesthesiology. 1985;3(2):331-345. X-2, X-3.
544 Hughes SC. Analgesia methods during labour and delivery. Can J Anaesth. May. 1992;39(5 Pt 2):R18-28. X-1, X-2, X-3, X-5. [pmid: 1600570].
545 Hull CJ, Jacobson L. A clinical trial of alfentanil as an adjuvant for short anaesthetic procedures. Br J Anaesth. Suppl 2. 1983;55:173S-178S. X-2, X-3. [pmid: 6418190].
546 Humphrey M, Chang A, Gilbert M, et al. The effect of intravenous ritodrine on the acid-base status of the fetus during the second stage of labour. Br J Obstet Gynaecol. Mar. 1975;82(3):234-45. X-3. [pmid: 237528].
547 Hunter JG, Swanstrom L, Thornburg K. Carbon dioxide pneumoperitoneum induces fetal acidosis in a pregnant ewe model. Surg Endosc. Mar. 1995;9(3):272-7. discussion 277-9. X-2, X-3. [pmid: 7597597].
548 Hunter T, Kleiman S. Anaesthesia for Caesarean hysterectomy in a patient with a preoperative diagnosis of placenta percreta with invasion of the urinary bladder. Can J Anaesth. 1996;43(3):246-251. X-1, X-2, X-3. [pmid: 8829864].
549 Hunton J, Oswal VH. Metal tube anaesthesia for ear, nose and throat carbon dioxide laser surgery. Anaesthesia. 1210. 40(12):1210-1212. X-1, X-2, X-3a, X-3d, X-5. [pmid: 3936375].
550 Husemeyer RP, Cummings AJ, Rosankiewicz JR, et al. A study of pethidine kinetics and analgesia in women in labour following intravenous intramuscular and epidural administration. Br J Clin Pharmacol. 1982;13(2):171-176. X-3, X-5. [pmid: 7059414].
551 Hutchison AA, Forbes AM, Russell G. Effective pulmonary blood flow in preterm and light-for-date infants. Pediatrics. Feb. 1976;57(2):187-90. X-2, X-3. [pmid: 1250653].
552 Hutchison AA, Ogletree ML, Palme CJH. Plasma 6-keto prostaglandin F<sub>1</sub>alpha and thromboxane B<sub>2</sub> in sick preterm neonates. Prostaglandins Leukot Med. 1985;18(2):163-181. X-2, X-3. [pmid: 3859877].
553 Huttel FA, Mitchell I, Fischer WM, et al. A quantitative evaluation of psycho-prophylaxis in childbirth. J Psychosom Res. Apr. 1972;16(2):81-92. X-3, X-5. [pmid: 5038892].
554 Ickx BE, Rigolet M, Van Der Linden PJ. Cardiovascular and metabolic response to acute normovolemic anemia: Effects of anesthesia. Anesthesiology. 1011. 93(4):1011-1016. X-2, X-3. [pmid: 11020756].
555 Idris AH, McDermott MF, Raucci JC, et al. Emergency department treatment of severe asthma: Metered-dose inhaler plus holding chamber is equivalent in effectiveness to nebulizer. Chest. 1993;103(3):665-672. X-2, X-3. [pmid: 8449049].
556 Imberti R, Preseglio I, Imbriani M, et al. Low flow anaesthesia reduces occupational exposure to inhalation anaesthetics. Environmental and biological measurements in operating room personnel. Acta Anaesthesiol Scand. Jul. 1995;39(5):586-91. X-2, X-5. [pmid: 7572005].
557 Imbriani M, Ghittari S, Pezzagano G. Nitrous oxide in urine as biological index of exposure in operating room personnel. Appl IndHygiene. 1988. 1988;3:223-7. X-3d, X-5.
558 Imbriani M, Ghittori S, Pezzagno G. The biological monitoring of inhalation anaesthetics. G Ital Med Lav Ergon. Jan-Mar. 1998;20(1):44-9. X-4. [pmid: 9546101].
559 Imtiaz A, Mustafa S, Masroorudin, et al. Effect of spinal and general anaesthesia over APGAR score in neonates born after elective cesarean section. J Liaquat Univ Med Health Sci. 2010;9(3):151-154. X-2, X-3.
560 Ingram J, Domagala C, Yates S. The effects of shiatsu on post-term pregnancy. Complement Ther Med. 2005;13(1):11-15. X-2, X-3. [pmid: 15907673].
561 Inomata S, Nishikawa T, Saito S, et al. ‘Best’ PEEP during one-lung ventilation. Br J Anaesth. 1997;78(6):754-756. X-2, X-3. [pmid: 9215031].
562 Ioscovich A, Gislason R, Fadeev A, et al. Peripartum anesthetic management of patients with Takayasu's arteritis: case series and review. Int J Obstet Anesth. 2008;17(4):358-364. X-1, X-2, X-3. [pmid: 18691876].
563 Ioscovich A, Shen O, Sichel JY, et al. Remifentanil-nitroglycerin combination as an anesthetic support for ex utero intrapartum treatment (EXIT) procedure. J Clin Anesth. 2011;23(2):142-144. X-1, X-2, X-3. [pmid: 21377080].
564 Irestedt L. Current status of nitrous oxide for obstetric pain relief. Acta Anaesthesiol Scand. Nov. 1994;38(8):771-2. X-1, X-2, X-5. [pmid: 7887095].
565 Isobe K, Kusaka T, Fujikawa Y, et al. Measurement of cerebral oxygenation in neonates after vaginal delivery and cesarean section using full-spectrum near infrared spectroscopy. Comp Biochem Physiol A Mol Integr Physiol. 2002;132(1):133-138. X-2, X-3. [pmid: 12062201].
566 Ittichaikulthol W, Sriswasdi S, Prachanpanich N, et al. Bispectral index in assessment of 3% and 4.5% desflurane in 50% N2O for caesarean section. J Med Assoc Thai. Aug. 2007;90(8):1546-50. X-2, X-3. [pmid: 17926983].
567 Ivankovic AD, Elam JO, Huffman J. Methoxyflurane anesthesia for cesarian section. J Reprod Med. Mar. 1971;6(3):105-9. X-3. [pmid: 5114096].
568 Jacobs DE, Middendorf PJ. Control of nitrous oxide exposures in dental operatories using local exhaust ventilation: A pilot study. Anesth Prog. 1986;33(5):235-242. X-2, X-3d, X-5. [pmid: 3465259].
569 Jacobson B, Eklund G, Hamberger L, et al. Perinatal origin of adult self-destructive behavior. Acta Psychiatr Scand. Oct. 1987;76(4):364-71. X-2, X-3. [pmid: 3425362].
570 Jakobsson J, Davidson S, Andreen M, et al. Opioid supplementation to propofol anaesthesia for outpatient abortion: a comparison between alfentanil, fentanyl and placebo. Acta Anaesthesiol Scand. Nov. 1991;35(8):767-70. X-2, X-3. [pmid: 1763599].
571 Jakobsson J, Oddby E, Rane K. Patient evaluation of four different combinations of intravenous anaesthetics for short outpatient procedures. Anaesthesia. Nov. 1993;48(11):1005-7. X-2, X-3. [pmid: 8285950].
572 Jalkanen A, Alanen A, Airas L. Pregnancy outcome in women with multiple sclerosis: Results from a prospective nationwide study in Finland. Multiple Sclerosis. 2010;16(8):950-955. X-2, X-3. [pmid: 20542921].
573 James CF, Banner T, Caton D. Cardiac output in women undergoing cesarean section with epidural or general anesthesia. Am J Obstet Gynecol. 1178. 160(5 I):1178-1184. X-2, X-3. [pmid: 2729392].
574 James MFM, Huddle KRL, Owen AD, et al. Use of magnesium sulphate in the anaesthetic management of phaeochromocytoma in pregnancy. Can J Anaesth. 1988;35(2):178-182. X-1, X-2, X-3. [pmid: 3356054].
575 James MFM, White JF. Anesthetic considerations at moderate altitude. Anesth Analg. 1097. 63(12):1097-1105. X-1, X-2, X-3. [pmid: 6239572].
576 Jan GS, Tong WN, Chan AM, et al. Recovery from mivacurium block with or without anticholinesterase following continuous infusion in obstetric patients. Anaesth Intensive Care. Oct. 1996;24(5):585-9. X-2, X-3, X-5. [pmid: 8909671].
577 Janeczko GF, el-Etr AA, Younes S. Low-dose ketamine anesthesia for obstetrical delivery. Anesth Analg. Nov-Dec. 1974;53(6):828-31. X-3d, X-5. [pmid: 4473922].
578 Jansen GFA, Van Praagh BH, Kedaria MB, et al. Jugular bulb oxygen saturation during propofol and isoflurane/nitrous oxide anesthesia in patients undergoing brain tumor surgery. Anesth Analg. 1999;89(2):358-363. X-2, X-3. [pmid: 10439748].
579 Jarvi K, Osborn N, Wall N. An obstetric patient with neurocadiogenic syncope. Int J Obstet Anesth. 2009;18(4):396-399. X-1, X-2, X-3. [pmid: 19700306].
580 Jeffs SA, Hall JE, Morris S. Comparison of morphine alone with morphine plus clonidine for postoperative patient-controlled analgesia. Br J Anaesth. 2002;89(3):424-427. X-2, X-3. [pmid: 12402720].
581 Jenssen H. The shape of the amniotic pressure curve before and after paracervical block during labour. Acta Obstet Gynecol Scand Suppl. 1975;(42):1-29. X-3. [pmid: 1060356].
582 Jenstrup M, Fruergaard KO, Mortensen CR. Pollution with nitrous oxide using laryngeal mask or face mask. Acta Anaesthesiol Scand. 1999;43(6):663-666. X-2, X-3, X-5. [pmid: 10408822].
583 Jha S, Chiu JW, Yeo ISW. Intravenous nitroglycerine versus general anaesthesia for placental extraction - A sequential comparison. Med Sci Monit. 2003;9(7). X-1, X-2, X-3c.
584 Jirasiritham S, Tantivitayatan K, Sirivararom P. Over half MAC sevoflurane in cesarean section. J Med Assoc Thai. Jul. 2005;88(7):914-20. X-2, X-3d. [pmid: 16241019].
585 Joffe M. Time to pregnancy: A measure of reproductive function in either sex. Occup Environ Med. 1997;54(5):289-295. X-1, X-2, X-3. [pmid: 9196448].
586 John AH. The effect of maternal hypoxia on the heart rate of the foetus in utero. Br J Anaesth. Jul. 1965;37(7):515-9. X-5. [pmid: 5829161].
587 Johnson JA, Buchan RM, Reif JS. Effect of waste anesthetic gas and vapor exposure on reproductive outcome in veterinary personnel. Am Ind Hyg Assoc J. 1987;48(1):62-66. X-2, X-3, X-5. [pmid: 3565261].
588 Johnson MD, Flusche G. The anaesthetic management of selected respiratory problems in the obstetric patient. Clin Anaesthesiol. 1986;4(2):261-273. X-1, X-2, X-3d, X-5.
589 Johnstone MJ. The effect of lorazepam on neonatal feeding behaviour at term. Pharmatherapeutica. 1982;3(4):259-262. X-2, X-3d. [pmid: 6128740].
590 Jones BP, Milliken BC, Penning DH. Anesthesia for Cesarean section in a patient with paraplegia resulting from tumour metastases to spinal cord. Can J Anaesth. 1122. 47(11):1122-1128. X-1, X-2, X-3d. [pmid: 11097545].
591 Jones CR, McCullouch J, Butters L. Plasma catecholamines and modes of delivery: The relation between catecholamine levels and in-vitro platelet aggregation and adrenoreceptor radioligand binding characteristics. BJOG. 1985;92(6):593-599. X-2, X-3d.
592 Jones D. The problem patient. Anaesthesia during pregnancy and delivery. Curr Ther (Seaforth). 1985;26(6):97-109. X-1, X-2, X-3, X-5.
593 Jones HE, Svikis DS, Tran G. Patient compliance and maternal/infant outcomes in pregnant drug-using women. Subst Use Misuse. 1411. 37(11):1411-1422. X-2, X-3. [pmid: 12371578].
594 Jones I, Craddock N. Familiality of the puerperal trigger in bipolar disorder: Results of a family study. Am J Psychiatry. 2001;158(6):913-917. X-2, X-3. [pmid: 11384899].
595 Jordan S, Emery S, Bradshaw C, et al. The impact of intrapartum analgesia on infant feeding. Obstet Gynecol Surv. 2005;60(12):790-791. X-1, X-2, X-3, X-5.
596 Jouppila R, Puolakka J, Kauppila A, et al. Maternal and umbilical cord plasma noradrenaline concentrations during labour with and without segmental extradural analgesia, and during caesarean section. Br J Anaesth. 1984;56(3):251-255. X-3d, X-5. [pmid: 6704273].
597 Juvin P, Servin F, Giraud O, et al. Emergence of elderly patients from prolonged desflurane, isoflurane, or propofol anesthesia. Anesth Analg. Sep. 1997;85(3):647-51. X-2, X-3a, X-3d. [pmid: 9296424].
598 Kainuma M, Kimura N, Nonami T, et al. The effect of dobutamine on hepatic blood flow and oxygen supply-uptake ratio during enflurane nitrous oxide anesthesia in humans undergoing liver resection. Anesthesiology. 1992;77(3):432-438. X-2, X-3a, X-3d. [pmid: 1519780].
599 Kaita TM, Nikkola EM, Rantala MI, et al. Fetal oxygen saturation during epidural and paracervical analgesia. Acta Obstet Gynecol Scand. 2000;79(5):336-340. X-3, X-5. [pmid: 10830758].
600 Kalappa R, Ueland K, Hansen JM, et al. Maternal acid-base status during cesarean section under thiopental, N201 and succinylcholine anesthesia. Am J Obstet Gynecol. Feb. 1. 1971;109(3):411-7. X-2, X-3d, X-5. [pmid: 5549183].
601 Kallela H, Haasio J, Korttila K. Comparison of eltanolone and propofol in anesthesia for termination of pregnancy. Anesth Analg. 1994;79(3):512-516. X-2, X-3b. [pmid: 8067557].
602 Kamal NM, Omar SH, Radwan KG, et al. Bispectral index monitoring tailors clinical anesthetic delivery and reduces anesthetic drug consumption. J Med Sci. 2009;9(1):10-16. X-2, X-3a, X-3d.
603 Kampe S, Kiencke P, Delis A, et al. The continuous epidural infusion of ropivacaine 0.1% with 0.5 mugmL-1 sufentanil provides effective postoperative analgesia after total hip replacement: A pilot study. Can J Anaesth. 2003;50(6):580-585. X-2, X-3a, X-3d. [pmid: 12826550].
604 Kan AS, Caves N, Wong SY, et al. A double-blind, randomized controlled trial on the use of a 50:50 mixture of nitrous oxide/oxygen in pain relief during suction evacuation for the first trimester pregnancy termination. Hum Reprod. Oct. 2006;21(10):2606-11. X-2, X-3b. [pmid: 16790607].
605 Kanazawa M, Kinefuchi Y, Suzuki T, et al. The use of sevoflurane anesthesia during early pregnancy. Tokai Journal of Experimental and Clinical Medicine. 1999;24(2):53-55. X-1, X-2, X-3d. [pmid: 10641992].
606 Kangas L, Erkkola R, Kanto J, et al. Halothane anaesthesia in caesarean section. Acta Anaesthesiol Scand. 1976;20(3):189-94. X-2, X-3a, X-3d. [pmid: 8942].
607 Kanto J, Erkkola R, Mansikka M, et al. Segmental epidural analgesia. A modern method for safe and effective management of labor pains. Biol Res Pregnancy Perinatol. 1983;4(4):172-176. X-3, X-5. [pmid: 6652173].
608 Kanto J, Pihlajamaki K. Oropharyngeal absorption of atropine. Int J Clin Pharmacol Ther Toxicol. 1986;24(11):627-629. X-3. [pmid: 3793298].
609 Karadia S, Walford C, McSwiney M, et al. Hepatic rupture complicating eclampsia in pregnancy. Br J Anaesth. 1996;77(6):792-794. X-1, X-2, X-3, X-5. [pmid: 9014637].
610 Karakaya H, Sahin N, Arslan A, et al. Complete sternal cleft in adolescence. Internet J Anesthesiol. 2003;6(2). X-1, X-2, X-3.
611 Karasawa F, Takita A, Fukuda I, et al. Nitrous oxide concentrations in maternal and fetal blood during caesarean section. Eur J Anaesthesiol. Jul. 2003;20(7):555-9. X-2, X-3a, X-3d, X-5. [pmid: 12884989].
612 Kardong-Edgren S. Is it time to change the paradigm?. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 1999;28(5):477-9. X-1, X-2.
613 Kaul HL, Mehta M, Bhanumati G, et al. Vecuronium is not suitable for rapid sequence intubation for caesarean section. J Anaesthesiol Clin Pharmacol. 1998;14(3):241-244. X-3.
614 Keating IHJ, Kundrat M. Patient-controlled analgesia with nitrous oxide in cancer pain. J Pain Symptom Manage. 1996;11(2):126-130. X-2, X-3, X-5. [pmid: 8907144].
615 Keats AS. The effect of drugs on respiration in man. Annu Rev Pharmacol Toxicol. 1985;25:41-65. X-1, X-2, X-3. [pmid: 2860846].
616 Kelly D, Brull SJ. The cost of modern technology. J Clin Anesth. 1995;7(1):80-81. X-1, X-3. [pmid: 7772365].
617 Kennedy GL Jr., Smith SH, Keplinger ML, et al. Reproductive and teratologic studies with halothane. Toxicol Appl Pharmacol. Mar. 1976;35(3):467-74. X-2, X-3d, X-5. [pmid: 1265761].
618 Kennedy RL. General analgesia and anesthesia in obstetrics. Clin Obstet Gynecol. Jun. 1974;17(2):227-39. X-1, X-2, X-5. [pmid: 4152524].
619 Kenny GNC, Sutcliffe NP. Target-controlled infusions: Stress free anesthesia?. J Clin Anesth. 1996;8(3 SUPPL). X-1, X-2, X-3, X-5.
620 Kersten JR, Kane K, Coon R. Bronchospasm during pneumoperitoneum. Anesth Analg. 1099. 81(5):1099-1101. X-2, X-3a, X-5. [pmid: 7486057].
621 Kestin IG, Dorje P. Anaesthesia for evacuation of retained products of conception. Comparison between alfentanil plus etomidate and fentanyl plus thiopentone. Br J Anaesth. Mar. 1987;59(3):364-8. X-3. [pmid: 3103663].
622 Khaw KS, Ngan Kee WD, Chu CY, et al. Effects of different inspired oxygen fractions on lipid peroxidation during general anaesthesia for elective Caesarean section. Br J Anaesth. Sep. 2010;105(3):355-60. X-3. [pmid: 20576633].
623 Khaw KS, Ngan Kee WD, Chu CY, et al. Effects of different inspired oxygen fractions on lipid peroxidation during general anaesthesia for elective Caesarean section+. Br J Anaesth. 2010;105(3):355-360. X-3. [pmid: 20576633].
624 Kilickan L, Solak M, Bayindir O. Thoracic epidural anesthesia preserves myocardial function during intraoperative and postoperative period in coronary artery bypass grafting operation. J Cardiovasc Surg (Torino). 2005;46(6):559-567. X-2, X-3.
625 Kim TY, Ryu DH. The effect of fundal pressure at Caesarean section on maternal haemodynamics. Anaesthesia. 2006;61(5):434-438. X-2, X-3. [pmid: 16674616].
626 King H, Ashley S, Brathwaite D, et al. Adequacy of general anesthesia for cesarean section. Anesth Analg. Jul. 1993;77(1):84-8. X-3. [pmid: 8317753].
627 King MJ, Bowden MI, Cooper GM. Epidural fentanyl and 0.5% bupivacaine for elective caesarean section. Anaesthesia. Apr. 1990;45(4):285-8. X-3. [pmid: 2337211].
628 Kinoshita O, Aoki A, Yamamura T, et al. Plasma glucagon levels during spinal anesthesia and surgery in a glucagon-deficient patient. Anesth Analg. 1983;62(9):846-847. X-1, X-2, X-3. [pmid: 6881572].
629 Kitajima T, Miyamoto H, Takiguchi T, et al. General anesthesia for Cesarean section in a parturient with quintuplet pregnancy. J Anesth. 1993;7(2):240-244. X-2, X-3a, X-5. [pmid: 15278482].
630 Kivalo I, Timonen S, Castren O. The influence of anaesthesia and the induction-delivery interval on the newborn delivered by Caesarean section. Ann Chir Gynaecol Fenn. 1971;60(2):71-5. X-2, X-3a, X-5. [pmid: 5555822].
631 Kizilarslan S, Kuvaki B, Onat U, et al. Epidural fentanyl-bupivacaine compared with clonidine-bupivacaine for analgesia in labour. Eur J Anaesthesiol. 2000;17(11):692-697. X-3a, X-3d, X-5. [pmid: 11029568].
632 Kizilarslan S, Kuvaki B, Onat U, et al. Epidural fentanyl-bupivacaine compared with clonidine-bupivacaine for analgesia in labour. Eur J Anaesthesiol. 2000;17(11):692-697. X-3. [pmid: 11029568].
633 Kjellmer I, Magno R, Karlsson K. Anesthesia for Cesarean section. I. Effects on the respiratory adaptation of the newborn in elective Cesarean section. Acta Anaesthesiol Scand. 1974;18(1):48-57. X-2, X-3, X-5. [pmid: 4836146].
634 Klebanoff MA, Shiono PH, Rhoads GG. Spontaneous and induced abortion among resident physicians. JAMA. Jun. 5. 1991;265(21):2821-5. X-2, X-3. [pmid: 2033738].
635 Kline JK. Maternal occupation: effects on spontaneous abortions and malformations. Occup Med. Jul-Sep. 1986;1(3):381-403. X-1. [pmid: 3299783].
636 Knill-Jones RP, Rodrigues LV, Moir DD, et al. Anaesthetic practice and pregnancy. Controlled survey of women anaesthetists in the United Kingdom. Lancet. Jun. 17. 1972;1(7764):1326-8. X-3, X-5. [pmid: 4113412].
637 Kobielski J, Wysocki M, Orlicz P. Clinical evaluation of calypsol used for induction of anaesthesia for cesarean section. Ther Hung. 1985;33(3):140-147. X-2, X-3, X-5. [pmid: 3842010].
638 Konieczko KM, Chapple JC, Nunn JF. Fetotoxic potential of general anaesthesia in relation to pregnancy. Br J Anaesth. 1987;59(4):449-454. X-2, X-3, X-5. [pmid: 3566997].
639 Krantz ML, Campbell WT, Edwards WL. The effect of spontaneous ventilation on blood gases in obstetric patients under general anesthesia. Anesth Analg. Nov-Dec. 1973;52(6):965-8. X-3, X-5. [pmid: 4796574].
640 Kressig P, Beinder E, Schweer H, et al. Post-delivery oxidative stress in women with preeclampsia or IUGR. J Perinat Med. 2008;36(4):310-315. X-3. [pmid: 18598120].
641 Krestow M. The effect of post-anaesthetic dreaming on patient acceptance of ketamine anaesthesia: a comparison with thiopentone-nitrous oxide anaesthesia. Can Anaesth Soc J. Jul. 1974;21(4):385-9. X-2, X-3, X-5. [pmid: 4836917].
642 Krintel JJ, Wegmann F. Aminophylline reduces the depth and duration of sedation with barbiturates. Acta Anaesthesiol Scand. May. 1987;31(4):352-4. X-3. [pmid: 3296607].
643 Krishnan L, Gunasekaran N, Bhaskaranand N. Anesthesia for caesarean section and immediate neonatal outcome. Indian Journal of Pediatrics. 1995;62(2):219-223. X-3. [pmid: 10829871].
644 Krishnan L, Gunasekaran N, Bhaskaranand N. Neonatal effects of anesthesia for caesarean section. Indian J Pediatr. 1995;62(1):109-113. X-3. [pmid: 10829852].
645 Kugel G, Letelier C, Attallah H. Chronic low level nitrous oxide exposure and infertility. J Dent Res. 1989;68:313. X-3d, X-5.
646 Kugel G, Letelier C, Zive MA, et al. Nitrous oxide and infertility. Anesth Prog. Jul. 1990;37(4):176-80. X-2, X-3. [pmid: 2096739].
647 Kumar IH, Borkar JD. Twin surgeries in a case of pheochromocytoma. Journal of Anaesthesiology Clinical Pharmacology. 2008;24(2):217-218. X-1, X-2, X-3, X-5.
648 Kvorning Ternov N, Nilsson M, Lofberg L, et al. Acupuncture for pain relief during childbirth. Acupunct Electrother Res. 1998;23(1):19-26. X-3a. [pmid: 9607101].
649 Ladakhi GM, Mubarik M, Nabi B, et al. Neonatal risk factors and outcome of birth asphyxia. JK Practitioner. 2000;7(4):267-270. X-2, X-3d, X-5.
650 Lahoud GY, Averley PA. Comparison of sevoflurane and nitrous oxide mixture with nitrous oxide alone for inhalation conscious sedation in children having dental treatment: A randomised controlled trial. Anaesthesia. 2002;57(5):446-450. X-2, X-3. [pmid: 11966554].
651 Laine K, Heikkinen T, Ekblad U, et al. Effects of exposure to selective serotonin reuptake inhibitors during pregnancy on serotonergic symptoms in newborns and cord blood monoamine and prolactin concentrations. Arch Gen Psychiatry. 2003;60(7):720-726. X-2, X-3. [pmid: 12860776].
652 Laishley RS, Morgan BM. A single dose epidural technique for caesarean section. A comparison between 0.5% bupivacaine plain and 0.5% bupivacaine with adrenaline. Anaesthesia. Feb. 1988;43(2):100-3. X-3. [pmid: 3354801].
653 Lally JE, Murtagh MJ, Macphail S, et al. More in hope than expectation: A systematic review of women's expectations and experience of pain relief in labour. BMC Medicine. 2008;6(7). X-1, X-2, X-3.
654 Lam SP, Yat FSY, Wing YK. Status cataplecticus leading to the obstetric complication of prolonged labor. J Clin Sleep Med. 2007;3(1):56-57. X-2, X-3. [pmid: 17557454].
655 LaMarca B, Speed J, Fournier L, et al. Hypertension in response to chronic reductions in uterine perfusion in pregnant rats effect of tumor necrosis factor-alpha blockade. Hypertension. 1161. 52(6):1161-1167. X-2, X-3. [pmid: 18981324].
656 Landon MJ, Toothill VJ. Effect of nitrous oxide on placental methionine synthase activity. Br J Anaesth. May. 1986;58(5):524-7. X-2, X-3d, X-5. [pmid: 3964518].
657 Lange AP, Secher NJ, Westergaard JG, et al. Neonatal jaundice after labour induced or stimulated by prostaglandin E2 or oxytocin. Lancet. 8279;1(8279):991-994. X-2, X-3. [pmid: 6122848].
658 Lao TT, Halpern SH, MacDonald D, et al. Spinal subdural haematoma in a parturient after attempted epidural anaesthesia. Can J Anaesth. 1993;40(4):340-345. X-2, X-3c. [pmid: 8485794].
659 Latto IP, Molloy MJ, Rosen M. Arterial concentrations of nitrous oxide during intermittent patient-controlled inhalation of 50 percent nitrous oxide in oxygen (Entonox) during the first stage of labour. Br J Anaesth. Oct. 1973;45(10):1029-34. X-2, X-5. [pmid: 4772639].
660 Latto IP, Rosen M, Molloy MJ. Absence of accumulation of methoxyflurane during intermittent self-administration for pain relief in labour. Br J Anaesth. Apr. 1972;44(4):391-400. X-3a, X-5. [pmid: 5032078].
661 Latto IP, Wainwright AC. Anaesthesia for Caesarean section. Analysis of blood concentrations of methoxyflurane using 0.1 per cent methoxyflurane and 40 per cent oxygen. Br J Anaesth. Oct. 1972;44(10):1050-6. X-2, X-3a, X-3d, X-5. [pmid: 4639823].
662 Latto IP, Waldron BA. Anaesthesia for Caesarean section. Analysis of blood concentrations of halothane using 0.2% or 0.65% halothane with 50% nitrous oxide in oxygen. Br J Anaesth. Apr. 1977;49(4):371-8. X-2, X-3. [pmid: 889651].
663 Lauretti GR, Lima ICPR. The effects of intrathecal neostigmine on somatic and visceral pain: Improvement by association with a peripheral anticholinergic. Anesth Analg. 1996;82(3):617-620. X-2, X-3d. [pmid: 8623971].
664 Lavand'homme P, Roelants F. Patient-controlled intravenous analgesia as an alternative to epidural analgesia during labor: questioning the use of the short-acting opioid remifentanil. Survey in the French part of Belgium (Wallonia and Brussels). Acta Anaesthesiol Belg. 2009;60(2):75-82. X-2, X-3. [pmid: 19594088].
665 Law NL, Ng KFJ, Irwin MG, et al. Comparison of coagulation and blood loss during anaesthesia with inhaled isoflurane or intravenous propofol. Br J Anaesth. 2001;86(1):94-98. X-2, X-3. [pmid: 11575418].
666 Lawes EG, Newman B, Campbell MJ, et al. Maternal inspired oxygen concentration and neonatal status for caesarean section under general anaesthesia. Comparison of effects of 33% or 50% oxygen in nitrous oxide. Br J Anaesth. Sep. 1988;61(3):250-4. X-2, X-3d, X-5. [pmid: 3140860].
667 Lawler K. Entonox: too useful to be limited to childbirth?. Prof Care Mother Child. 1995;5(1):19-21. X-1, X-2, X-3. [pmid: 8680210].
668 Laws PJ, Lim C, Tracy S, et al. Characteristics and practices of birth centres in Australia. Aust N Z J Obstet Gynaecol. Jun. 2009;49(3):290-5. X-2, X-3. [pmid: 19566562].
669 Layzer RB. Myeloneuropathy after prolonged exposure to nitrous oxide. Lancet. Dec. 9. 1978;2(8102):1227-30. X-3. [pmid: 82736].
670 Leaming HL. Awareness during anaesthesia. Br Med J. Oct. 4. 1969;4(5674):51. X-1, X-2, X-3d, X-5. [pmid: 5822096].
671 Ledin Eriksson S, Gentele C, Olofsson CH. PCEA compared to continuous epidural infusion in an ultra-low-dose regimen for labor pain relief: a randomized study. Acta Anaesthesiol Scand. Oct. 2003;47(9):1085-90. X-3a, X-3d, X-5. [pmid: 12969100].
672 Lee A. Drug use in pregnancy. (6) Drugs in labour and the puerperium: Part 2. Pharm J. 6857;255(6857):322-325. X-1, X-2, X-3, X-5.
673 Lee CN, Chang SW, Cho NH, et al. Nitrous oxide synthase expression in placenta of preeclampsia. J Korean Med Sci. Dec. 1997;12(6):532-8. X-2, X-3d. [pmid: 9443092].
674 Lee H, Ryu JW, Kim DY, et al. Anesthetic management of the ex utero intrapartum treatment (EXIT) procedure. Korean J Anesthesiol. 2010;59(SUPPL):S154-S157. X-2, X-3. [pmid: 21286428].
675 Lee K, Ho KM. Obstetric regional analgesia services in New Zealand: A national survey. N Z Med J. 1206;117(1206). X-5.
676 Lee PF. Methohexital an aesthesia in caesarean section. Acta Obstet Gynecol Scand. 1965;44(3):458-66. X-3. [pmid: 5863078].
677 Lee PF. Anaesthesia for Caesarean section with methohexital. Acta Anaesthesiol Scand Suppl. 1966;23:138-43. X-3a, X-3d, X-5. [pmid: 4952997].
678 Lee RSY, Milgrom P, Huebner CE, et al. Dentists' perceptions of barriers to providing dental care to pregnant women. Womens Health Issues. 2010;20(5):359-365. X-2, X-3d. [pmid: 20800772].
679 Lee SE, Han BD, Park IS, et al. Evidence supporting proteolytic cleavage of insulin-like growth factor binding protein-1 (IGFBP-1) protein in amniotic fluid. J Perinat Med. 2008;36(4):316-323. X-2, X-3. [pmid: 18598121].
680 Lee SY, Hagen DF. Laparoscopic sterilization in a free-standing clinic: a report of 1,092 cases. Contraception. Dec. 1984;30(6):545-53. X-2, x-3a. [pmid: 6241561].
681 Lee YS, Kim WY, Choi JH, et al. The effect of ketamine on the incidence of emergence agitation in children undergoing tonsillectomy and adenoidectomy under sevoflurane general anesthesia. Korean J Anesthesiol. 2010;58(5):440-445. X-2, X-3a. [pmid: 20532051].
682 Leeman L, Fontaine P, King V, et al. The nature and management of labor pain: part II. Pharmacologic pain relief. Am Fam Physician. Sep. 15. 2003;68(6):1115-20. X-1, X-2, X-3. [pmid: 14524398].
683 Leeson PD, Davis AM, Steele J. Drug-like properties: Guiding principles for design - Or chemical prejudice?. Drug Discov Today Technol. 2004;1(3):189-195. X-1, X-2, X-3d.
684 Leighton BL, Cheek TG, Gross JB. Succinylcholine pharmacodynamics in peripartum patients. Anesthesiology. 1986;64(2):202-205. X-2, X-3d. [pmid: 3946807].
685 Lemmens HJM, Saidman LJ, Eger EI, et al. Obesity modestly affects inhaled anesthetic kinetics in humans. Anesth Analg. 1864. 107(6):1864-1870. X-2, X-3a. [pmid: 19020131].
686 Leo S, Ocampo CE, Lim Y, et al. A randomized comparison of automated intermittent mandatory boluses with a basal infusion in combination with patient-controlled epidural analgesia for labor and delivery. Int J Obstet Anesth. 2010;19(4):357-364. X-3a, X-3d, X-5. [pmid: 20832282].
687 Leo S, Sng BL, Lim Y, et al. A randomized comparison of low doses of hyperbaric bupivacaine in combined spinal-epidural anesthesia for cesarean delivery. Anesth Analg. 1600. 109(5):1600-1605. X-2, X-3d. [pmid: 19843797].
688 Lepage L, Frangie MC, Detaint D, et al. Nitrous oxide inhalation for transoesophageal echocardiography: An alternative to benzodiazepine sedation?. Eur J Echocardiogr. 2008;9(5):621-624. X-2, X-3a. [pmid: 18296403].
689 Leslie K, Sessler DI, Smith WD, et al. Prediction of movement during propofol/nitrous oxide anesthesia. Performance of concentration, electroencephalographic, pupillary, and hemodynamic indicators. Anesthesiology. Jan. 1996;84(1):52-63. X-2, X-3a. [pmid: 8572354].
690 Levack ID, Tunstall ME. Systems modification in obstetric analgesia. Anaesthesia. Feb. 1984;39(2):183-5. X-1, X-2, X-5. [pmid: 6703274].
691 Lew TW, Tay DH, Thomas E. Venous air embolism during cesarean section: more common than previously thought. Anesth Analg. Sep. 1993;77(3):448-52. X-2, X-3d. [pmid: 8368543].
692 Li J, Schulze-Neick I, Lincoln C, et al. Oxygen consumption after cardiopulmonary bypass surgery in children: Determinants and implications. J Thorac Cardiovasc Surg. 2000;119(3):525-533. X-2, X-3a. [pmid: 10694613].
693 Lichtenstein M, Mellander M, Milsom I, et al. The influence of epidural blockade and pethidine administered during delivery on neonatal myocardial performance. Acta Obstet Gynecol Scand. 1991;70(4-5):315-9. X-2. [pmid: 1746256].
694 Lieberman BA, Bostock JF, Anderson MC. Evaluation of laparoscopic sterilization using a spring-loaded clip. J Obstet Gynaecol Br Commonw. Dec. 1974;81(12):921-32. X-2, X-3d, X-3a, X-5. [pmid: 4281444].
695 Lin CM, Li CY, Mao IF. Increased risks of term low-birth-weight infants in a petrochemical industrial city with high air pollution levels. Arch Environ Health. Dec. 2004;59(12):663-8. X-2, X-3d. [pmid: 16789475].
696 Lindow SW, Dhillon AR, Husaini SW, et al. A randomised double-blind comparison of epidural fentanyl versus fentanyl and bupivicaine for pain relief in the second stage of labour. BJOG. 1075. 111(10):1075-1080. X-3d. [pmid: 15383109].
697 Lippmann M, Appel PL, Mok MS, et al. Sequential cardiorespiratory patterns of anesthetic induction with ketamine in critically ill patients. Crit Care Med. 1983;11(9):730-734. X-2, X-3d. [pmid: 6884053].
698 Littler WA, Redman CW, Bonnar J, et al. Reduced pulmonary arterial compliance in hypertensive pregnancy. Lancet. Jun. 9. 1973;1(7815):1274-8. X-2, X-3d, X-5. [pmid: 4126072].
699 Liu PL, Warren TM, Ostheimer GW. Foetal monitoring in parturients undergoing surgery unrelated to pregnancy. Can Anaesth Soc J. 1985;32(5):525-532. X-2, X-3a. [pmid: 4041953].
700 Liu W, Loo CC, Chiu JW, et al. Analgesic efficacy of pre-operative etoricoxib for termination of pregnancy in an ambulatory centre. Singapore Med J. 2005;46(8):397-400. X-2, X-3b, X-3d. [pmid: 16049609].
701 Loan PB, Mirakhur RK, Paxton LD, et al. Comparison of desflurane and isoflurane in anaesthesia for dental surgery. Br J Anaesth. Sep. 1995;75(3):289-92. X-2, X-3a. [pmid: 7547045].
702 Loft S, Jensen V, Rorsgaard S. Influence of moderate alcohol intake on wakening plasma thiopental concentration. Acta Anaesthesiol Scand. Jun. 1983;27(3):266-9. X-2, X-3b. [pmid: 6880588].
703 Loft S, Jensen V, Rorsgaard S, et al. Influence of moderate alcohol intake on thiopental anesthesia. Acta Anaesthesiol Scand. Feb. 1982;26(1):22-6. X-1, X-2, X-3b. [pmid: 7072468].
704 Loizzi P, Carriero C, Di Gesu A, et al. Rational use of cryosurgery and cold knife conization for treatment of cervical intraepithelial neoplasia. Eur J Gynaecol Oncol. 1992;13(6):507-13. X-2, X-3d. [pmid: 1473532].
705 Long J, Yue Y. Patient controlled intravenous analgesia with tramadol for labor pain relief. Chin Med J. 1752. 116(11):1752-1755. X-3a, X-5. [pmid: 14642152].
706 Loop T, Priebe HJ. Recovery after anesthesia with remifentanil combined with propofol, desflurane, or sevoflurane for otorhinolaryngeal surgery. Anesth Analg. Jul. 2000;91(1):123-9. X-2, X-3a, X-3d. [pmid: 10866898].
707 Loughnan BA, Carli F, Romney M, et al. Randomized controlled comparison of epidural bupivacaine versus pethidine for analgesia in labour. Br J Anaesth. Jun. 2000;84(6):715-9. X-2, X-5. [pmid: 10895743].
708 Loughran PG, Moore J, Dundee JW. Maternal stress response associated with caesarean delivery under general and epidural anaesthesia. BJOG. 1986;93(9):943-949. X-2, X-3d, X-5.
709 Lowe NK. Context and process of informed consent for pharmacologic strategies in labor pain care. J Midwifery Womens Health. 2004;49(3):250-9. X-1, X-2. [pmid: 15134679].
710 Lowe SW, House W, Garrett T. Comparison of outcome of low-risk labour in an isolated general practice maternity unit and a specialist maternity hospital. J R Coll Gen Pract. Nov. 1987;37(304):484-7. X-3, X-5. [pmid: 3505637].
711 Lucas DN, Siemaszko O, Yentis SM. Maternal hypoxaemia associated with the use of Entonox in labour. Int J Obstet Anesth. 2000;9(4):270-272. X-1, X-2, X-5. [pmid: 15321078].
712 Luhmann JD, Kennedy RM, Jaffe DM, et al. Continuous-flow delivery of nitrous oxide and oxygen: A safe and cost- effective technique for inhalation analgesia and sedation of pediatric patients. Pediatr Emerg Care. 1999;15(6):388-392. X-2, X-3a, X-3d. [pmid: 10608322].
713 Lum Hee WC, Metias VF. Intramuscular ketamine in a parturient in whom pre-operative intravenous access was not possible. Br J Anaesth. 2001;86(6):891-893. X-2, X-3d. [pmid: 11573604].
714 Lutz E, Lind B, Herin P, et al. Concentrations of mercury, cadmium and lead in brain and kidney of second trimester fetuses and infants. J Trace Elem Med Biol. 1996;10(2):61-67. X-2, X-3d. [pmid: 8829128].
715 Luzardo GE, Karlnoski RA, Williams B, et al. Anesthetic management of a parturient with hyperhomocysteinemia. Anesth Analg. 1833. 106(6):1833-1836. X-1, X-2, X-3, X-5. [pmid: 18499618].
716 TJ MTB, Yao FS, Van Poznak A. Depressant effects of anesthetics on isolated human gravid and non-gravid uterine muscle. Chin Med J. 1986;99(3):235-242. X-3d. [pmid: 3095052].
717 Macario A, Scibetta WC, Navarro J, et al. Analgesia for labor pain: a cost model. Anesthesiology. Mar. 2000;92(3):841-50. X-1, X-2, X-3a, X-5. [pmid: 10719963].
718 Magno R, Karlsson K, Selstam U, et al. Anesthesia for cesarean section V: effects of enflurane anesthesia on the respiratory adaptation of the newborn in elective cesarean section. Acta Anaesthesiol Scand. 1976;20(2):147-55. X-2, X-3, X-5. [pmid: 936970].
719 Magno R, Kjellmer I, Karlsson K. Anesthesia for cesarean section III: effects of epidural analgesia on the respiratory adaptation of the newborn in elective cesarean section. Acta Anaesthesiol Scand. 1976;20(1):73-82. X-2, X-3d, X-5. [pmid: 4947].
720 Mahmoud NA, Rose DJA, Laurence AS. Desflurane or sevoflurane for gynaecological day-case anaesthesia with spontaneous respiration?. Anaesthesia. 2001;56(2):171-174. X-2, X-3a, X-3d. [pmid: 11167479].
721 Mahomedy MC, Downing JW, Jeal DE, et al. Ketamine for anaesthetic induction at Caesarean section. S Afr Med J. May. 22. 1976;50(22):846-8. X-2, X-3d, X-5. [pmid: 935971].
722 Mahomedy MC, Downing JW, Jeal DE, et al. Propanidid for anaesthetic induction at Caesarean section. S Afr Med J. Aug. 2. 1975;49(33):1358-60. X-2, X-3a, X-3d. [pmid: 239456].
723 Mahomedy MC, Downing JW, Jeal DE, et al. Anaesthetic induction for Caesarean section with propanidid. Anaesthesia. Mar. 1976;31(2):205-11. X-2, X-3d, X-5. [pmid: 7151].
724 Mahomedy MC, Downing JW, Mahomedy YH. Alfathesin for anaesthetic induction at caesarean section. S Afr Med J. Jun. 28. 1975;49(27):1095-6. X-2, X-3a, X-3d. [pmid: 239451].
725 Mahomedy YH, Downing JW, Coleman AJ, et al. Ketamine and the obstetric patient. S Afr Med J. Apr. 13. 1974;48(17):734-6. X-2, X-3d, X-5. [pmid: 4824138].
726 Mahony R, Enright F, O'Herlihy C, et al. Cerebral palsy following neonatal hypoxic seizures in singleton term infants; the influence of parity. Ir Med J. 2009;102(8). X-2, X-3d.
727 Maiz N, Valencia C, Emmanuel EE, et al. Screening for adverse pregnancy outcome by Ductus venosus Doppler at 11-13+6 weeks of gestation. Obstet Gynecol. 2008;112(3):598-605. X-3. [pmid: 18757658].
728 Major V, Rosen M, Mushin WW. Concentration of methoxyflurane for obstetric analgesia by self-administered intermittent inhalation. Br Med J. Dec. 30. 1967;4(5582):767-70. X-3a, X-5. [pmid: 6081001].
729 Malhotra N, Bhardwaj R, Vani, et al. MTP in a patient with Factor VII deficiency. J Anaesthesiol Clin Pharmacol. 2002;18(2):213-214. X-1, X-2, X-3b, X-5.
730 Mallick MS, Jado AM, Al-Bassam AR. Surgical procedures performed in the neonatal intensive care unit on critically ill neonates: feasibility and safety. Ann Saudi Med. Mar-Apr. 2008;28(2):105-8. X-2, X-3. [pmid: 18398286].
731 Maltau JM, Andersen HT, Skrede S. Obstetrical analgesia assessed by free fatty acid mobilisation. Acta Anaesthesiol Scand. 1975;19(4):245-9. X-2, X-3. [pmid: 1189878].
732 Maltau JM, Eielsen OV, Stokke KT. Effect of stress during labor on the concentration of cortisol and estriol in maternal plasma. Am J Obstet Gynecol. Jul. 15. 1979;134(6):681-4. X-2. [pmid: 463960].
733 Maltby JR, Hamilton RC, Phillips R. Comparison of flunitrazepam and thiopentone for induction of general anaesthesia. Can Anaesth Soc J. Jul. 1980;27(4):331-7. X-2, X-3. [pmid: 6105907].
734 Manber R, Schnyer RN, Allen JJB, et al. Acupuncture: A promising treatment for depression during pregnancy. J Affect Disord. 2004;83(1):89-95. X-2, X-3d. [pmid: 15546651].
735 Mankowitz E, Brock-Utne JG, Downing JW. Nitrous oxide elimination by the newborn. Anaesthesia. Nov. 1981;36(11):1014-6. X-2, X-3. [pmid: 7316119].
736 Mankowitz E, Downing JW, Brock-Utne JG, et al. Total intravenous anaesthesia using low-dose ketamine infusion for caesarean section. A comparison with a standard inhalation anaesthetic technique. S Afr Med J. Feb. 18. 1984;65(7):246-50. X-2, X-3. [pmid: 6420904].
737 Maplestone PA. Pain relief in labour. Med J Aust. Oct. 29. 1977;2(18):610-2. X-1, X-2, X-5. [pmid: 23490].
738 Marc I, Rainville P, Verreault R, et al. The use of hypnosis to improve pain management during voluntary interruption of pregnancy: an open randomized preliminary study. Contraception. Jan. 2007;75(1):52-8. X-2, X-3. [pmid: 17161125].
739 Marmor TR, Krol DM. Labor pain management in the United States: understanding patterns and the issue of choice. Am J Obstet Gynecol. May. 2002;186(5 Suppl Nature):S173-80. X-1, X-2. [pmid: 12011881].
740 Marshall CA, Jones RM, Bajorek PK, et al. Recovery characteristics using isoflurane or propofol for maintenance of anaesthesia: a double-blind controlled trial. Anaesthesia. Jun. 1992;47(6):461-6. X-2, X-3. [pmid: 1535485].
741 Martensson L, Nyberg K, Wallin G. Subcutaneous versus intracutaneous injections of sterile water for labour analgesia: A comparison of perceived pain during administration. BJOG. 1248. 107(10):1248-1251. X-2, X-3. [pmid: 11028576].
742 Martin TC, Bell P, Ogunbiyi O. Comparison of general anaesthesia and spinal anaesthesia for Caesarean section in Antigua and Barbuda. West Indian Med J. 2007;56(4):330-333. X-2, X-3. [pmid: 18198737].
743 Marx GF. Newer aspects of general anesthesia for cesarean section. N Y State J Med. May. 15. 1971;71(10):1084-6. X-1, X-2, X-3a, X-3d, X-5. [pmid: 5280683].
744 Massaro M, Di Carlo C, Gargano V, et al. Effects of the contraceptive patch and the vaginal ring on bone metabolism and bone mineral density: a prospective, controlled, randomized study. Contraception. 2010;81(3):209-214. X-2, X-3. [pmid: 20159176].
745 Massouda D, Muram D. Laparoscopic tubal ligation under local anesthesia. J Tenn Med Assoc. Feb. 1986;79(2):75-6. X-3a. [pmid: 2936930].
746 Matorras R, Tacuri C, Nieto A, et al. Fetal cardiotocography and acid-base status during cesarean section. European Journal of Obstetrics Gynecology and Reproductive Biology. 1998;80(2):161-167. X-3.
747 Matt DW, Steingold KA, Dastvan CM, et al. Effects of sera from patients given various anesthetics on preimplantation mouse embryo development in vitro. J In Vitro Fert Embryo Transf. Aug. 1991;8(4):191-7. X-2, X-3.
748 Mattia MA. Hazards in the hospital environment. Anesthesia gases and methylmethacrylate. Am J Nurs. Jan. 1983;83(1):73-7. X-1, X-2, X-5. [pmid: 6549724].
749 Mattila M, Larma I. A simple method for the administration of doxapram. Br J Clin Pharmacol. 1987;23(3):371-372. X-3. [pmid: 3567056].
750 Mauritz W, Hackl W, Winkler M, et al. Anesthesia in malignant hyperthermia susceptible patients. Acta Anaesthesiol Belg. 1990;41(2):87-94. X-2, X-3. [pmid: 1973553].
751 May AE, Fombon FN, Francis S. UK registry of high-risk obstetric anaesthesia: report on neurological disease. Int J Obstet Anesth. 2008;17(1):31-36. X-3d, X-5. [pmid: 17981456].
752 Mazze RI, Kallen B. Reproductive outcome after anesthesia and operation during pregnancy: A registry study of 5405 cases. Am J Obstet Gynecol. 1178. 161(5):1178-1185. X-3. [pmid: 2589435].
753 McCool WF, Packman J, Zwerling A. Obstetric anesthesia: Changes and choices. Journal of Midwifery and Women's Health. 2004;49(6):505-513. X-1, X-2, X-5.
754 McCormack JG. Total intravenous anaesthesia in children. Current Anaesthesia and Critical Care. 2008;19(5-6):309-314. X-2, X-3.
755 McCracken FM, Madeley RJ, McCracken JS. A comparative study between the use of analgesia/anaesthesia and of episiotomy in women delivered under consultant supervision or general practitioner care. Public Health. Jul. 1989;103(4):245-50. X-3d, X-5. [pmid: 2772125].
756 McDonald AD, McDonald JC, Armstrong B, et al. Fetal death and work in pregnancy. Br J Ind Med. Mar. 1988;45(3):148-57. X-3d, X-5. [pmid: 3348991].
757 McDonald JS, Mateo CV, Reed EC. Modified nitrous oxide or ketamine hydrochloride for cesarean section. Anesth Analg. Nov-Dec. 1972;51(6):975-85. X-2, X-3a, X-3d, X-5. [pmid: 4673939].
758 McGonnell M, Corkum P, McKinnon M, et al. Doing it right: An interdisciplinary model for the diagnosis of ADHD. J Can Acad Child Adolesc Psychiatry. 2009;18(4):283-286. X-2, X-3d. [pmid: 19881936].
759 McGranahan TT. Methoxyflurane, nitrous oxide, oxygen analgesia for delivery. Rocky Mt Med J. Jul. 1967;64(7):55-9. X-5. [pmid: 6045935].
760 McInnes RJ, Hillan E, Clark D, et al. Diamorphine for pain relief in labour : a randomised controlled trial comparing intramuscular injection and patient-controlled analgesia. BJOG. Oct. 2004;111(10):1081-9. X-3d, X-5. [pmid: 15383110].
761 McKenzie R, Wadhwa RK, Lim Uy NT. Antiemetic effectiveness of intramuscular hydroxyzine compared with intramuscular droperidol. Anesth Analg. 1981;60(11):783-788. X-3. [pmid: 7197489].
762 McKie BD. Postoperative vomiting: the effects of premedication, anaesthetic and oxytocic drugs. Med J Aust. Jun. 14. 1969;1(24):1236-8. X-2, X-3, X-5. [pmid: 5798666].
763 McLean BY, Rottman RL, Kotelko DM. Failure of multiple test doses and techniques to detect intravascular migration of an epidural catheter. Anesth Analg. 1992;74(3):454-456. X-1, X-2, X-3, X-5. [pmid: 1482429].
764 McLeod B, Boheimer N. Propofol (‘Diprivan’) infusion as main agent for day case surgery. Postgrad Med J. Suppl 3. 1985;61:105-7. X-2, X-3. [pmid: 3932992].
765 McMurray TJ, Robinson FP, Dundee JW. A method for producing constant plasma concentrations of drugs. Application to methohexitone. Br J Anaesth. 1085. 58(10):1085-1090. X-3. [pmid: 3768221].
766 McNeill JA, Alderdice FA, McMurray F. A retrospective cohort study exploring the relationship between antenatal reflexology and intranatal outcomes. Complement Ther Clin Pract. May. 2006;12(2):119-25. X-3a, X-3d, X-5. [pmid: 16648089].
767 McNeill MJ, Bennet A. Use of regional anaesthesia in a patient with acute porphyria. Br J Anaesth. 1990;64(3):371-373. X-2, X-3. [pmid: 2328186].
768 McSweeney ME, Atmadja ML, Ganesh M, et al. Outcomes of percutaneous endoscopic gastrostomy (PEG) tube placement in small infants. Gastrointestinal Endoscopy. Conference: Digestive Diease Week, DDW. 2011;73(4 SUPPL. 1). X-2, X-3d.
769 Mehta S, Burton P, Simms JS. Monitoring of occupational exposure to nitrous oxide. Can Anaesth Soc J. Sep. 1978;25(5):419-23. X-2, X-3, X-5. [pmid: 698872].
770 Meinardi JR, Van Der Schaaf W, Bom FH, et al. A new screening test for the Protein C anticoagulant Pathway: The PCP test. Fibrinolysis Proteolysis. 1999;13(SUPPL. 1):16-20. X-2, X-3.
771 Meiser A, Laubenthal H. Inhalational anaesthetics in the ICU: Theory and practice of inhalational sedation in the ICU, economics, risk-benefit. Best Pract Res Clin Anaesthesiol. 2005;19(3 SPEC. ISS):523-538. X-2, X-3. [pmid: 16013698].
772 Meneses F, Ney JG, Torres AG, et al. Erythrocyte membrane and plasma non-esterified n-3 and n-6 polyunsaturated fatty acids of pregnant and non-pregnant Brazilian adolescents. Prostaglandins Leukot Essent Fatty Acids. 2009;80(2-3):137-142. X-2, X-3d. [pmid: 19201181].
773 Messahel FM, Al-Qahtani AS. Awareness during surgery. Saudi Medical Journal. 2003;24(9):967-970. X-2, X-3. [pmid: 12973479].
774 Metcalfe NH. Military influence upon the development of anaesthesia from the American Civil War (1861-1865) to the outbreak of the First World War. Anaesthesia. 1213. 60(12):1213-1217. X-1, X-2, X-3. [pmid: 16288619].
775 Mettam I, Wee M. Update on pain relief in labour. Curr Anaesth Crit Care. 1995;6(4):206-211. X-1, X-2, X-3, X-5.
776 Mhyre JM. Anesthetic management for the morbidly obese pregnant woman. Int Anesthesiol Clin. 2007;45(1):51-70. X-1, X-2, X-3, X-5. [pmid: 17215699].
777 Michel TC, Rosenberg AL, Polley LS. EXIT to ECMO. Anesthesiology. 2002;97(1):267-268. X-1, X-2, X-3d, X-5. [pmid: 12131131].
778 Middendorf PJ, Jacobs DE, Smith KA, et al. Occupational exposure to nitrous oxide in dental operatories. Anesthesia Progress. 1986;33(2):91-97. X-2, X-3d, X-5. [pmid: 3459383].
779 Milesi C, Pidoux O, Sabatier E, et al. Nitrous oxide analgesia for intubating preterm neonates: a pilot study. Acta Paediatr. Sep. 2006;95(9):1104-8. X-2, X-3d, X-5. [pmid: 16938758].
780 Miller CL. Nitric oxide therapy for persistent pulmonary hypertension of the newborn. Neonatal Network. 1995;14(8):9-15. X-2, X-3. [pmid: 8552021].
781 Miller FL, Mann DL. Anesthetic management of a pregnant patient with the hyperimmunoglobulin E (Job's) syndrome. Anesth Analg. 1990;70(4):454-456. X-1, X-2, X-3, X-5. [pmid: 2316888].
782 Miller MC. The pregnant dental patient. J Calif Dent Assoc. Aug. 1995;23(8):63-70. X-1, X-2, X-3, X-5. [pmid: 9052016].
783 Milsom I, Forssman L, Biber B. Maternal haemodynamic changes during caesarean section: A comparison of epidural and general anaesthesia. Acta Anaesthesiol Scand. 1985;29(2):161-167. X-2, X-3. [pmid: 3976328].
784 Mimpriss TJ. Nitrous oxide versus ether anaesthesia for caesarian section. East Afr Med J. May. 1973;50(5):244-7. X-2, X-3a, X-3d, X-5. [pmid: 4747816].
785 Mischel E, Brighouse D. Does the primiparous woman have a realistic expectation of childbirth?. Int J Obstet Anesth. 1995;4(1):64-65. X-3, X-5.
786 Mitchell SZ, Freilich JD, Brant D, et al. Anesthetic management of pheochromocytoma resection during pregnancy. Anesth Analg. 1987;66(5):478-480. X-1, X-2, X-3a, X-5. [pmid: 3578858].
787 Mittal P, Romero R, Kusanovic JP, et al. CXCL6 (granulocyte chemotactic protein-2): A novel chemokine involved in the innate immune response of the amniotic cavity. Am J Reprod Immunol. 2008;60(3):246-257. X-2, X-3. [pmid: 18782286].
788 Mittal P, Romero R, Mazaki-Tovi S, et al. Fetal membranes as an interface between inflammation and metabolism: Increased Aquaporin 9 expression in the presence of spontaneous labor at term and chorioamnionitis. J Matern Fetal Neonatal Med. 1167. 22(12):1167-1175. X-3d. [pmid: 19916714].
789 Mittal P, Romero R, Tarca AL, et al. The molecular signature of an arrest of descent in human parturition. Am J Obstet Gynecol Conference. 2010;201(6 SUPPL. 1). X-2, X-3d.
790 Miyasaka K, Fujiwara H, Takata M, et al. A safe clinical system for nitric oxide inhalation therapy for pediatric patients. Pediatr Pulmonol. 1996;22(3):174-181. X-2, X-3. [pmid: 8893256].
791 Miyazu M, Sobue K, Ito H, et al. Anesthetic and airway management of general anesthesia in a patient with Meckel-Gruber syndrome. J Anesth. 2005;19(4):309-310. X-1, X-2, X-3a. [pmid: 16261468].
792 Moghbeli N, Srinivas SK, Bastek J, et al. N-terminal pro-brain natriuretic peptide as a biomarker for hypertensive disorders of pregnancy. Am J Perinatol. 2010;27(4):313-319. X-2, X-3. [pmid: 19856261].
793 Mohapatra SN, Costeloe KL, Hill DW. Blood resistivity and its implications for the calculation of cardiac output by the thoracic electrical impedance technique. Intensive Care Med. Aug. 1977;3(2):63-7. X-2, X-3. [pmid: 893775].
794 Moir DD. Anaesthesia for Caesarean section. An evaluation of a method using low concentrations of halothane and 50 per cent of oxygen. Br J Anaesth. Feb. 1970;42(2):136-42. X-2, X-3d, X-5. [pmid: 5440528].
795 Monte S, Lyons G. Peripartum management of a patient with Glanzmann's thrombasthenia using thrombelastograph. Br J Anaesth. 2002;88(5):734-738. X-2, X-3. [pmid: 12067020].
796 Moore TR, Key TC, Reisner LS, et al. Evaluation of the use of continuous lumbar epidural anesthesia for hypertensive pregnant women in labor. Am J Obstet Gynecol. 1985;152(4):404-412. X-2, X-3. [pmid: 4014333].
797 Moos DD, Prasch M, Cantral DE, et al. Are patients with obstructive sleep apnea syndrome appropriate candidates for the ambulatory surgical center?. AANA Journal. 2005;73(3):197-205. X-2, X-3. [pmid: 16010772].
798 Morgan BM, Aulakh JM, Barker JP. Anaesthesia for caesarean section. A medical audit of junior anaesthetic staff practice. Br J Anaesth. 1983;55(9):885-889. X-2, X-3. [pmid: 6615677].
799 Morishima HO, Hyman AI, Adamsons K, et al. Anesthetic management for fetal operation in the subhuman primate. Am J Obstet Gynecol. Aug. 1. 1971;110(7):926-33. X-3. [pmid: 4997672].
800 Morley-Forster PK, Reid DW, Vandeberghe H. A comparison of patient-controlled analgesia fentanyl and alfentanil for labour analgesia. Can J Anaesth. Feb. 2000;47(2):113-9. X-2, X-3a. [pmid: 10674503].
801 Morley-Forster PK, Toll M. Effect of labour room ventilation design and scavenging on ambient nitrous oxide levels. Can J Respir Ther. 1999;35(3):37-43. X-2, X-5.
802 Morrison PJ, Robinson PN, MacLeod KGA. Emergency anaesthetia in a patient with plasma cholinesterase deficiency. Anaesthesia. 1986;41(3):323-324. X-1, X-2, X-3a, X-5. [pmid: 3963340].
803 Moseley HSL, Shankar KB, Krishnan A. Flow requirements for the Bain breathing circuit during anaesthesia for Caesarean section. Can Anaesth Soc J. 1986;33(5):583-587. X-2, X-3. [pmid: 3094921].
804 Moslemi F, Rasooli S. Comparison of spinal versus general anesthesia for cesarean delivery in patients with severe preeclampsia. J Med Sci. 1044. 7(6):1044-1048. X-2, X-3.
805 Mosler KH. The dynamics of uterine muscle. Bibl Gynaecol. 1968;48:1-82. X-1, X-2, X-3, X-5. [pmid: 5690123].
806 Mueksch JN, Stevens WA. Undiagnosed myasthenia gravis masquerading as eclampsia. Int J Obstet Anesth. 2007;16(4):379-382. X-2, X-3. [pmid: 17693079].
807 Muller H, Gips H, Brahler A. Haemodynamic effects of fenoterol for labour inhibition during spinal or epidural anaesthesia. Gynecol Obstet Invest. 1985;19(2):64-72. X-2, X-3, X-5. [pmid: 3988147].
808 Muller M, Sticher J, Schindler E, et al. Effects of dopexamine and volume loading on hemodynamics and oxygenation parameters in patients undergoing pulmonary resection. Acta Anaesthesiol Scand. 2000;44(7):858-863. X-2, X-3. [pmid: 10939699].
809 Munley AJ, Railton R, Gray WM, et al. Exposure of midwives to nitrous oxide in four hospitals. Br Med J (Clin Res Ed). Oct. 25. 1986;293(6554):1063-4. X-5.
810 Murayama K, Mamiya K, Nozaki K, et al. Cesarean section in a patient with syringomyelia. Can J Anaesth. 2001;48(5):474-477. X-2, X-3d. [pmid: 11394517].
811 Murphy DF, MacGrath P, Stritch M. Postoperative analgesia in hip surgery. A controlled comparison of epidural buprenorphine with intramuscular morphine. Anaesthesia. Feb. 1984;39(2):181-3. X-2, X-3. [pmid: 6703273].
812 Murphy EJ. Intra-arterial injection of metoclopramide, midazolam, propofol and pethidine. Anaesth Intensive Care. 2002;30(3):367-369. X-2, X-3. [pmid: 12075648].
813 Mushin WW, Campbell H, Ng WS. The pattern of anaesthesia in a general hospital. Br J Anaesth. Apr. 1967;39(4):323-34. X-1, X-2, X-3a, X-5. [pmid: 6023954].
814 Mutoh S, Kobayashi M, Hirata J, et al. Studies on blood coagulation-fibrinolysis system regarding kallikrein-kinin system in the utero-placental circulation during normal pregnancy, labor and puerperium. Agents and Actions. 1992;38(SUPPL. II):320-329. X-2, X-3. [pmid: 1462839].
815 Nafiu OO, Urquhart JC. Pneumocephalus with headache complicating labour epidural analgesia: should we still be using air?. Int J Obstet Anesth. 2006;15(3):237-239. X-2, X-3a. [pmid: 16798452].
816 Nair V, Henry R. Bilateral paravertebral block: A satisfactory alternative for labour analgesia. Can J Anaesth. 2001;48(2):179-184. X-2, X-3. [pmid: 11220428].
817 Nakamura H, Tanaka O, Kaetsu H, et al. Cesarean section in a pregnant woman with primary pulmonary hypertension. Hiroshima J Anesth. 1987;23(4):315-318. X-1, X-2, X-3d, X-5.
818 Nancekievill DG. An apparatus for the delivery of 50% premixed nitrous oxide and oxygen on demand or by controlled ventilation. Anaesthesia. 1983;38(7):674-677. X-1, X-2, X-3a, X-5. [pmid: 6869743].
819 Nathan N, Peyclit A, Lahrimi A, et al. Comparison of sevoflurane and propofol for ambulatory anaesthesia in gynaecological surgery. Can J Anaesth. Dec. 1998;45(12):1148-50. X-2, X-3. [pmid: 10051930].
820 Nayebzadeh A. Exposure to exhaled nitorus oxide in hospitals post-anesthesia care units. Ind Health. 2007;45(2):334-337. X-2, X-3b, X-5. [pmid: 17485879].
821 Neff SPW, Stapelberg F, Warmington A. Excruciating perineal pain after intravenous dexamethasone. Anaesth Intensive Care. 2002;30(3):370-371. X-2, X-3. [pmid: 12075649].
822 Negovsky VA, Manevich LE, Kassil VL. Anaesthesia and intensive care in eclampsia. Resuscitation. 1974;3(3):157-63. X-3d, X-5. [pmid: 4157045].
823 Nel MR, Watts JD, Lockwood GG. An alternative method of nitrous oxide delivery into a minimal-flow circle breathing system. Anaesthesia. 1997;52(1):57-61. X-2, X-3a, X-5. [pmid: 9014546].
824 Neppert J, Witzleben-Schurholz EV, Zupanska B, et al. High incidence of maternal HLA A, B and C antibodies associated with a mild course of haemolytic disease of the newborn. Eur J Haematol. 1999;63(2):120-125. X-2, X-3. [pmid: 10480291].
825 Nesheim BI, Kinge R. Performance of acupuncture as labor analgesia in the clinical setting. Acta Obstet Gynecol Scand. 2006;85(4):441-3. X-5. [pmid: 16612706].
826 Nesheim BI, Kinge R, Berg B, et al. Acupuncture during labor can reduce the use of meperidine: A controlled clinical study. Clin J Pain. 2003;19(3):187-191. X-5. [pmid: 12792557].
827 Newman B, Lam AM. Induced hypotension for clipping of a cerebral aneurysm during pregnancy: A case report and brief review. Anesth Analg. 1986;65(6):675-678. X-1, X-2, X-3a, X-5. [pmid: 3706805].
828 Ng A, Parker J, Toogood L, et al. Does the opioid-sparing effect of rectal diclofenac following total abdominal hysterectomy benefit the patient?. Br J Anaesth. 2002;88(5):714-716. X-2, X-3a, X-3d. [pmid: 12067012].
829 Ng KH, Gurubatham AI. Awareness during caesarean section under general anaesthesia. Med J Aust. Nov. 23. 1974;2(21):774-6. X-3. [pmid: 4453236].
830 Ngan Kee WD, Khaw KS, Ma KC, et al. Randomized, double-blind comparison of different inspired oxygen fractions during general anaesthesia for Caesarean section. Br J Anaesth. 2002;89(4):556-561. X-2, X-3a. [pmid: 12393355].
831 Ngan Kee WD, Khaw KS, Ma KC, et al. Maternal and neonatal effects of remifentanil at induction of general anesthesia for cesarean delivery: A randomized, double-blind, controlled trial. Anesthesiology. 2006;104(1):14-20. X-2, X-3. [pmid: 16394684].
832 Ngan Kee WD, Khaw KS, Ma ML, et al. Postoperative analgesic requirement after cesarean section: a comparison of anesthetic induction with ketamine or thiopental. Anesth Analg. Dec. 1997;85(6):1294-8. X-2, X-3. [pmid: 9390597].
833 Nhan-Chang CL, Romero R, Kusanovic JP, et al. A role for CXCL13 (BCA-1) in pregnancy and intra-amniotic infection/inflammation. J Matern Fetal Neonatal Med. 2008;21(11):763-775. X-3. [pmid: 19031272].
834 Niinimaki M, Pouta A, Bloigu A, et al. Immediate complications after medical compared with surgical termination of pregnancy. Obstet Gynecol. 2009;114(4):795-804. X-2, X-3b. [pmid: 19888037].
835 Nijland R, Nierlich S, Jongsma HW, et al. Validation of reflectance pulse oximetry: an evaluation of a new sensor in piglets. J Clin Monit. Jan. 1997;13(1):43-9. X-2, X-3. [pmid: 9058252].
836 Nishiyama T. Saving sevoflurane and hastening emergence from anaesthesia using an anaesthetic-conserving device. Eur J Anaesthesiol. 2009;26(1):35-38. X-2, X-3a. [pmid: 19122549].
837 Nishiyama T, Hanaoka K. Case reports of anesthesia for cerebral hemorrhage during pregnancy - Cerebral aneurysm and arteriovenous malformation. Anesthesia Resuscitation. 1999;35(1):55-57. X-1, X-2, X-3a, X-5.
838 Noble J, Ogg TW. The effect of propofol (‘Diprivan’) and methohexitone on memory after day case anaesthesia. Postgrad Med J. 1985;61(SUPPL. 3):103-104. X-3.
839 Norris MC. Labour analgesia: What are the (new) options?. Can J Anaesth. 1998;45(5 II SUPPL):R138-R148. X-1, X-2, X-5. [pmid: 9599683].
840 Northwood D, Sapsford DJ, Jones JG, et al. Nitrous oxide sedation causes post-hyperventilation apnoea. Br J Anaesth. Jul. 1991;67(1):7-12. X-2, X-3d, X-5. [pmid: 1907155].
841 Nour El Din BM. Clinical evaluation of oxygen transport in patients undergoing off-pump compared to conventional coronary artery bypass grafting. Egyptian J Anaesthesia. 2004;20(4):351-355. X-2, X-3.
842 Nunn H, Lalli A, Fortune F, et al. Oral cancer screening in the Bangladeshi community of Tower Hamlets: A social model. Br J Cancer. 2009;101(SUPPL. 2):S68-S72. X-2, X-3d. [pmid: 19956167].
843 Nunn JF. Faulty cell replication: abortion, congenital abnormalities. Int Anesthesiol Clin. Winter. 1981;19(4):77-97. X-1, X-2, X-5. [pmid: 7309253].
844 Nunn JF, Chanarin I. Nitrous oxide and vitamin B12. Br J Anaesth. Nov. 1978;50(11):1089-90. X-1, X-2, X-3, X-5. [pmid: 718776].
845 Obara H, Sugiyama D, Maekawa N, et al. Plasma cortisol levels in paediatric anaesthesia. Can Anaesth Soc J. Jan. 1984;31(1):24-7. X-2. [pmid: 6692176].
846 Ochiai N, Tashiro C, Okutani R, et al. Improved oxygen delivery to the fetus during cesarean section under sevoflurane anesthesia with 100% oxygen. J Anesth. 1999;13(2):65-70. X-2, X-3d, X-5. [pmid: 14530942].
847 Odin I, Feiss P. Low flow and economics of inhalational anaesthesia. Best Pract Res Clin Anaesthesiol. 2005;19(3 SPEC. ISS):399-413. X-1, X-2, X-3. [pmid: 16013690].
848 Oduntan SA, Gool RY. Clinical trial of ketamine (CI-581): a preliminary report. Can Anaesth Soc J. Jul. 1970;17(4):411-6. X-3. [pmid: 5429682].
849 Ogasawara H, Hashimoto Y, Ishihara H, et al. Anesthetic experience of emergency Cesarean section for a patient with myotonic dystrophy. Japanese Journal of Anesthesiology. 1993;42(5):738-741. X-1, X-2, X-3. [pmid: 8515553].
850 Ogbonna B, Daw E. Epidural analgesia and the length of labour for vaginal twin delivery. J Obstet Gynaecol. 1986;6(3):166-168. X-5.
851 Ogg TW, Jennings RA, Morrison CG. Day-case anaesthesia for termination of pregnancy. Evaluation of a total intravenous anaesthetic technique. Anaesthesia. Nov. 1983;38(11):1042-6. X-3b. [pmid: 6638451].
852 O'Hara DA, Derbyshire GJ, Overdyk FJ, et al. Closed-loop infusion of atracurium with four different anesthetic techniques. Anesthesiology. 1991;74(2):258-263. X-2, X-3. [pmid: 1990902].
853 Okafor UV, Aniebue U. Anaesthesia for uterine rupture in a Nigerian teaching hospital: Maternal and fetal outcome. Int J Obstet Anesth. 2006;15(2):124-128. X-3d. [pmid: 16488135].
854 Okojie P, Cook P. Immediate and delayed complications of epidural analgesia in labour and delivery. J Obstet Gynaecol. 1999;19(4):370-372. X-3, X-5. [pmid: 15512333].
855 Olenmark M, Biber B, Dottori O, et al. Fatal iron intoxication in late pregnancy. J Toxicol Clin Toxicol. 1987;25(4):347-359. X-1, X-2, X-3. [pmid: 3669120].
856 Olkkola KT, Schwilden H. Quantitation of the interaction between atracurium and succinylcholine using closed-loop feedback control of infusion of atracurium. Anesthesiology. 1990;73(4):614-618. X-2, X-3. [pmid: 2221429].
857 Olney JW, Farber NB, Wozniak DF, et al. Environmental agents that have the potential to trigger massive apoptotic neurodegeneration in the developing brain. Environ Health Perspect. 2000;108(SUPPL. 3):383-388. X-1, X-2. [pmid: 10852832].
858 Olsson GL, Hallen B, Hambraeus-Jonzon K. Aspiration during anaesthesia: A computer-aided study of 185,358 anaesthetics. Acta Anaesthesiol Scand. 1986;30(1):84-92. X-2, X-3. [pmid: 3754372].
859 Olufolabi AJ, Charlton GA, Allen SA, et al. Use of implantable cardioverter defibrillator and anti-arrhythmic agents in a parturient. Br J Anaesth. 2002;89(4):652-655. X-1, X-2, X-3. [pmid: 12393373].
860 Olufolabi AJ, Wee MYK. Caesarean section in a patient with torsion dystonia. Br J Anaesth. 2006;96(5):611-613. X-1, X-2, X-3. [pmid: 16531441].
861 Ooi R, Joshi P, Soni N. Nitrous oxide-oxygen analgesia: The performance of the MC mask delivery system. J R Soc Med. 1992;85(9):534-536. X-2, X-3, X-5. [pmid: 1433119].
862 Orlikowski CEP, Dickinson JE, Paech MJ, et al. Intrapartum analgesia and its association with post-partum back pain and headache in nulliparous women. Aust N Z J Obstet Gynaecol. 2006;46(5):395-401. X-3d, X-5. [pmid: 16953853].
863 Orme RMLE, Grange CS, Ainsworth QP, et al. General anaesthesia using remifentanil for caesarean section in parturients with critical aortic stenosis: A series of four cases. Int J Obstet Anesth. 2004;13(3):183-187. X-1, X-2, X-3, X-5. [pmid: 15321399].
864 Ormezzano X, Francois TP, Viaud JY, et al. Aspiration pneumonitis prophylaxis in obstetric anaesthesia: Comparison of effervescent cimetidine-sodium citrate mixture and sodium citrate. Br J Anaesth. 1990;64(4):503-506. X-2, X-3d. [pmid: 2334627].
865 Ostreicher DS. Vitamin B12 supplements as protection against nitrous oxide inhalation. N Y State Dent J. Mar. 1994;60(3):47-9. X-1, X-2, X-3, X-5. [pmid: 8170632].
866 O'Sullivan G. Analgesia and anaesthesia in labour. Curr Obstet Gynaecol. 2002;12(1):8-14. X-1, X-2.
867 O'Sullivan G. Non-neuraxial analgesia in labour. South Afr J Anaesth Analg. 2008;14(1):98-100. X-1, X-2.
868 Ounsted M, Scott A, Moar V. Pain relief during childbirth and development at 4 years. J R Soc Med. 1981;74(8):629-630. X-1, X-2, X-3, X-5. [pmid: 20894370].
869 Owe KM, Nystad W, Bo K. Association between regular exercise and excessive newborn birth weight. Obstet Gynecol. 2009;114(4):770-776. X-2, X-3d. [pmid: 19888034].
870 Oyston J. Obstetrical anaesthesia in Ontario. Can J Anaesth. Dec. 1995;42(12):1117-25. X-2. [pmid: 8595688].
871 Ozkose Z, Ercan B, Unal Y, et al. Inhalation versus total intravenous anesthesia for lumbar disc herniation: Comparison of Hemodynamic Effects, Recovery Characteristics, and Cost. J Neurosurg Anesthesiol. 2001;13(4):296-302. X-2, X-3d. [pmid: 11733660].
872 Padhye SM. Rupture uterus in primigravida: Morbidity and mortality. Kathmandu Univ Med J. 2007;5(20):497-500. X-3d.
873 Padmini E, Sowmya S, Phil M. Atherosis: A major event in the pathophysiology of preeclampsia. Biomedicine. 2005;25(3-4):6-12. X-2, X-3d.
874 Paech M. Newer techniques of labor analgesia. Anesthesiol Clin North America. Mar. 2003;21(1):1-17. X-1, X-2. [pmid: 12698829].
875 Paech MJ, Scott KL, Clavisi O, et al. A prospective study of awareness and recall associated with general anaesthesia for caesarean section. Int J Obstet Anesth. 2008;17(4):298-303. X-2, X-3. [pmid: 18617387].
876 Palahniuk RJ, Cumming M. Serum cholinesterase activity following the use of methoxyflurane in obstetrics. Anesthesiology. Dec. 1977;47(6):520-2. X-1, X-2, X-3d, X-5. [pmid: 337857].
877 Palahniuk RJ, Scatliff J, Biehl D, et al. Maternal and neonatal effects of methoxyflurane, nitrous oxide and lumbar epidural anaesthesia for Caesarean section. Can Anaesth Soc J. Sep. 1977;24(5):586-96. X-2, X-3d. [pmid: 907896].
878 Palmer RB, Mautz DS, Cox K, et al. Endotracheal lidocaine administration via an esophageal combitube. J Emerg Med. 2000;18(2):153-157. X-2, X-3a, X-3d. [pmid: 10699514].
879 Palomo T, Archer T, Beninger RJ, et al. Neurodevelopment liabilities of substance abuse. Neurotox Res. 2002;4(4):267-279. X-1, X-2, X-3. [pmid: 12829418].
880 Pan PH, Moore C. Comparison of cisatracurium-induced neuromuscular blockade between immediate postpartum and nonpregnant patients. J Clin Anesth. Mar. 2001;13(2):112-7. X-2, X-3a. [pmid: 11331170].
881 Pang D, O'Sullivan G. Analgesia and anaesthesia in labour. Obstet Gynaecol Reprod Med. 2008;18(4):87-92. X-1, X-2.
882 Pang WW, Wu HS, Lin CH, et al. Metoclopramide decreases emesis but increases sedation in tramadol patient-controlled analgesia. Can J Anaesth. 1029. 49(10):1029-1033. X-2, X-3a. [pmid: 12477672].
883 Parkhouse J. Inhalation anaesthesia and analgesia. Int Anesthesiol Clin. Spring. 1967;5(1):1-20. X-1, X-2, X-3, X-5. [pmid: 5628413].
884 Parkins GE, Boamah MO. Congenital maxillomandibular syngnathia: Case report. J Craniomaxillofac Surg. 2009;37(5):276-278. X-2, X-3d. [pmid: 19231229].
885 Parpaglioni R, Capogna G, Celleno D, et al. Intraoperative fetal oxygen saturation during Caesarean section: general anaesthesia using sevoflurane with either 100% oxygen or 50% nitrous oxide in oxygen. Eur J Anaesthesiol. Feb. 2002;19(2):115-8. X-2, X-3a, X-3d, X-5. [pmid: 11999593].
886 Pathy GV, Rosen M. Prolonged block with recovery after extradural analgesia for labour. Br J Anaesth. Apr. 1975;47(4):520-2. X-2, X-3a. [pmid: 1138764].
887 Patterson KW, O'Toole DP. HELLP-syndrome: A case report with guidelines for diagnosis and management. Br J Anaesth. 1991;66(4):513-515. X-2, X-3d. [pmid: 2025482].
888 Paull J. International overview of obstetric anaesthesia. Clin Anaesthesiol. 1986;4(2):429-439. X-1, X-2, X-3, X-5.
889 Paull J, Ziccone S. Halothane, enflurane, methoxyflurane, and isolated human uterine muscle. Anaesthesia and Intensive Care. 1980;8(4):397-401. X-2, X-3, X-5. [pmid: 7457806].
890 Peat S. Providing pain relief for the surgical patient. Care of the Critically Ill. 1995;11(1):16-17. X-1, X-2, X-3d.
891 Pedersen H, Finster M. Anesthetic risk in the pregnant surgical patient. Anesthesiology. Nov. 1979;51(5):439-51. X-1, X-2, X-3d, X-5. [pmid: 40462].
892 Pedersen JE, Fernandes A, Christensen M. Halothane 2% for caesarean section. Eur J Anaesthesiol. Jul. 1992;9(4):319-24. X-2, X-3d, X-5. [pmid: 1628635].
893 Peng AT, Blancato LS, Motoyama EK. Effect of maternal hypocapnia v. eucapnia on the foetus during Caesarean section. Br J Anaesth. Nov. 1972;44(11):1173-8. X-2, X-3a, X-3d, X-5. [pmid: 4647112].
894 Perry LB. Current concepts of obstetric anesthesia and analgesia. Primary Care Clin Office Pract. 1983;10(2):269-283. X-1, X-2, X-3, X-5.
895 Pershad J, Kost S. Emergency Department Based Sedation Services. Clin Pediatr Emerg Med. 2007;8(4):253-261. X-1, X-2, X-3d.
896 Petrek JA. Breast cancer during pregnancy. Cancer. 1994;74(1 SUPPL):518-527. X-1, X-2, X-3d. [pmid: 8004627].
897 Phairas D. Wrongful birth and birth injury claims: new risks for oral surgeons. J Mass Dent Soc. Spring. 1992;41(2):82-3. X-1, X-2, X-3d, X-5. [pmid: 1624910].
898 Pharoah PO, Alberman E, Doyle P, et al. Outcome of pregnancy among women in anaesthetic practice. Lancet. Jan. 1. 1977;1(8001):34-6. X-3, X-5. [pmid: 63667].
899 Phillips AS, Mirakhur RK, Glen JB, et al. Total intravenous anaesthesia with propofol or inhalational anaesthesia with isoflurane for major abdominal surgery. Recovery characteristics and postoperative oxygenation--an international multicentre study. Anaesthesia. Nov. 1996;51(11):1055-9. X-2, X-3. [pmid: 8943601].
900 Pierce JT. Continuing education - “The Action Level”. J Occup Environ Hyg. 2005;2(6):D51-D52. X-1, X-2, X-3, X-5.
901 Piggott SE, Bogod DG, Rosen M, et al. Isoflurane with either 100% oxygen or 50% nitrous oxide in oxygen for caesarean section. Br J Anaesth. Sep. 1990;65(3):325-9. X-2, X-3a, X-3d, X-5. [pmid: 2121203].
902 Pihlajamaki KK, Kanto JH, Oksman-Caldentey KM. Pharmacokinetics and clinical effects of scopolamine in caesarean section patients. Acta Pharmacol Toxicol. 1986;59(4):259-262. X-2, X-3, X-5.
903 Pillai P, Spears FD. Intra-operative diagnosis of hypopituitarism in a patient undergoing radical nephrectomy. Anaesthesia. 2005;60(9):924-927. X-1, X-2, X-3d. [pmid: 16115255].
904 Pilon RN. Anesthesia for uncomplicated obstetric delivery. Am Fam Physician. Jan. 1974;9(1):113-20. X-1, X-2, X-5. [pmid: 4855635].
905 Pitter C, Preston R. Modern pharmacologic methods in labor analgesia. Int J Childbirth Educ. 2001;16(2):15-9. X-1, X-2, X-5.
906 Polonen P, Hippelainen M, Takala R, et al. Relationship between intra-and postoperative oxygen transport and prolonged intensive care after cardiac surgery: A prospective study. Acta Anaesthesiol Scand. 1997;41(7):810-817. X-2, X-3d. [pmid: 9265921].
907 Polvi HJ, Pirhonen JP, Erkkola RU. Nitrous oxide inhalation: effects on maternal and fetal circulations at term. Obstet Gynecol. Jun. 1996;87(6):1045-8. X-2, X-3d, X-5. [pmid: 8649688].
908 Pope WD, Halsey MJ, Hammond G, et al. Occupational Hazards of anaesthesia. A panel discussion. Can Anaesth Soc J. Mar. 1985;32(2):142-8. X-1, X-2, X-5. [pmid: 3986651].
909 Prendergast B, Scott DHT, Mankad PS. Beneficial effects of inhaled nitric oxide in hypoxaemic patients after coronary artery bypass surgery. Eur J Cardiothorac Surg. 1998;14(5):488-493. X-2, X-3d. [pmid: 9860205].
910 Prendergast J, Austin MP. Early childhood nurse-delivered cognitive behavioural counselling for post-natal depression. Australasian Psychiatry. 2001;9(3):255-259. X-2, X-3d.
911 Prichep LS, Gugino LD, John ER, et al. The Patient State Index as an indicator of the level of hypnosis under general anaesthesia. Br J Anaesth. 2004;92(3):393-399. X-2, X-3d. [pmid: 14742326].
912 Pritchard JA, Cunningham FG, Pritchard SA. The Parkland Memorial Hospital protocol for treatment of eclampsia: Evaluation of 245 cases. Am J Obstet Gynecol. 1984;148(7):951-963. X-3d, X-5. [pmid: 6711634].
913 Puhringer FK, Sparr HJ, Mitterschiffthaler G, et al. Extended duration of action of rocuronium in postpartum patients. Anesth Analg. Feb. 1997;84(2):352-4. X-2, X-3. [pmid: 9024027].
914 Puri GD, George MA, Singh H, et al. Awareness under anaesthesia due to a defective gas-loaded regulator. Anaesthesia. 1987;42(5):539-540. X-1, X-2, X-3. [pmid: 3592184].
915 Puri GD, Jayant A, Dorje M, et al. Propofol-fentanyl anaesthesia at high altitude: Anaesthetic requirements and haemodynamic variations when compared with anaesthesia at low altitude. Acta Anaesthesiol Scand. 2008;52(3):427-431. X-2, X-3d. [pmid: 18269393].
916 Qiu J, Zhang A, Tuo D. Clinical observation on N2O inhalation used in the course of artificial abortion. [Chinese]. Chin Nurs Res. 2004;18(2B):326-7. X-2, X-3b.
917 Qublan HS, Merhej A, Dabbas MA, et al. Spinal versus general anesthesia for elective cesarean delivery: A prospective comparative study. Clin Exp Obstet Gynecol. 2001;28(4):246-248. X-2, X-3d. [pmid: 11838750].
918 Qvist N, Storm K. Cimethidine pre-anesthetic. A prophylatic method against Mendelson's syndrome in cesarean section. Acta Obstet Gynecol Scand. 1983;62(2):157-159. X-2, X-3. [pmid: 6346782].
919 Rachootin P, Olsen J. The risk of infertility and delayed conception associated with exposures in the Danish workplace. J Occup Med. May. 1983;25(5):394-402. X-3a, X-5. [pmid: 6854429].
920 Radomsky NA. Family practice obstetrics in a community hospital. Canadian Family Physician. 1995;41(APR):617-624. X-2, X-3d. [pmid: 7787492].
921 Raeder JC. Propofol anaesthesia versus paracervical blockade with alfentanil and midazolam sedation for outpatient abortion. Acta Anaesthesiol Scand. Jan. 1992;36(1):31-7. X-2, X-3b, X-3d. [pmid: 1539476].
922 Raeder JC, van der Linden J, Breivik H. Premedication for day-case surgery: double-blind comparison of ketobemidone + dimethylaminodiphenylbuten (A-29) and morphine + scopolamine. Acta Anaesthesiol Scand. Oct. 1986;30(7):502-6. X-2, X-3b, X-3d. [pmid: 3811793].
923 Rahimi M, Makarem J. Effects of diclofenac epolamine patch on postoperative sore throat in parturients after cesarean delivery under endotracheal general anesthesia. Acta Anaesthesiol Taiwan. 2009;47(1):17-21. X-2, X-3d. [pmid: 19318295].
924 Rainaldi MP, Busi T, Melloni C, et al. Pharmacokinetics and placental transmission of fazadinium in elective caesarean sections. Acta Anaesthesiol Scand. 1984;28(2):222-225. X-2, X-3. [pmid: 6145279].
925 Rajah A, Powell H, Morgan M. Eltanolone for induction of anaesthesia and to supplement nitrous oxide for minor gynaecological surgery. Anaesthesia. Nov. 1993;48(11):951-4. X-2, X-3d. [pmid: 8250188].
926 Rajan L. Perceptions of pain and pain relief in labour: the gulf between experience and observation. Midwifery. Sep. 1993;9(3):136-45. X-5. [pmid: 8412834].
927 Rajan L. The impact of obstetric procedures and analgesia/anaesthesia during labour and delivery on breast feeding. Midwifery. Jun. 1994;10(2):87-103. X-2, X-5. [pmid: 8057961].
928 Rajhans GS, Brown DA, Whaley D, et al. Hygiene aspects of occupational exposure to waste anaesthetic gases in Ontario hospitals. Ann Occup Hyg. 1989;33(1):27-45. X-2, X-3, X-5. [pmid: 2705694].
929 Ramanathan J, Coleman P, Sibai B. Anesthetic modification of hemodynamic and neuroendocrine stress responses to cesarean delivery in women with severe preeclampsia. Anesth Analg. 1991;73(6):772-779. X-2, X-3d. [pmid: 1659254].
930 Ramanathan S, Sheth R, Turndorf H. Anesthesia for cesarean section in patients with genital herpes infections: A retrospective study. Anesthesiology. 1986;64(6):807-809. X-3. [pmid: 3717647].
931 Rampton AJ, Mallaiah S, Garrett CPO. Increased ventilation requirements during obstetric general anaesthesia. Br J Anaesth. 1988;61(6):730-737. X-2, X-3a, X-5. [pmid: 3145001].
932 Ranbhushan, Gupta S, Kohli GB. Drug error due to similarity between the ampoules. J Anaesthesiol Clin Pharmacol. 2003;19(3):319-321. X-1, X-2, X-3, X-5.
933 Rawal N, Schollin J, Wesstrom G. Epidural versus combined spinal epidural block for cesarean section. Acta Anaesthesiol Scand. Jan. 1988;32(1):61-6. X-2, X-3d. [pmid: 3278500].
934 Raymond JA. Respiratory performance and the Mid-O-Gas. N Z Med J. Feb. 1971;73(465):80-2. X-2, X-3, X-5. [pmid: 5279920].
935 Reber A, Bobbia SA, Hammer J, et al. Effect of airway opening manoeuvres on thoraco-abdominal asynchrony in anaesthetized children. Eur Respir J. 1239. 17(6):1239-1243. X-2, X-3d. [pmid: 11491171].
936 Redfern N, Stafford MA, Brooker J, et al. Incremental propofol for minor gynaecological procedures. Postgrad Med J. 1985;61(SUPPL. 3):127-128. X-3.
937 Reed PN, Jago RH. Comparison of the frequency of muscle pain associated with suxamethonium in pre- and post-ovulatory women and in those taking a combined oral contraceptive pill. Br J Anaesth. May. 1983;55(5):377-80. X-2, X-3d. [pmid: 6849723].
938 Reeve BK, Cook DJ, Babineau D, et al. Prophylactic Diclectin reduces the incidence of postoperative vomiting. Can J Anaesth. 2005;52(1):55-61. X-2, X-3d. [pmid: 15625257].
939 Regaert P, Noorduin H. General anesthesia with etomidate, alfentanil and droperidol for caesarean section. Acta Anaesthesiol Belg. Sep. 1984;35(3):193-200. X-2, X-3d. [pmid: 6441435].
940 Reid DH. Diffusion anoxia at birth. Lancet. Oct. 5. 1968;2(7571):757-8. X-2. [pmid: 4175554].
941 Reinhart K, Foehring U, Kersting T, et al. Effects of thoracic epidural anesthesia on systemic hemodynamic function and systemic oxygen supply-demand relationship. Anesth Analg. 1989;69(3):360-369. X-2, X-3d. [pmid: 2774232].
942 Reisner LS. Anesthesia for cesarean section. Clin Obstet Gynecol. Jun. 1980;23(2):517-23. X-1, X-2, X-3, X-5. [pmid: 7398162].
943 Reynolds AC, Abram SE, Worthington D. Anesthetic management of a patient with spinal muscular atrophy. Case report and review of the literature. Anesthesiology Review. 1982;9(11-12):24-26. X-1, X-2, X-3, X-5.
944 Reynolds F. Pain relief in labour. Br J Obstet Gynaecol. Nov. 1993;100(11):979-83. X-1, X-2, X-5. [pmid: 8251468].
945 Reynolds F. Analgesia for labour. Prescribers' Journal. 1998;38(1):26-31. X-1, X-2, X-5.
946 Reynolds F, Crowhurst JA. Opioids in labour - No analgesic effect. Lancet. 9044. 349(9044):4-5. X-1, X-2, X-3, X-5. [pmid: 8988111].
947 Reynolds F, Sharma SK, Seed PT. Analgesia in labour and fetal acid-base balance: A meta-analysis comparing epidural with systemic opioid analgesia. BJOG. 1344. 109(12):1344-1353. X-1, X-2, X-3d. [pmid: 12504969].
948 Reza FM, Zahra F, Esmaeel F, et al. Preemptive analgesic effect of ketamine in patients undergoing elective cesarean section. Clin J Pain. Mar-Apr. 2010;26(3):223-6. X-2, X-3. [pmid: 20173436].
949 Rezaeipour A, Idenloo F, Khakbazan Z, et al. The effects of Entonox on implication of painless labor and delivery satisfaction rate among pregnant women. [Farsi]. Hayat. 2007;13(4):92. X-4.
950 Rice SA. Behavioural toxicity of inhalation anaesthetic agents. Clin Anaesthesiol. 1983;1(2):507-519. X-1, X-2, X-3, X-5.
951 Richards KA, Stasko T. Dermatologic surgery and the pregnant patient. Dermatol Surg. 2002;28(3):248-256. X-1, X-2, X-3d. [pmid: 11896778].
952 Rising S, Dodgson MS, Steen PA. Isoflurane v fentanyl for outpatient laparoscopy. Acta Anaesthesiol Scand. Apr. 1985;29(3):251-5. X-2, X-3d. [pmid: 3158146].
953 Riss PA, Bieglmayer C. Obstetric analgesia and immunoreactive endorphin peptides in maternal plasma during labor. Gynecol Obstet Invest. 1984;17(3):127-130. X-3. [pmid: 6706247].
954 Ritchie RG, Ernst EA, Pate BL, et al. Automatic control of anesthetic delivery and ventilation during surgery. Med Prog Technol. 1990;16(1-2):61-67. X-2, X-3, X-5. [pmid: 2138698].
955 Robert-Gnansia E, Saillenfait AM. Physical and chemical factors in the home and workplace before and during pregnancy. Community Genet. 2002;5(1):78-85. X-1, X-2, X-3. [pmid: 14960903].
956 Roberts SW, Leveno KJ, Sidawi JE, et al. Fetal acidemia associated with regional anesthesia for elective cesarean delivery. Obstet Gynecol. 1995;85(1):79-83. X-2, X-3a, X-3d. [pmid: 7800330].
957 Robertson A. Nitrous oxide -- no laughing matter. MIDIRS Midwifery Digest. 2006;16(1):123-8. X-1, X-2.
958 Robertson CH, Lund RR, Soroosh F, et al. Percutaneous fetal ventriculography. A new technic and case report. Obstet Gynecol. Dec. 1969;34(6):841-6. X-1, X-2, X-3d, X-5. [pmid: 5308428].
959 Robinson J. Consumer comments Drugged babies: drugged adults?. Br J Midwifery. 1998;6(1). X-1, X-2, X-5.
960 Robinson JO, Rosen M, Evans JM. Maternal opinion about analgesia for labour. A controlled trial between epidural block and intramuscular pethidine combined with inhalation. Anaesthesia. 1980;35(12):1173-1181. X-5. [pmid: 7006441].
961 Rocke DA, Rout CC, Russell HD, et al. The labour ward analgesic service at King Edward VIII Hospital, Durban. S Afr Med J. Jan. 1993;83(1):32-3. X-3, X-5. [pmid: 8424198].
962 Rodgers L, Dangel-Palmer MC, Berner N. Acute circulatory and respiratory collapse in obstetrical patients: a case report and review of the literature. AANA Journal. 2000;68(5):444-50. X-1, X-2, X-3d. [pmid: 11759129].
963 Rodier PM. Differential structural effects of three behavioral teratogens. Dev Toxicol Environ Sci. 1983;11:53-60. X-1, X-2, X-3, X-5. [pmid: 6203696].
964 Roeleveld N. Pregnant operating room personnel: risks and prevention. Acta Anaesthesiol Belg. 2002;53(4):327-9. X-2, X-3, X-5. [pmid: 12503360].
965 Rooks JP. Nitrous oxide for pain in labor--why not in the United States?. Birth. Mar. 2007;34(1):3-5. X-1, X-5. [pmid: 17324171].
966 Rooks JP. Use of nitrous oxide in midwifery practice -- complementary, synergistic, and needed in the United States. J Midwifery Womens Health. 2007;52(3):186-9. X-1, X-2. [pmid: 17467584].
967 Rooth G. Maternal hypoxaemia during labor. Padiatr Padol. 1982;17(2):231-6. X-1, X-2, X-3. [pmid: 6808439].
968 Rosen MA. Management of anesthesia for the pregnant surgical patient. Anesthesiology. 1159. 91(4):1159-1163. X-1, X-2, X-5. [pmid: 10519516].
969 Rosen MA. Papillary thyroid cancer in pregnancy: Therapeutic consideration of thyroid surgery under local anaesthesia. Asian J Surg. 2001;24(3):314-315. X-1, X-2, X-3a, X-5.
970 Rosen MA. Nitrous oxide for relief of labor pain: A systematic review. Am J Obstet Gynecol. 2002;186(5 SUPPL):S110-S126. X-1, X-2. [pmid: 12011877].
971 Rosen MA, Roizen MF, Eger EI 2nd, et al. The effect of nitrous oxide on in vitro fertilization success rate. Anesthesiology. Jul. 1987;67(1):42-4. X-2, X-3d. [pmid: 3605734].
972 Rosenthal J, Bolotin E, Shakhnovits M, et al. High-dose therapy with hematopoietic stem cell rescue in patients with poor prognosis Ewing family tumors. Bone Marrow Transplant. 2008;42(5):311-318. X-2, X-3d. [pmid: 18587438].
973 Ross A. Maternal satisfaction with labour analgesia. Baillieres Clin Obstet Gynaecol. Sep. 1998;12(3):499-512. X-1, X-2, X-5. [pmid: 10023435].
974 Ross JA, Tunstall ME. Simulated use of premixed 0.25% isoflurane in 50% nitrous oxide and 50% oxygen. Br J Anaesth. Dec. 2002;89(6):820-4. X-2, X-3. [pmid: 12453923].
975 Rowland AS, Baird DD, Shore DL, et al. Ethylene oxide exposure may increase the risk of spontaneous abortion, preterm birth, and postterm birth. Epidemiology. Jul. 1996;7(4):363-8. X-2, X-3a, X-3d, X-5. [pmid: 8793361].
976 Rowland AS, Baird DD, Shore DL, et al. Nitrous oxide and spontaneous abortion in female dental assistants. Am J Epidemiol. Mar. 15. 1995;141(6):531-8. X-2, X-3, X-5. [pmid: 7900720].
977 Rowland AS, Baird DD, Weinberg CR, et al. Reduced fertility among women employed as dental assistants exposed to high levels of nitrous oxide. N Engl J Med. Oct. 1. 1992;327(14):993-7. X-2, X-3d, X-5. [pmid: 1298226].
978 Rubin RR, Peyrot M, Chen X, et al. Patient-reported outcomes from a 16-week open-label, multicenter study of insulin pump therapy in patients with type 2 diabetes mellitus. Diabetes Technol Ther. 2010;12(11):901-906. X-2, X-3d. [pmid: 20879963].
979 Rungreungvanich M, Thienthong S, Charuluxananan S, et al. Predictors of intra-operative recall of awareness: Thai anesthesia incidents study (THAI Study): A case-control study. J Med Assoc Thai. 1551. 90(8):1551-1557. X-2, X-3a, X-3d. [pmid: 17926984].
980 Russell IF. Effect of posture during the induction of subarachnoid analgesia for Caesarean section. Right v. left lateral. Br J Anaesth. 1987;59(3):342-346. X-2, X-3d. [pmid: 3828184].
981 Russell JT. Awareness under anesthesia. Anaesthesia. Jul. 1969;24(3):494-5. X-1, X-2, X-3d, X-5. [pmid: 5791072].
982 Russell R, Groves P, Taub N, et al. Assessing long term backache after childbirth. BMJ. 6888. 306(6888):1299-1303. X-2, X-3, X-5.
983 Ryhanen P, Jouppila R, Lanning M. Natural killer cell activity after elective Cesarean section under general and epidural anesthesia in healthy parturients and their newborns. Gynecol Obstet Invest. 1985;19(3):139-142. X-2, X-3d. [pmid: 4018672].
984 Sahajananda H, Meneges J. Anaesthesia for a child with Walker-Warburg syndrome. Paediatric Anaesthesia. 2003;13(7):624-628. X-1, X-2, X-3. [pmid: 12950865].
985 Sakai T, Vallejo MC, Shannon KT. A parturient with neurofibromatosis type 2: Anesthetic and obstetric considerations for delivery. Int J Obstet Anesth. 2005;14(4):332-335. X-1, X-2, X-3d. [pmid: 16140520].
986 Saleh AM, Abotalib ZM, Al-Ibrahim AA, et al. Comparison of maternal and fetal outcomes, in epileptic and non-epileptic women. Saudi Med J. 2008;29(2):261-266. X-3d. [pmid: 18246238].
987 Samieh-Tucker A, Rupasinghe M. Anaesthesia for caesarean section in a patient with acute generalised pustular psoriasis. Int J Obstet Anesth. 2007;16(4):375-378. X-2, X-3d. [pmid: 17643975].
988 Sampson IH, Plosker H, Cohen M, et al. Comparison of propofol and thiamylal for induction and maintenance of anaesthesia for outpatient surgery. Br J Anaesth. Dec. 1988;61(6):707-11. X-2, X-3b. [pmid: 3264709].
989 Sanci M, Dikis C, Inan S, et al. Distributions of estrogen and progesterone receptors and Ki-67 on human leiomyomas, cellular leiomyomas and leiomyosarcomas. IUBMB Life. Conference: 3rd International Congress of Molecular Medicine of the Turkish Society of Molecular Medicine. Istanbul Turkey. Conference Start. 2009. 61(3). X-2, X-3d.
990 Sanders J, Campbell R, Peters TJ. Effectiveness of pain relief during perineal suturing. BJOG. Sep. 2002;109(9):1066-8. X-2, X-3a, X-3d. [pmid: 12269684].
991 Sanders RD, Weimann J, Maze M. Biologic effects of nitrous oxide: a mechanistic and toxicologic review. Anesthesiology. Oct. 2008;109(4):707-22. X-1, X-2. [pmid: 18813051].
992 Sanders RS, Sinclair ME, Sear JW. Alfentanil in short procedures. A comparison with halothane using etomidate or methohexitone for induction of anaesthesia. Anaesthesia. Dec. 1984;39(12):1202-6. X-2, X-3b. [pmid: 6440446].
993 Sanderson JH, Blades JF. Multicentre study of propofol in day case surgery. Anaesthesia. Mar. Suppl. 1988;43:70-3. X-2, X-3d. [pmid: 3259103].
994 Sandhya, Yaddanapudi LN. Evaluation of two antiemetic agents during outpatient gynaecological surgery. Singapore Med J. Jun. 1994;35(3):271-3. X-2, X-3b. [pmid: 7997902].
995 Sands TD, Pynn BR. Management considerations for the pregnant or nursing emergency patient. Ont Dent. Jul-Aug. 1998;75(6):17-9. X-1, X-2, X-3d. [pmid: 10518900].
996 Saravanakumar K, Rao SG, Cooper GM. Obesity and obstetric anaesthesia. Anaesthesia. 2006;61(1):36-48. X-1, X-2. [pmid: 16409341].
997 Sass-Kortsak AM, Purdham JT, Bozek PR, et al. Exposure of hospital operating room personnel to potentially harmful environmental agents. American Industrial Hygiene Association Journal. 1992;53(3):203-209. X-3, X-5. [pmid: 1642173].
998 Sato N, Shirotani T, Miyawaki I, et al. Retrospective assessment of anesthesia, cesarean section and toxemia of pregnancy. Hiroshima J Anesth. 1992;28(4):339-343. X-2, X-3, X-5.
999 Sato T, Hashiguchi A, Mitsuse T. Anesthesia for cesarean delivery in a pregnant woman with acute hepatic failure. Anesth Analg. 1441. 91(6):1441-1442. X-1, X-2, X-3a, X-5. [pmid: 11093996].
1000 Saunders JF. Nitrous oxide. RDH. Oct. 26. 1988;8(8):22-7. X-1, X-2, X-3, X-5. [pmid: 3268945].
1001 Scavee C, Jais P, Hsu LF, et al. Prospective randomised comparison of irrigated-tip and large-tip catheter ablation of cavotricuspid isthmus-dependent atrial flutter. European Heart Journal. 2004;25(11):963-969. X-2, X-3. [pmid: 15172468].
1002 Schapera A. An anesthesia mask gas-scavenging system. J Occup Med. 1138. 35(11):1138-1141. X-2, X-3d, X-5. [pmid: 8295039].
1003 Schindler AW, Scheeren TWL, Picker O, et al. Accuracy of feedback-controlled oxygen delivery into a closed anaesthesia circuit for measurement of oxygen consumption. Br J Anaesth. 2003;90(3):281-290. X-2, X-3d. [pmid: 12594137].
1004 Schrading W, Kaplan R, Stewart R. Effect of scavenging on ambient levels of nitrous oxide in ambulances. Ann Emerg Med. 1990;19(8):910-913. X-2, X-3, X-5. [pmid: 2372175].
1005 Schug SA, MacIntyre P, Power I, et al. The scientific evidence in acute pain management. Acute Pain. 2005;7(4):161-165. X-1, X-2, X-3, X-5.
1006 Schulpis KH, Margeli A, Akalestos A, et al. Effects of mode of delivery on maternal-neonatal plasma antioxidant status and on protein S100B serum concentrations. Scand J Clin Lab Invest. 2006;66(8):733-742. X-3. [pmid: 17101566].
1007 Schultetus RR, Hill CR, Dharamraj CM. Wakefulness during cesarean section after anesthetic induction with ketamine, thiopental, or ketamine and thiopental combined. Anesth Analg. 1986;65(7):723-728. X-2, X-3. [pmid: 3717612].
1008 Schultetus RR, Paulus DA, Spohr GL. Haemodynamic effects of ketamine and thiopentone during anaesthetic induction for Caesarean section. Can Anaesth Soc J. 1985;32(6):592-596. X-3. [pmid: 3907790].
1009 Schumann D. Nitrous oxide anaesthesia: risks to health personnel. Int Nurs Rev. 1990;37(1):214-7. X-1, X-2. [pmid: 2179153].
1010 Schwartz DA, Moriarty KP, Tashjian DB, et al. Anesthetic management of the exit (Ex Utero intrapartum treatment) procedure. J Clin Anesth. 2001;13(5):387-391. X-2, X-3d. [pmid: 11498323].
1011 Schwender D, Madler C, Klasing S, et al. Mid-latency auditory evoked potentials and wakefulness during caesarean section. Eur J Anaesthesiol. Mar. 1995;12(2):171-9. X-2, X-3. [pmid: 7781637].
1012 Schwilden H, Stoeckel H. Closed-loop feedback controlled administration of alfentanil during alfentanil-nitrous oxide anaesthesia. Br J Anaesth. 1993;70(4):389-393. X-2, X-3a, X-5. [pmid: 8499195].
1013 Scotland GS, McNamee P, Cheyne H, et al. Women's Preferences for Aspects of Labor Management: Results from a Discrete Choice Experiment. Birth. 2011;38(1):36-46. X-2, X-5. [pmid: 21332773].
1014 Scott WA, Whitwam JG, Wilkinson RT. Choice reaction time. A method of measuring postoperative psychomotor performance decrements. Anaesthesia. Dec. 1983;38(12):1162-8. X-2, X-3. [pmid: 6660455].
1015 Sear JW, Cooper GM, Kumar V. The effect of age on recovery. A comparison of the kinetics of thiopentone and Althesin. Anaesthesia. Dec. 1983;38(12):1158-61. X-2, X-3. [pmid: 6660454].
1016 Sear JW, Walters FJ, Wilkins DG, et al. Etomidate by infusion for neuroanaesthesia. Kinetic and dynamic interactions with nitrous oxide. Anaesthesia. Jan. 1984;39(1):12-8. X-2, X-3. [pmid: 6696212].
1017 Secher NJ, Arnsbo P, Andersen LH, et al. Measurements of cardiac stroke volume in various body positions in pregnancy and during Caesarean section: a comparison between thermodilution and impedance cardiography. Scand J Clin Lab Invest. Oct. 1979;39(6):569-76. X-2, X-3. [pmid: 531485].
1018 Sechzer PH. Dreams with low-dose ketamine in obstetrical patients. Curr Ther Res Clin Exp. 1984;35(3):396-404. X-3a, X-5.
1019 Sedaghat N, Ellwood D, Shadbolt B, et al. The effect of mode of delivery and anaesthesia on neonatal blood pressure. Aust N Z J Obstet Gynaecol. 2008;48(2):172-178. X-5, No way to pull out N20 data. [pmid: 18366491].
1020 Segatto A, Vincenti E, Valenti S, et al. TIVA with propofol vs thiopental-nitrous oxide anaesthesia for uterine cerclage (A prospective randomized clinical study on 200 pregnant patients). Acta Anaesthesiol Ital. 1993;44(SUPPL. 1):59-65. X-2, X-3, X-5.
1021 Sen A, Rudra A, Sarkar SK, et al. Intrathecal midazolam for postoperative pain relief in caesarean section delivery. J Indian Med Assoc. 2001;99(12):683-686. X-2, X-3a. [pmid: 12022217].
1022 Sener EB, Guldogus F, Karakaya D, et al. Comparison of neonatal effects of epidural and general anesthesia for cesarean section. Gynecol Obstet Invest. 2003;55(1):41-5. X-2, X-3. [pmid: 12624551].
1023 Sener EB, Kocamanoglu S, Ustun E, et al. Anesthetic management for cesarean delivery in a woman with Gilles de la Tourette's syndrome. Int J Obstet Anesth. 2006;15(2):163-165. X-2, X-3. [pmid: 16434179].
1024 Sengupta P, Nielsen M. The effect of labour and epidural analgesia on pain threshold. Anaesthesia. 1984;39(10):982-986. X-3d, X-5. [pmid: 6496913].
1025 Settergren G, Ohqvist G, Ekestrom S. Sequential myocardial depressant and non-depressant anaesthesia for coronary artery surgery. Acta Anaesthesiol Scand. 1985;29(1):26-31. X-2, X-3. [pmid: 3872002].
1026 Sevarino FB, Paige D, Sinatra RS, et al. Postoperative analgesia with parenteral opioids: Does continuous delivery utilizing a transdermal opioid preparation affect analgesic efficacy or patient safety?. J Clin Anesth. 1997;9(3):173-178. X-2, X-3. [pmid: 9172021].
1027 Seward EH. Obstetric analgesia; a new machine for the self-administration of nitrous oxide oxygen. Proc R Soc Med. Sep. 1949;42(9):745. X-1, X-2, X-5. [pmid: 18142828].
1028 Shankar KA, Puri R, Dutta PK. Anaesthetic management of a case of early pregnancy with systemic sclerosis. Med J Armed Forces India. 2005;61(3):287-288. X-1, X-2, X-3d, X-5.
1029 Shankar KB, Posner M, Moore FD Jr, et al. Laryngeal nerve monitoring during thyroid surgery in pregnancy. J Clin Anesth. 2005;17(5):369-371. X-2, X-3. [pmid: 16102689].
1030 Shapira SC, Chrubasik S, Hoffmann A, et al. Use of alfentanil for in vitro fertilization oocyte retrieval. J Clin Anesth. Jun. 1996;8(4):282-5. X-2, X-3. [pmid: 8695130].
1031 Shapira SC, Weiss YS. Analgesia for labour. Curr Opin Anaesthesiol. 1996;9(3):207-210. X-1, X-2.
1032 Sharifi N, Sadeghian MH, Ayatollahi H, et al. Validity of P57kip2 immunohistochemical marker in differential diagnosis of molar pregnancy. J Turkish German Gynecol Assoc Artemis. 2009;10(1):39-42. X-2, X-3.
1033 Sharley CB. The value of physiotherapy in obstetrics. Med J Aust. Jun. 6. 1970;1(23):1159-62. X-3. [pmid: 5431755].
1034 Sharma RM, Vardhan S. Flash pulmonary oedema following prostodin in pregnancy. Med J Armed Forces India. 2008;64(4):375-376. X-1, X-2, X-3, X-5.
1035 Sharma SK, Vera RL, Stegall WC, et al. Management of a postpartum coagulopathy using thrombelastography. J Clin Anesth. 1997;9(3):243-247. X-2, X-3. [pmid: 9172035].
1036 Sharp LM, Levy DM. Rapid sequence induction in obstetrics revisited. Curr Opin Anesthesiol. 2009;22(3):357-61. X-1, X-2, X-3.
1037 Shaw DB, Wheeler AS. Anesthesia for obstetric emergencies. Clin Obstet Gynecol. Mar. 1984;27(1):112-24. X-1, X-2, X-3, X-5. [pmid: 6705305].
1038 Shek KL, Dietz HP. Intrapartum risk factors for levator trauma. BJOG. 1485. 117(12):1485-1492. X-2, X-3. [pmid: 20735379].
1039 Sher AM, Braude BM, Cleaton-Jones PE. Nitrous oxide sedation in dentistry. A comparison between Rotameter settings, pharyngeal concentrations and blood levels of nitrous oxide. Anaesthesia. 1984;39(3):236-239. X-2, X-3. [pmid: 6703290].
1040 Sherke RR, Rao MS. Anaesthetic management of splenectomy in Evan's syndrome during pregnancy with pregnancy induced hypertension. J Postgrad Med. 2001;47(3):196-198. X-2, X-3. [pmid: 11832624].
1041 Shetty A, Danielian P, Templeton A. A comparison of oral and vaginal misoprostol tablets in induction of labour at term. BJOG. 2001;108(3):238-243. X-3d. [pmid: 11281461].
1042 Shira RB, Greenfield W, Karpinski JF. Citanest Forte--its use in oral surgery. Oral Surg Oral Med Oral Pathol. Feb. 1975;39(2):177-83. X-2, X-3. [pmid: 1054444].
1043 Shokry M, Elsedfy GO, Bassiouny MM, et al. Effects of antenatal magnesium sulfate therapy on cerebral and systemic hemodynamics in preterm newborns. Acta Obstet Gynecol Scand. 2010;89(6):801-806. X-2, X-3. [pmid: 20504082].
1044 Short SM, Rutherfoord CF, Sebel PS. A comparison between isoflurane and alfentanil supplemented anaesthesia for short procedures. Anaesthesia. Dec. 1985;40(12):1160-4. X-2, X-3. [pmid: 3936374].
1045 Shortridge-McCauley LA. Reproductive hazards: an overview of exposures to health care workers. AAOHN Journal. 1995;43(12):614-21. X-1, X-2, X-5. [pmid: 8694964].
1046 Shrestha SM, Costello MF, Sjoblom P, et al. Power doppler ultrasound assessment of follicular vascularity in the early follicular phase and its relationship with outcome of in vitro fertilization. J Assist Reprod Genet. 2006;23(4):161-169. X-2, X-3d. [pmid: 16758346].
1047 Shuhaiber S, Koren G. Occupational exposure to inhaled anesthetic. Is it a concern for pregnant women?. Can Fam Physician. Dec. 2000;(46):2391-2. X-1, X-2, X-3. [pmid: 11153403].
1048 Sia AT, Lim Y, Ocampo CE. Computer-integrated patient-controlled epidural analgesia: A preliminary study on a novel approach of providing pain relief in labour. Singapore Med J. 2006;47(11):951-956. X-3, X-5. [pmid: 17075662].
1049 Siafarikas A, Piazena H, Feister U, et al. Randomised controlled trial analysing supplementation with 250 versus 500 units of vitamin D3, sun exposure and surrounding factors in breastfed infants. Arch Dis Child. 2011;96(1):91-95. X-2, X-3. [pmid: 20861405].
1050 Sibai BM, Spinnato JA, Watson DL, Eclampsia IV. Neurological findings and future outcome. Am J Obstet Gynecol. 1985;152(2):184-192. X-2, X-3d. [pmid: 4003467].
1051 Sidhu MS, Cullen BF. Low-dose enflurane does not increase blood loss during therapeutic abortion. Anesthesiology. Aug. 1982;57(2):127-9. X-1, X-2, X-3a, X-3b, X-5. [pmid: 7091736].
1052 Simmons PD. Genital warts. International Journal of Dermatology. 1983;22(7):410-414. X-1, X-2, X-3. [pmid: 6629603].
1053 Simpson PJ, Radford SG, Lockyer JA, et al. Some factors predisposing to althesin hypersensitivity. Br J Anaesth. 1131. 54(10). X-2, X-3, X-5.
1054 Simpson PJ, Radford SG, Lockyer JA, et al. Some predisposing factors to hypersensitivity reactions following first exposure to Althesin. Anaesthesia. 1985;40(5):420-423. X-2, X-3. [pmid: 4014616].
1055 Sinatra RS, Philip BK, Naulty JS, et al. Prolonged neuromuscular blockade with vecuronium in a patient treated with magnesium sulfate. Anesth Analg. 1220. 64(12):1220-1222. X-1, X-2, X-3d, X-5. [pmid: 2865911].
1056 Sindram-Trujillo AP, Scherjon SA, Miert PPVHV, et al. Comparison of decidual leukocytes following spontaneous vaginal delivery and elective cesarean section in uncomplicated human term pregnancy. J Reprod Immunol. 2004;62(1-2):125-137. X-2, X-3. [pmid: 15288188].
1057 Singh SI, Brooks C, Dobkowski W. General anesthesia using remifentanil for Cesarean delivery in a parturient with Marfan's syndrome. Can J Anaesth. 2008;55(8):526-531. X-2, X-3. [pmid: 18676388].
1058 Sivan E, Ben-Baruch G. Cryotherapy - Preliminary treatment of genital condylomata. Isr J Med Sci. 1992;28(6):365-367. X-3. [pmid: 1607274].
1059 Sivevski A. Effects of varying doses of plain bupivacaine with fentanyl in patients undergoing cesarean section: Haemodinamics and neonatal outcome. Anaesthes Intensive Care. 2009;39(5):30-35. X-2, X-3.
1060 Skilnand E, Fossen D, Heiberg E. Acupuncture in the management of pain in labor. Acta Obstet Gynecol Scand. 2002;81(10):943-948. X-3a. [pmid: 12366485].
1061 Slater RM, Bowles BJM, Pumphrey RSH. Anaphylactoid reaction to oxytocin in pregnancy. Anaesthesia. 1985;40(7):655-656. X-1, X-2, X-3d, X-5. [pmid: 4025768].
1062 Sloan PA, Rasul M. Prolongation of rapacuronium neuromuscular blockade by clindamycin and magnesium. Anesth Analg. 2002;94(1):123-124. X-1, X-2, X-3d, X-5. [pmid: 11772813].
1063 Smetkin AA, Kirov MY, Kuzkov VV, et al. Single transpulmonary thermodilution and continuous monitoring of central venous oxygen saturation during off-pump coronary surgery. Acta Anaesthesiol Scand. 2009;53(4):505-514. X-2, X-3. [pmid: 19183113].
1064 Smith BE. Teratology in anesthesia. Clin Obstet Gynecol. Jun. 1974;17(2):145-63. X-1, X-2, X-3, X-5. [pmid: 4844196].
1065 Smith BE. Anesthetic emergencies. Clin Obstet Gynecol. 1985;28(2):391-404. X-1, X-2, X-3d, X-5. [pmid: 3160516].
1066 Smith MA, Ruffin IMT, Green LA. The rational management of labor. Am Fam Physician. 1471. 47(6):1471-1481. X-1, X-2. [pmid: 8480568].
1067 Sng BL, Lim Y, Sia AT. An observational prospective cohort study of incidence and characteristics of failed spinal anaesthesia for caesarean section. Int J Obstet Anesth. Jul. 2009;18(3):237-41. X-2, X-3a, X-3d. [pmid: 19450971].
1068 Solca M, Salvo I, Russo R, et al. Anaesthesia with desflurane-nitrous oxide in elderly patients. Comparison with isoflurane-nitrous oxide. Minerva Anestesiol. Sep. 2000;66(9):621-6. X-2, X-3a. [pmid: 11070961].
1069 Sonander H, Stenqvist O, Nilsson K. Urinary N2O as a measure of biologic exposure to nitrous oxide anaesthetic contamination. Ann Occup Hyg. 1983;27(1):73-9. X-2, X-3, X-5. [pmid: 6847046].
1070 Soyannwo OA, Elegbe EO, Odugbesan CO. Effect of flunitrazepam (Rohypnol) on awareness during anaesthesia for caesarean section. Afr J Med Med Sci. Mar. 1988;17(1):23-6. X-2, X-3. [pmid: 2834929].
1071 Soydemir F, Kuruvilla S, Brown M, et al. Adapting in vitro dual perfusion of the human placenta to soluble oxygen tensions associated with normal and pre-eclamptic pregnancy. Lab Invest. 2011;91(2):181-189. X-2, X-3. [pmid: 20921952].
1072 Spence AA, Cohen EN, Brown BW Jr., et al. Occupational hazards for operating room-based physicians. Analysis of data from the United States and the United Kingdom. JAMA. Aug. 29. 1977;238(9):955-9. X-1, X-3. [pmid: 577989].
1073 Spence AA, Knill-Jones RP. Is there a health hazard in anaesthetic practice?. Br J Anaesth. Jul. 1978;50(7):713-9. X-3d, X-5. [pmid: 354667].
1074 Spielman FJ. Anesthesia for in vitro fertilization. Anesthesiol Clin North America. 1989;7(3):723-739. X-1, X-2, X-3.
1075 Spielman FJ, Corke BC. Advantages and disadvantages of regional anesthesia for cesarean section. A review. J Reprod Med. 1985;30(11):832-840. X-1, X-2, X-3. [pmid: 4078816].
1076 Spierdijk J, Regjer V. Dangers of chronic exposure to inhalation anaesthetics. Preventive measures. Acta Anaesthesiol Belg. May. 1973;24(2):115-27. X-1, X-2, X-3, X-5. [pmid: 4717672].
1077 Spodick DH. Directly applied cardiac therapy. Cardiol Rev. 1999;16(7):53-54. X-1, X-2, X-3, X-5.
1078 Sprung J, Flick RP, Wilder RT, et al. Anesthesia for cesarean delivery and learning disabilities in a population-based birth cohort. Anesthesiology. 2009;111(2):302-310. X-2, X-3, X-5. [pmid: 19602960].
1079 Stallabrass P. Halothane and blood loss at delivery. Acta Anaesthesiol Scand Suppl. 1966;25:376. X-1, X-2, X-3, X-5. [pmid: 6003306].
1080 Stange K, Halldin M. Hypothermia in pregnancy. Anesthesiology. 1983;58(5):460-461. X-1, X-2, X-3, X-5. [pmid: 6837998].
1081 Stanway G. Potential hazards of trace inhalation of anaesthetic gases: a risk assessment. SAAD Dig. Apr. 2002;19(2):14-9. X-1, X-2, X-3, X-5. [pmid: 12244732].
1082 Stefani SJ, Hughes SC, Schnider SM, et al. Neonatal neurobehavioral effects of inhalation analgesia for vaginal delivery. Anesthesiology. May. 1982;56(5):351-5. X-2. [pmid: 7072998].
1083 Stenger VG, Blechner JN, Andersen TW, et al. Observations on pentothal, nitrous oxide, and succinylcholine anesthesia at cesarean section. Am J Obstet Gynecol. Nov. 1. 1967;99(5):690-701. X-2, X-3, X-5. [pmid: 6051163].
1084 Stenger VG, Blechner JN, Prystowsky H. A study of prolongation of obstetric anesthesia. Am J Obstet Gynecol. Apr. 1. 1969;103(7):901-7. X-2, X-3, X-5. [pmid: 5774670].
1085 Stevens WD, Dolan WM, Gibbons RT, et al. Minimum alveolar concentrations (MAC) of isoflurande with and without nitrous oxide in patients of various ages. Anesthesiology. Feb. 1975;42(2):197-200. X-3d, X-5. [pmid: 1115370].
1086 Steverlynck N. Birth in Sweden. Midwifery Today. 2007;81:56-7. X-1, X-2, X-3, X-5. [pmid: 17447705].
1087 Stewart A, Sodhi V, Harper N, et al. Assessment of the effect upon maternal knowledge of an information leaflet about pain relief in labour. Anaesthesia. 1015. 58(10):1015-1019. X-2, X-3, X-5. [pmid: 12969045].
1088 Stewart RD. Nitrous oxide sedation/analgesia in emergency medicine. Ann Emerg Med. Feb. 1985;14(2):139-48. X-1, X-2, X-3. [pmid: 4038592].
1089 Stojanovic N, Lewandowski K, Salata I, et al. Serum levels of matrix metalloproteinases MMP-2 and MMP-9 and their inhibitors in women with glucose intolerance in pregnancy and normal controls. Gynecol Endocrinol. 2010;26(3):201-207. X-2, X-3. [pmid: 19526397].
1090 Stovner J, Vangen O. Diazepam compared to thiopentone as induction agent for caesarean sections. Acta Anaesthesiol Scand. 1974;18(4):264-9. X-2, X-3a, X-3d, X-5. [pmid: 4451018].
1091 Stow PJ, White JB. Anaesthesia for paediatric tonsillectomy. Comparison of spontaneous ventilation and intermittent positive pressure ventilation. Br J Anaesth. 1987;59(4):419-423. X-2, X-3d. [pmid: 3552007].
1092 Street D. A practical guide to giving Entonox. Nurs Times. Aug. 24-30. 2000;96(34):47-8. X-1, X-2, X-5. [pmid: 11968402].
1093 Strintzi Paschalaki N, Karathanos A, Demopoulos H. Neurobehavioral responses of newborn infants after maternal epidural vs. general anesthesia. Rev Med Chir Soc Med Nat Iasi. 1982;86(4):619-621. X-2, X-3, X-5. [pmid: 7170517].
1094 Stubblefield MD, Manfield L, Riedel ER. A preliminary report on the efficacy of a dynamic jaw opening device (dynasplint trismus system) as part of the multimodal treatment of trismus in patients with head and neck cancer. Arch Phys Med Rehabil. 1278. 91(8):1278-1282. X-2, X-3a, X-3d. [pmid: 20684911].
1095 Su HT, Chen KB, Liu YC, et al. Cerebral arteriovenous malformation diagnosed during labor induction with headache and convulsions as presentations - A case report. Acta Anaesthesiol Taiwan. 2005;43(4):247-251. X-2, X-3d. [pmid: 16450601].
1096 Sudunagunta S, Eckersall SJ, Gowrie-Mohan S. Continuous caudal analgesia in labour for a patient with Harrington rods. Int J Obstet Anesth. 1998;7(2):128-130. X-1, X-2, X-3, X-5. [pmid: 15321231].
1097 Sungurtekin H, Cook DJ, Orszulak TA, et al. Cerebral response to hemodilution during hypothermic cardiopulmonary bypass in adults. Anesth Analg. 1078. 89(5):1078-1083. X-2, X-3. [pmid: 10553815].
1098 Suver J, Arikian SR, Doyle JJ, et al. Use of anesthesia selection in controlling surgery costs in an HMO hospital. Clin Ther. 1995;17(3):561-571. X-1, X-2, X-3d. [pmid: 7585860].
1099 Svanstrom MC, Biber B, Hanes M, et al. Signs of myocardial ischaemia after injection of oxytocin: A randomized double-blind comparison of oxytocin and methylergometrine during Caesarean section. Br J Anaesth. 2008;100(5):683-689. X-2, X-3a, X-3d. [pmid: 18385263].
1100 Sylvester IE, Paul A. Effects of socio demographic factors on plasma ascorbic acid and alpha tocopherol anti oxidants during pregnancy. Pak J Med Sci. 2009;25(5):755-759. X-2, X-3d.
1101 Tahseen S, McLean G. Spontaneous delivery through perineum, bypassing the vaginal introitus. J Obstet Gynaecol. 2003;23(6):671-672. X-1, X-2, X-3, X-5. [pmid: 14617481].
1102 Tailor TD, Hanna G, Yarmolenko PS, et al. Targeting the tumor microenvironment via inhibition of VEGF and PDGF to improve liposomal drug delivery in human non-small cell lung cancer xenografts. Molecular Cancer Therapeutics. Conference: AACR NCI EORTC International Conference: Molecular Targets and Cancer Therapeutics. Boston, MA United States. Conference Start. 2009. 8(12 SUPPL 1). X-2, X-3d.
1103 Takauchi Y, Inamori N, Ohashi Y, et al. Anesthetic management for cesarean section in two parturients with quintuplet gestation. Masui. 1993;42(12):1844-1848. X-4. [pmid: 8301836].
1104 Tay SM, Ong BC, Tan SA. Cesarean section in a mother with uncorrected congenital coronary to pulmonary artery fistula. Can J Anaesth. 1999;46(4):368-371. X-1, X-2, X-3. [pmid: 10232722].
1105 Taylor DJ, Nelson J, Howie PW. Neurodevelopmental disability--a sibling-control study. Dev Med Child Neurol. Nov. 1993;35(11):957-64. X-2, X-3d. [pmid: 7693529].
1106 Tazeh-Kand NF, Eslami B, Mohammadian K. Inhaled fluticasone propionate reduces postoperative sore throat, cough, and hoarseness. Anesth Analg. 2010;111(4):895-898. X-2, X-3a, X-4. [pmid: 20237046].
1107 Tekavec CD. The pregnant auxiliary: reducing risks in the office setting. Dent Assist (Waco Tx). Jan-Feb. 1984;3(3):20-3. X-1, X-2, X-3, X-5. [pmid: 6584240].
1108 Ternov K, Nilsson M, Lofberg L, et al. Acupuncture for pain relief during childbirth. Acupunct Electrother Res. 1998;23(1):19-26. X-3a, X-5. [pmid: 9607101].
1109 Ternov NK, Buchhave P, Svensson G, et al. Acupuncture during childbirth reduces use of conventional analgesia without major adverse effects: A retrospective study. Am J Acupunct. 1998;26(4):233-239. X-3, X-5.
1110 Teschke K, Abanto Z, Arbour L, et al. Exposure to anesthetic gases and congenital anomalies in offspring of female registered nurses. Am J Ind Med. Feb. 2011;54(2):118-27. X-5. [pmid: 20607734].
1111 Thalme B, Belfrage P, Raabe N. Lumbar epidural analgesia in labour. I. Acid-base balance and clinical condition of mother, fetus and newborn child. Acta Obstet Gynecol Scand. 1974;53(1):27-35. X-3. [pmid: 4817625].
1112 Thalme B, Raabe N, Belfrage P. Lumbar epidural analgesia in labour. II. Effects on glucose, lactate, sodium, chloride, total protein, haematocrit and haemoglobin in maternal, fetal and neonatal blood. Acta Obstet Gynecol Scand. 1974;53(2):113-9. X-3. [pmid: 4822343].
1113 Thind GS, Bryson THL. Single dose suxamethonium and muscle pain in pregnancy. Br J Anaesth. 1983;55(8):743-745. X-2, X-3a, X-3d. [pmid: 6882612].
1114 Thistlewood JM. Obstetric analgesia. Can Fam Physician. 2013;34(SEP). X-1, X-2, X-5.
1115 Thomas I, Thomas M, Scrutton M. Spinal anaesthesia in a patient with hereditary spastic paraplegia: case report and literature review. Int J Obstet Anesth. 2006;15(3):254-256. X-1, X-2, X-3. [pmid: 16798455].
1116 Thomas TA, Fletcher JE, Hill RG. Influence of medication, pain and progress in labour on plasma beta-endorphin-like immunoreactivity. Br J Anaesth. Apr. 1982;54(4):401-8. X-2. [pmid: 6279134].
1117 Thorburn J, Reid JA. Alternative methods of pain relief in pregnancy. Curr Obstet Gynaecol. 1996;6(2):61-66. X-1, X-2, X-5.
1118 Thorniley A, Moyes DG, Pike RF, et al. Comparison of nalbuphine and pethidine for the relief of pain after caesarean section. S Afr Med J. 1986;69(11):682-683. X-2, X-3a, X-3d. [pmid: 3704858].
1119 Thurlow JA, Laxton CH, Dick A, et al. Remifentanil by patient-controlled analgesia compared with intramuscular meperidine for pain relief in labour. Br J Anaesth. 2002;88(3):374-378. X-2, X-3d. [pmid: 11990269].
1120 Todorova K, Palaveev O, Petkova VB, et al. A pharmacoeconomical model for choice of a treatment for pregnant women with gestational diabetes. Acta Diabetologica. 2007;44(3):144-148. X-2, X-3d. [pmid: 17721753].
1121 Tooley G. Normal birth: a new beginning. RCM Midwives. 2005;8(8):338-9. X-1, X-2, X-3, X-5. [pmid: 16353730].
1122 Torricelli M, Sabatini L, Florio P, et al. Levels of antibodies against protein C and protein S in pregnancy and in preeclampsia. J Matern Fetal Neonatal Med. 2009;22(11):993-999. x-2, X-3d. [pmid: 19900037].
1123 Tortosa JC, Parry NS, Mercier FJ, et al. Efficacy of augmentation of epidural analgesia for Caesarean section. Br J Anaesth. 2003;91(4):532-535. X-2, X-3a, X-3d. [pmid: 14504155].
1124 Tournaire M. Alternative approaches to pain relief during labor and delivery. Adv Exp Med Biol. 2004;546:193-206. X-1, X-2, X-5. [pmid: 15584375].
1125 Trevisan A, Gori GP. Biological monitoring of nitrous oxide exposure in surgical areas. Am J Ind Med. 1990;17(3):357-62. X-3d, X-5. [pmid: 2305815].
1126 Tsai FF, Wu GJ, Lin CJ, et al. Optimizing epidural fentanyl loading dose for early labor pain. Acta Anaesthesiol Taiwan. 2009;47(4):167-172. X-3a, X-3d. [pmid: 20015816].
1127 Tsai PS, Huang CJ, Hung YC, et al. Effects on the bispectral index during elective caesarean section: a comparison of propofol and isoflurane. Acta Anaesthesiol Sin. Mar. 2001;39(1):17-22. X-2, X-3a, X-3d, X-5. [pmid: 11407290].
1128 Tsen LC. Anesthesia for assisted reproductive technologies. Int Anesthesiol Clin. 2007;45(1):99-113. X-1, X-2, X-3, X-5. [pmid: 17215702].
1129 Tuckey JP, Prout RE, Wee MYK. Prescribing intramuscular opioids for labour analgesia in consultant-led maternity units: a survey of UK practice. Int J Obstet Anesth. 2008;17(1):3-8. X-2, X-3. [pmid: 17981457].
1130 Tunell R. Method for determination of pulmonary gas exchange in connection with birth. Acta Paediatr Scand. Jan. 1975;64(1):49-56. X-2, X-3d. [pmid: 1114897].
1131 Tunstall ME. Obstetric analgesia. The use of a fixed nitrous oxide and oxygen mixture from one cylinder. Lancet. Oct. 28. 1961;2(7209):964. X-1, X-2, X-3, X-4, X-5. [pmid: 13923097].
1132 Tunstall ME. The reduction of amnesic wakefulness during caesarean section. Anaesthesia. Apr. 1979;34(4):316-9. X-2, X-3d, X-5. [pmid: 453504].
1133 Tunstall ME, Hawksworth GM. Halothane uptake and nitrous oxide concentration. Arterial halothane levels during Caesarean section. Anaesthesia. Feb. 1981;36(2):177-82. X-2, X-3a, X-3d, X-5. [pmid: 7212227].
1134 Tunstall ME, Sheikh A. Comparison of 1.5% enflurane with 1.25% isoflurane in oxygen for caesarean section: avoidance of awareness without nitrous oxide. Br J Anaesth. Feb. 1989;62(2):138-43. X-2, X-3d. [pmid: 2923765].
1135 Tveit TO, Halvorsen A, Rosland JH. Analgesia for labour: a survey of Norwegian practice - with a focus on parenteral opioids. Acta Anaesthesiol Scand. Jul. 2009;53(6):794-9. X-2, X-3d, X-5. [pmid: 19456300].
1136 Tylleskar J, Finnstrom O, Leijon I. Spontaneous labor and elective induction - a prospective randomized study. I. Effects on mother and fetus. Acta Obstet Gynecol Scand. 1979;58(6):513-518. X-3, X-5. [pmid: 45068].
1137 Ueland K, Hansen J, Eng M, et al. Maternal cardiovascular dynamics. V. Cesarean section under thiopental, nitrous oxide, and succinylcholine anesthesia. Am J Obstet Gynecol. Oct. 15. 1970;108(4):615-22. X-2, X-3d, X-5. [pmid: 5505993].
1138 Uppington J, Kay NH, Sear JW. Propofol (‘Diprivan’) as a supplement to nitrous oxide-oxygen for the maintenance of anaesthesia. Postgrad Med J. Suppl 3. 1985;61:80-3. X-2, X-3a, X-3d, X-5. [pmid: 3877301].
1139 Uys PC, Morrell DF, Bradlow HS, et al. Self-tuning, microprocessor-based closed-loop control of atracurium-induced neuromuscular blockade. Br J Anaesth. 1988;61(6):685-692. X-2, X-3d. [pmid: 3207541].
1140 Vaillancourt C, Berger N, Boksa P. Effects of vaginal birth versus caesarean section birth with general anesthesia on blood gases and brain energy metabolism in neonatal rats. Exp Neurol. Nov. 1999;160(1):142-50. X-2, X-3d. [pmid: 10630199].
1141 Vakkuri O, Arnason SS, Pouta A, et al. Radioimmunoassay of plasma ouabain in healthy and pregnant individuals. J Endocrinol. 2000;165(3):669-677. X-2, X-3d. [pmid: 10828851].
1142 Vallejo MC, Phelps AL, Shepherd CJ, et al. Nitrous oxide anxiolysis for elective cesarean section. J Clin Anesth. Nov. 2005;17(7):543-8. X-2, X-3d. [pmid: 16297755].
1143 Van Buul BJA, Nijhuis JG, Slappendel R, et al. General anesthesia for surgical repair of intracranial aneurysm in pregnancy: Effects on fetal heart rate. Am J Perinatol. 1993;10(2):183-186. X-2, X-3d. [pmid: 8476488].
1144 Van Damme C, Berre J. Influence of enflurane on blood loss from the pregnant uterus. Acta Anaesthesiol Belg. 1976;27(suppl):259-61. X-2, X-3b, X-5. [pmid: 1015226].
1145 Van de Velde M. CONTROVERSY cont. to follow after “Remifentanil patient-controlled analgesia should be routinely available for use in labour” on same page. Int J Obstet Anesth. 2008;17(4):339-342. X-1, X-3d, X-5. [pmid: 18617386].
1146 Van Der Linden P, Wathieu M, Gilbart E, et al. Cardiovascular effects of moderate normovolaemic haemodilution during enflurane-nitrous oxide anaesthesia in man. Acta Anaesthesiol Scand. 1994;38(5):490-498. X-2, X-3d. [pmid: 7524256].
1147 Van Nimwegen D, Dyer DC. The action of vasopressors on isolated uterine arteries. Am J Obstet Gynecol. Apr. 15. 1974;118(8):1099-103. X-3. [pmid: 4817644].
1148 Van Wijngaarden WJ, Strachan BK, Sahota DS, et al. Improving intrapartum surveillance: An individualised T/QRS ratio?. Eur J Obstet Gynecol Reprod Biol. 2000;88(1):43-48. X-3d, X-5. [pmid: 10659915].
1149 Vandewater SL. Anaesthesia for the primiparous patient. Acta Anaesthesiol Scand Suppl. 1966;23:167-71. X-3a, X-5. [pmid: 6003630].
1150 Vangen S, Stoltenberg C, Schei B. Ethnicity and use of obstetrical analgesia: do Pakistani women receive inadequate pain relief in labour?. Ethn Health. May. 1996;1(2):161-7. X-3, X-5. [pmid: 9395560].
1151 Vanhorebeek I, Vos RD, Mesotten D, et al. Protection of hepatocyte mitochondrial ultrastructure and function by strict blood glucose control with insulin in critically ill patients. Lancet. 9453. 365(9453):53-59. X-2, X-3d. [pmid: 15639679].
1152 Vardanyan A, Mastis B, Serriello J, et al. Development of behavioral measures of osteoarthritis-induced pain in rabbits. Osteoarthritis Cartilage. 2010;18:S222. Conference. X-2, X-3d.
1153 Vassiliadis J, Hitos K, Hill CT. Factors influencing prehospital and emergency department analgesia administration to patients with femoral neck fractures. Emerg Med. 2002;14(3):261-266. X-2, X-3d.
1154 Vedam S, Goff M, Marnin VN. Closing the Theory-Practice Gap: Intrapartum Midwifery Management of Planned Homebirths. Journal of Midwifery and Women's Health. 2007;52(3):291-300. X-1, X-2.
1155 Vella L, Francis D, Houlton P, et al. Comparison of the antiemetics metoclopramide and promethazine in labour. Br Med J (Clin Res Ed). Apr. 20. 1985;290(6476):1173-5. X-1, X-3d, X-5.
1156 Velzing-Aarts FV, Van Der Klis FRM, Van Der Dijs FPL, et al. Effect of three low-dose fish oil supplements, administered during pregnancy, on neonatal long-chain polyunsaturated fatty acid status at birth. Prostaglandins Leukot Essent Fatty Acids. 2001;65(1):51-57. X-2, X-3d. [pmid: 11487309].
1157 Verma R, Ramasubramanian R, Sachar RM. Anesthesia for termination of pregnancy: midazolam compared with methohexital. Anesth Analg. Aug. 1985;64(8):792-4. X-2, X-3b, X-3d. [pmid: 3160263].
1158 Versichelen L, Serreyn R, Rolly G, et al. Physiopathologic changes during anesthesia administration for gynecologic laparoscopy. J Reprod Med. 1984;29(10):697-700. X-2, X-3d. [pmid: 6239921].
1159 Vessey MP, Nunn JF. Occupational hazards of anesthesia. Br Med J. Sep. 13. 1980;281(6242):696-8. X-1, X-2, X-3a, X-5. [pmid: 7000271].
1160 Victory RA, Gajraj NM, Van Elstraete A, et al. Effect of preincision versus postincision infiltration with bupivacaine on postoperative pain. J Clin Anesth. 1995;7(3):192-196. X-2, X-3d. [pmid: 7669307].
1161 Vieira E, Cleaton-Jones P, Moyes D. Effects of intermittent 0 5% nitrous oxide/air (v/v) on the fertility of male rats and the post-natal growth of their offspring. Anaesthesia. 1983;38(4):319-23. X-2, x-3d, X-5. [pmid: 6682636].
1162 Villeneuve V, Kaufman I, Weeks S, et al. Anesthetic management of a labouring parturient with urticaria pigmentosa. Can J Anaesth. 2006;53(4):380-384. X-2, X-3d. [pmid: 16575037].
1163 Vincent RD Jr., Syrop CH, Van Voorhis BJ, et al. An evaluation of the effect of anesthetic technique on reproductive success after laparoscopic pronuclear stage transfer. Propofol/nitrous oxide versus isoflurane/nitrous oxide. Anesthesiology. Feb. 1995;82(2):352-8. X-2, X-3d. [pmid: 7856893].
1164 Vincenti E, Giorgino F, Agnello A, et al. Is the current general anaesthesia for caesarean section really protective for the mother and the foetus? A study on beta-endorphin levels with different techniques of general anaesthesia. Agressologie. 1988;29(3):193-197. X-2, X-3d. [pmid: 2975147].
1165 Vogel TM, Ratner EF, Thomas RC Jr, et al. Pregnancy complicated by severe osteogenesis imperfecta: A report of two cases. Anesth Analg. 1315. 94(5):1315-1317. X-2, X-3d. [pmid: 11973211].
1166 Volmanen P, Akural E, Raudaskoski T, et al. Comparison of remifentanil and nitrous oxide in labour analgesia. Acta Anaesthesiol Scand. Apr. 2005;49(4):453-8. X-2. [pmid: 15777291].
1167 Volmanen P, Akural EI, Raudaskoski T, et al. Remifentanil in obstetric analgesia: A dose-finding study. Anesth Analg. 2002;94(4):913-917. X-3a, X-3d. [pmid: 11916796].
1168 Volmanen P, Palomäki O, Ahonen J. Alternatives to neuraxial analgesia for labor. Curr Opin Anesthesiol. 2011;24(3):235-41. X-1, X-2.
1169 Volmanen PVE, Akural EI, Raudaskoski T, et al. Timing of intravenous patient-controlled remifentanil bolus during early labour. Acta Anaesthesiol Scand. 2011;55(4):486-494. X-3a, X-3d. [pmid: 21288228].
1170 Voss L, Shimoda T. Protect against free NO2 in the operatory--for health's sake. Dent Stud. May. 1977;55(8):62-6. X-1, X-2, X-5. [pmid: 280488].
1171 Vural P, Akgul C, Yildirim A, et al. Antioxidant defence in recurrent abortion. Clinica Chimica Acta. 2000;295(1-2):169-177. X-2, X-3b.
1172 Wagner RL, White PF. Etomidate inhibits adrenocortical function in surgical patients. Anesthesiology. Dec. 1984;61(6):647-51. X-2, X-3d. [pmid: 6095700].
1173 Wakeling HG, McFall MR, Jenkins CS, et al. Intraoperative oesophageal Doppler guided fluid management shortens postoperative hospital stay after major bowel surgery. Br J Anaesth. 2005;95(5):634-642. X-2, X-3d. [pmid: 16155038].
1174 Waldenstrom U. Midwives' attitudes to pain relief during labour and delivery. Midwifery. Jun. 1988;4(2):48-57. X-5. [pmid: 3386541].
1175 Waldenstrom U. Variations between midwives regarding administration of obstetrical analgesia. Scand J Caring Sci. 1989;3(2):83-9. X-2, X-3d, X-5. [pmid: 2762684].
1176 Waldmann CS, Verghese C, Short SM. The evaluation of domperidone and metoclopramide as antiemetics in day care abortion patients. Br J Clin Pharmacol. 1985;19(3):307-310. X-2, X-3b, X-3d. [pmid: 3885984].
1177 Waldron Ble G. Awareness under general anaesthesia. Br J Anaesth. Jun. 1971;43(6):591. X-1, X-2, X-3, X-5. [pmid: 5089937].
1178 Warde DJ. Anaesthesia and the practice of medicine: Historical perspectives. Ir Med J. 2008;101(7). X-1, X-2, X-3, X-5.
1179 Warren TM, Datta S, Ostheimer GW, et al. Comparison of the maternal and neonatal effects of halothane, enflurane, and isoflurane for cesarean delivery. Anesth Analg. May. 1983;62(5):516-20. X-2, X-3a, X-3d. [pmid: 6837963].
1180 Watanabe KI, Hatakenaka S, Ikemune K, et al. A case of suspected liver dysfunction induced by sevoflurane anesthesia. Masui. 1993;42(6):902-905. X-2, X-3a. [pmid: 8320810].
1181 Watcha MF, White PF, Tychsen L, et al. Comparative effects of laryngeal mask airway and endotracheal tube insertion on intraocular pressure in children. Anesth Analg. 1992;75(3):355-360. X-2, X-3a. [pmid: 1510256].
1182 Wathen KA, Stenman UH, Leinonen E, et al. Concentrations of vascular endothelial growth factor C and D in amniotic fluid and maternal plasma. Acta Obstet Gynecol Scand. 2009;88(6):629-634. X-2, X-3. [pmid: 19308753].
1183 Watson ED, Henderson-Smart DJ, Storey GNB, et al. Perinatal factors and the development of chronic lung disease in preterm infants: A case control study. Aust Paediatr J. 1987;23(3):181-184. X-2, X-3d. [pmid: 3310996].
1184 Waud BE, Waud DR. Calculated kinetics of distribution of nitrous oxide and methoxyflurane during intermittent administration in obstetrics. Anesthesiology. Apr. 1970;32(4):306-16. X-1, X-2, X-5. [pmid: 5437861].
1185 Wee MY, Hasan MA, Thomas TA. Isoflurane in labour. Anaesthesia. May. 1993;48(5):369-72. X-2. [pmid: 8317641].
1186 Weinberg CR, Baird DD, Rowland AS. Pitfalls inherent in retrospective time-to-event studies: the example of time to pregnancy. Stat Med. May. 15. 1993;12(9):867-79. X-1, X-2, X-3. [pmid: 8327803].
1187 Weingarten AE, Korsh JI, Neuman GG, et al. Postpartum uterine atony after intravenous dantrolene. Anesth Analg. 1987;66(3):269-270. X-1, X-2, X-3, X-5. [pmid: 3826671].
1188 Weiniger CF, Ivri S, Ioscovich A, et al. Obstetric anesthesia units in Israel: a national questionnaire-based survey. Int J Obstet Anesth. Oct. 2010;19(4):410-6. X-5. [pmid: 20708921].
1189 Weis OF, Muller FO, Lyell H. Materno-fetal cholinesterase inhibitor poisoning. Anesth Analg. 1983;62(2):233-235. X-1, X-2, X-3, X-5. [pmid: 6829926].
1190 Weiss JE, Uribe AG, Malleson PN, et al. Anesthesia for intra-articular corticosteroid injections in juvenile idiopathic arthritis: A survey of pediatric rheumatologists. Pediatr Rheumatol. 2010;8(3). X-2, X-3.
1191 Weissman DB, Ehrenwerth J. Prolonged neuromuscular blockade in a parturient associated with succinylcholine. Anesth Analg. 1983;62(4):444-446. X-1, X-2, X-3, X-5. [pmid: 6829947].
1192 Wessen A, Elowsson P, Axemo P, et al. The use of intravenous nitroglycerin for emergency cervico-uterine relaxation. Acta Anaesthesiol Scand. 1995;39(6):847-849. X-1, X-2, X-3a. [pmid: 7484047].
1193 West SL, Moore CA, Gillard M, et al. Anaesthesia for suction termination of pregnancy. Anaesthesia. Jul. 1985;40(7):669-72. X-2, X-3b. [pmid: 4025771].
1194 Westenskow DR, Jordan WS, Hayes JK. Uptake of enflurane: A study of the variability between patients. Br J Anaesth. 1983;55(7):595-601. X-2, X-3. [pmid: 6871052].
1195 Westgren M, Lindahl SG, Norden NE. Maternal and fetal endocrine stress response at vaginal delivery with and without an epidural block. J Perinat Med. 1986;14(4):235-41. X-2. [pmid: 3029362].
1196 White PF, Coe V, Shafer A, et al. Comparison of alfentanil with fentanyl for outpatient anesthesia. Anesthesiology. 1986;64(1):99-106. X-1, X-2, X-3. [pmid: 3079973].
1197 Whittaker M, Selwyn Crawford J. Postoperative ileus, pregnancy-related cholinesterase deficiency and suxamethonium after-pains. A case report. Br J Anaesth. 1983;55(6):581-584. X-2, X-3. [pmid: 6860526].
1198 Wikstrom AK, Larsson A, Eriksson UJ, et al. Early postpartum changes in circulating pro- and anti-angiogenic factors in early-onset and late-onset pre-eclampsia. Acta Obstet Gynecol Scand. 2008;87(2):146-153. X-2, X-3. [pmid: 18231881].
1199 Wildsmith JA. Serum cholinesterase, pregnancy and suxamethonium. Anaesthesia. Jan. 1972;27(1):90-1. X-1, X-2, X-3a, X-3d, X-5. [pmid: 5007637].
1200 Wilhelm W, Hammadeh ME, White PF, et al. General anesthesia versus monitored anesthesia care with remifentanil for assisted reproductive technologies: effect on pregnancy rate. J Clin Anesth. Feb. 2002;14(1):1-5. X-2, X-3. [pmid: 11880013].
1201 Wilkins CJ, Reed PN, Aitkenhead AR. Hypoxaemia after inhalation of 50% nitrous oxide and oxygen. Br J Anaesth. Sep. 1989;63(3):346-7. X-2, X-3, X-5. [pmid: 2803894].
1202 Willdeck Lund G. General anaesthesia versus epidural block for caesarean section in patient with pre-eclampsia. AActa Obstet Gynecol Scand. 1983;62(SUPPL 118):117-119. X-2, X-3.
1203 Williams CE, Povey RC, White DG. Predicting women's intentions to use pain relief medication during childbirth using the Theory of Planned Behaviour and Self-Efficacy Theory. J Reprod Infant Psychol. 2008;26(3):168-79. X-2.
1204 Williamson LM, Buston K, Sweeting H. Young women and limits to the normalisation of condom use: A qualitative study. AIDS Care. 2009;21(5):561-566. X-2, X-3. [pmid: 19444663].
1205 Willis BA, Rosen M. Entonox analgesia--a method of reducing the delay between demand and supply. Anaesthesia. Jun. 1977;32(6):573-6. X-2, X-3d, X-5. [pmid: 879470].
1206 Wilson IH, Nair KR, Chibwe K, et al. Awareness during anaesthesia for caesarean section in Zambia. Trop Doct. Oct. 1990;20(4):160-2. X-2, X-3, X-5. [pmid: 2284668].
1207 Wilson J. Methoxyflurane in Caesarean section. Br J Anaesth. Feb. 1973;45(2):233-4. X-1, X-2, X-3, X-5. [pmid: 4704079].
1208 Wilson J, Turner DJ. Awareness during caesarean section under general anaesthesia. Br Med J. Feb. 1. 1969;1(5639):280-3. X-2, X-3a, X-3d, X-5. [pmid: 5762645].
1209 Wilson MJA, MacArthur C, Cooper GM, et al. Epidural analgesia and breastfeeding: A randomised controlled trial of epidural techniques with and without fentanyl and a non-epidural comparison group. Anaesthesia. 2010;65(2):145-153. X-2, X-3d. [pmid: 19912160].
1210 Wilson RD, Priano LL, Allen CR, et al. Demand analgesia and anesthesia in obstetrics: an evaluation of apparatus and technic. South Med J. May. 1972;65(5):556-62. X-3, X-5. [pmid: 5027460].
1211 Wolff J, Carl P, Clausen TG, et al. Ro 15-1788 for postoperative recovery: A randomised clinical trial in patients undergoing minor surgical procedures under midazolam anaesthesia. Anaesthesia. 1001. 41(10):1001-1006. X-2, X-3b. [pmid: 3098131].
1212 Wong AYC, Chan RSN, Irwin MG. Anesthetic management of Cesarean delivery in a patient with hypoplastic anemia and severe pre-eclampsia. Can J Anaesth. 2004;51(9):923-927. X-1, X-2, X-3. [pmid: 15525619].
1213 Yabe M, Enzan K, Takahashi H, et al. Anesthetic management of a patient with HELLP syndrome with bronchial asthma. Masui. 1993;42(8):1230-1232. X-1, X-2, X-3. [pmid: 8366566].
1214 Yacoub O, Doell D, Kryger MH, et al. Depression of hypoxic ventilatory response by nitrous oxide. Anesthesiology. Oct. 1976;45(4):385-9. X-2. [pmid: 973689].
1215 Yamada K, Takahashi R, Hamatani K. Hemorrhagic shock due to ruptured left common iliac artery aneurysm during pregnancy. J Anesth. 2002;16(4):342-344. X-1, X-2, X-3. [pmid: 14517629].
1216 Yamani-Zamzami TY. Delivery outcomes at term after one previous cesarean section. Saudi Med J. 1845;28(12):1845-1849. X-3d, X-5. [pmid: 18060214].
1217 Yang J, Leng J, Lang J. Clinical Analysis of 5 Cases of Laparoscopy in Pregnant Patients. Chin Med Sci J. 2003;18(4). X-2, X-3, X-5.
1218 Yao FSF, Savarese JJ. Pseudocholinesterase hyperactivity with succinylcholine resistance: An unusual cause of difficult intubation. J Clin Anesth. 1997;9(4):328-330. X-1, X-2, X-3. [pmid: 9195358].
1219 Yau G, Gin T, Ewart MC, et al. Propofol for induction and maintenance of anaesthesia at caesarean section. A comparison with thiopentone/enflurane. Anaesthesia. Jan. 1991;46(1):20-3. X-2, X-3d. [pmid: 1996746].
1220 Yavascaoglu B, Girgin NK. General anesthesia for urgent Caesarean section in a patient with untreated Takayasu's arteritis. Am J Case Rep. 2008;9:273-276. X-2, X-3.
1221 Yentur EA, Topcu I, Ekici Z, et al. The effect of epidural and general anesthesia on newborn rectal temperature at elective cesarean section. Braz J Med Biol Res. 2009;42(9):863-867. X-2, X-3d. [pmid: 19738991].
1222 Yeo SN, Lo WK. Bispectral index in assessment of adequacy of general anaesthesia for lower segment caesarean section. Anaesth Intensive Care. Feb. 2002;30(1):36-40. X-2, X-3d. [pmid: 11939437].
1223 Yerby M. Managing pain in labour Part 3: pharmacological methods of pain relief. Mod Midwife. 1996;6(5):22-5. X-1, X-2, X-5.
1224 Yoo KY, Jeong CW, Kang MW, et al. Bispectral index values during sevoflurane-nitrous oxide general anesthesia in women undergoing cesarean delivery: a comparison between women with and without prior labor. Anesth Analg. Jun. 2008;106(6):1827-32. X-2, X-3d, X-5. [pmid: 18499617].
1225 Yoon HJ, Hong JY, Kim SM. The effect of anesthetic method for prophylactic cervical cerclage on plasma oxytocin: a randomized trial. Int J Obstet Anesth. 2008;17(1):26-30. X-2, X-3a. [pmid: 17698336].
1226 Yoshizumi J, Vaughan RS, Jasani B. Pregnancy associated with Gorlin's syndrome. Anaesthesia. 1046. 45(12):1046-1048. X-1, X-2, X-3. [pmid: 2278327].
1227 Young KD. What's New in Topical Anesthesia. Clin Pediatr Emerg Med. 2007;8(4):232-239. X-1, X-2, X-3.
1228 Youngs PJ, Sice P, Harvey P. Labour analgesia and pseudoxanthoma elasticum (PXE). Int J Obstet Anesth. 2003;12(1):48-50. X-2, X-3d. [pmid: 15676321].
1229 Younker D, Harrison B. Scleroderma and pregnancy. Anaesthetic considerations. Br J Anaesth. 1136. 57(11):1136-1139. X-2, X-3. [pmid: 4052305].
1230 Youssef AR, Toppozada MK, El-Damarawi HA, et al. Effects of analgesics during labor. Middle East J Anaesthesiol. Jun. 1978;5(1):46-56. X-2. [pmid: 581690].
1231 Youssef HAE, El Shafi S, Alfy A. Low-dose ketamine infusion as an analgesic for vaginal delivery. Med Princ Pract. 1990;2(3-4):190-198. X-3d.
1232 Zagorzycki MT, Brinkman CR 3rd. The effect of general and epidural anesthesia upon neonatal Apgar scores in repeat cesarean section. Surg Gynecol Obstet. Nov. 1982;155(5):641-5. X-2, X-3a, X-3d. [pmid: 7135169].
1233 Zanardo V, Caroni G, Burlina A. Higher homocysteine concentrations in women undergoing caesarean section under general anesthesia. Thromb Res. 2003;112(1-2):33-6. X-2, X-3a, X-3d, X-5. [pmid: 15013270].
1234 Zavos PM, Correa JR, Kaskar K, et al. Precoital sexual stimulation and its effects on seminal characteristics. Middle East Fertil Soc J. 2003;8(1):69-73. X-2, X-3d.