# Applicability and Quality Tables

Table 1 Key Question 1—Applicability

Domain | Description of Applicability of Evidence Compared With Question
Population | The study populations were healthy women in labor who should be similar to the target population. The eligibility criteria and participant characteristics were not always explicitly detailed. Some participants were excluded due to choice of alternate pain management methods.
Intervention | Most studies used a 50/50 mix of nitrous and oxygen, often premixed in the form of Entonox. The 50/50 mix is available, although Entonox is not used in the U.S, and not currently approved by the FDA. In addition, mechanical equipment for delivery of N2O in labor and delivery has very limited availability in the U.S.
Comparators | The comparators include standard pain management methods, such as epidural, narcotics, and nonpharmacologic methods such as TENS. However, some comparators are not commonly used and/or available for laboring women in the U.S., such as other inhalational anesthetic gases.
Outcomes | The most frequent outcome was an assessment of pain, generally during labor. Some studies retrospectively assessed pain in the immediate postpartum period and/or weeks to months after birth. The methods of pain assessment were heterogeneous. Those assessing outcomes included participants, obstetricians, midwives, and anesthesia providers.
Setting | Only five of 21 studies were conducted in the U.S. The standards of care are not comparable because nitrous is widely available outside of the U.S. All of the studies were conducted in hospitals, thus the effectiveness of the intervention in birth centers and the home setting has not been reported.

Table 2 Key Question 2—Applicability

Domain | Description of Applicability of Evidence Compared With Question
Population | The study populations were healthy women in labor who should be similar to the target population. The eligibility criteria and participant characteristics were not always explicitly detailed. Some participants were excluded due to choice of alternate pain management methods.
Intervention | Most studies used a 50/50 mix of nitrous and oxygen, often premixed in the form of Entonox. The 50/50 mix is available, although Entonox is not used in the U.S, and not currently approved by the FDA. In addition, mechanical equipment for delivery of N2O in labor and delivery has very limited availability in the U.S.
Comparators | The comparators include standard pain management methods, such as epidural, narcotics, and nonpharmacologic methods such as TENS. However, some comparators are not commonly used and/or available for laboring women in the U.S., such as other inhalational anesthetic gases.
Outcomes | Satisfaction with pain management and the birth experience were the outcome measures, as reported by the women.
Setting | Only three of nine studies were conducted in the U.S. The standards of care are not comparable because nitrous is widely available outside of the U.S. All of the studies were conducted in hospitals, thus the satisfaction with the intervention in birth centers and the home setting has not been reported.

Table 3 Key Question 3—Applicability

Domain | Description of Applicability of Evidence Compared With Question
Population | The study populations were healthy women in labor who should be similar to the target population. The eligibility criteria and participant characteristics were not always explicitly detailed. Some participants were excluded due to choice of alternate pain management methods.
Intervention | Most studies used a 50/50 mix of nitrous and oxygen, often premixed in the form of Entonox. The 50/50 mix is available, although Entonox is not used in the U.S, and not currently approved by the FDA. In addition, mechanical equipment for delivery of N2O in labor and delivery has very limited availability in the U.S.
Comparators | The comparators include standard pain management methods, such as epidural, narcotics, and nonpharmacologic methods such as TENS. However, some comparators are not commonly used and/or available for laboring women in the U.S., such as other inhalational anesthetic gases.
Outcomes | The outcomes were vaginal birth, assisted vaginal birth, and cesarean. None of the studies had a cesarean birth rate greater than 10%, which is much lower than the most recently reported U.S. rate of 32%.1
Setting | Only one of six studies was conducted in the U.S. The standards of care are not comparable because nitrous is widely available outside of the U.S. All of the studies were conducted in hospitals, thus the route of birth in birth centers and the home setting has not been reported.

Table 4 Key Question 4—Applicability

Domain | Description of Applicability of Evidence Compared With Question
Population | The study populations were healthy women in labor who should be similar to the target population. The eligibility criteria and participant characteristics were not always explicitly detailed. Some participants were excluded due to choice of alternate pain management methods.
Intervention | Most studies used a 50/50 mix of nitrous and oxygen, often premixed in the form of Entonox. The 50/50 mix is available, although Entonox is not used in the U.S, and not currently approved by the FDA. The intervention varied significantly in terms of dose, frequency, and duration. In many studies participants received unspecified amounts of narcotics and/or sedating agents. Studies prior to 1980 are not applicable to current guidelines for clinical use.
Comparators | The comparators include standard pain management methods, such as epidural, narcotics, and nonpharmacologic methods such as TENS. However, some comparators are not commonly used and/or available for laboring women in the U.S., such as other inhalational anesthetic gases.
Outcomes | The most frequent outcomes were assessments of nausea, vomiting, dizziness, drowsiness, hypoxia, oxygen saturation, Apgar scores, and cord blood gases. Apoptosis was not addressed because there are no human studies.
Setting | Only six of 48 studies were conducted in the U.S. The standards of care are not comparable because nitrous is widely available outside of the U.S.

Table 5 The Cochrane Risk of Bias Tool for Randomized Controlled Trials

RANDOM SEQUENCE GENERATION Selection bias (biased allocation to interventions) due to inadequate generation of a randomised sequence.
Criteria for a judgment of ‘Low risk’ of bias. | The investigators describe a random component in the sequence generation process such as:; - Referring to a random number table;; - Using a computer random number generator;; - Coin tossing;; - Shuffling cards or envelopes;; - Throwing dice;; - Drawing of lots;; - Minimization*.; *Minimization may be implemented without a random element, and this is considered to be equivalent to being random.
Criteria for the judgment of ‘High risk’ of bias. | The investigators describe a nonrandom component in the sequence generation process. Usually, the description would involve some systematic, nonrandom approach, for example:; - Sequence generated by odd or even date of birth;; - Sequence generated by some rule based on date (or day) of admission;; - Sequence generated by some rule based on hospital or clinic record number.; Other nonrandom approaches happen much less frequently than the systematic approaches mentioned above and tend to be obvious. They usually involve judgement or some method of nonrandom categorization of participants, for example:; - Allocation by judgement of the clinician;; - Allocation by preference of the participant;; - Allocation based on the results of a laboratory test or a series of tests;; - Allocation by availability of the intervention.
Criteria for the judgment of ‘Unclear risk’ of bias. | Insufficient information about the sequence generation process to permit judgement of ‘Low risk’ or ‘High risk’.
ALLOCATION CONCEALMENT Selection bias (biased allocation to interventions) due to inadequate concealment of allocations prior to assignment.
Criteria for a judgment of ‘Low risk’ of bias. | Participants and investigators enrolling participants could not foresee assignment because one of the following, or an equivalent method, was used to conceal allocation:; - Central allocation (including telephone, web-based and pharmacy-controlled randomization);; - Sequentially numbered drug containers of identical appearance;; - Sequentially numbered, opaque, sealed envelopes.
Criteria for the judgment of ‘High risk’ of bias. | Participants or investigators enrolling participants could possibly foresee assignments and thus introduce selection bias, such as allocation based on:; - Using an open random allocation schedule (e.g. a list of random numbers);; - Assignment envelopes were used without appropriate safeguards (e.g. if envelopes were unsealed or nonopaque or not sequentially numbered);; - Alternation or rotation;; - Date of birth;; - Case record number;; - Any other explicitly unconcealed procedure.
Criteria for the judgment of ‘Unclear risk’ of bias. | Insufficient information to permit judgement of ‘Low risk’ or ‘High risk’. This is usually the case if the method of concealment is not described or not described in sufficient detail to allow a definite judgement – for example if the use of assignment envelopes is described, but it remains unclear whether envelopes were sequentially numbered, opaque and sealed.
SELECTIVE REPORTING Reporting bias due to selective outcome reporting.
Criteria for a judgment of ‘Low risk’ of bias. | Any of the following:; - The study protocol is available and all of the study's prespecified (primary and secondary) outcomes that are of interest in the review have been reported in the prespecified way;; - The study protocol is not available but it is clear that the published reports include all expected outcomes, including those that were prespecified (convincing text of this nature may be uncommon).
Criteria for the judgment of ‘High risk’ of bias. | Any one of the following:; - Not all of the study's prespecified primary outcomes have been reported;; - One or more primary outcomes is reported using measurements, analysis methods or subsets of the data (e.g. subscales) that were not prespecified;; - One or more reported primary outcomes were not prespecified (unless clear justification for their reporting is provided, such as an unexpected adverse effect);; - One or more outcomes of interest in the review are reported incompletely so that they cannot be entered in a meta-analysis;; - The study report fails to include results for a key outcome that would be expected to have been reported for such a study.
Criteria for the judgment of ‘Unclear risk’ of bias. | Insufficient information to permit judgement of ‘Low risk’ or ‘High risk’. It is likely that the majority of studies will fall into this category.
OTHER BIAS Bias due to problems not covered elsewhere in the table.
Criteria for a judgment of ‘Low risk’ of bias. | The study appears to be free of other sources of bias.
Criteria for the judgment of ‘High risk’ of bias. | There is at least one important risk of bias. For example, the study:; - Had a potential source of bias related to the specific study design used; or; - Has been claimed to have been fraudulent; or; - Had some other problem.
Criteria for the judgment of ‘Unclear risk’ of bias. | There may be a risk of bias, but there is either:; - Insufficient information to assess whether an important risk of bias exists; or; - Insufficient rationale or evidence that an identified problem will introduce bias.
BLINDING OF PARTICIPANTS AND PERSONNEL Performance bias due to knowledge of the allocated interventions by participants and personnel during the study.
Criteria for a judgment of ‘Low risk’ of bias. | Any one of the following:; - No blinding or incomplete blinding, but the review authors judge that the outcome is not likely to be influenced by lack of blinding;; - Blinding of participants and key study personnel ensured, and unlikely that the blinding could have been broken.
Criteria for the judgment of ‘High risk’ of bias. | Any one of the following:; - No blinding or incomplete blinding, and the outcome is likely to be influenced by lack of blinding;; - Blinding of key study participants and personnel attempted, but likely that the blinding could have been broken, and the outcome is likely to be influenced by lack of blinding.
Criteria for the judgment of ‘Unclear risk’ of bias. | Any one of the following:; - Insufficient information to permit judgment of ‘Low risk’ or ‘High risk’;; - The study did not address this outcome.
BLINDING OF OUTCOME ASSESSMENT Detection bias due to knowledge of the allocated interventions by outcome assessors.
Criteria for a judgment of ‘Low risk’ of bias. | Any one of the following:; - No blinding of outcome assessment, but the review authors judge that the outcome measurement is not likely to be influenced by lack of blinding;; - Blinding of outcome assessment ensured, and unlikely that the blinding could have been broken.
Criteria for the judgment of ‘High risk’ of bias. | Any one of the following:; - No blinding of outcome assessment, and the outcome measurement is likely to be influenced by lack of blinding;; - Blinding of outcome assessment, but likely that the blinding could have been broken, and the outcome measurement is likely to be influenced by lack of blinding.
Criteria for the judgment of ‘Unclear risk’ of bias. | Any one of the following:; - Insufficient information to permit judgment of ‘Low risk’ or ‘High risk’;; - The study did not address this outcome.
INCOMPLETE OUTCOME DATA Attrition bias due to amount, nature or handling of incomplete outcome data.
Criteria for a judgment of ‘Low risk’ of bias. | Any one of the following:; - No missing outcome data;; - Reasons for missing outcome data unlikely to be related to true outcome (for survival data, censoring unlikely to be introducing bias);; - Missing outcome data balanced in numbers across intervention groups, with similar reasons for missing data across groups;; - For dichotomous outcome data, the proportion of missing outcomes compared with observed event risk not enough to have a clinically relevant impact on the intervention effect estimate;; - For continuous outcome data, plausible effect size (difference in means or standardized difference in means) among missing outcomes not enough to have a clinically relevant impact on observed effect size;; - Missing data have been imputed using appropriate methods.
Criteria for the judgment of ‘High risk’ of bias. | Any one of the following:; - Reason for missing outcome data likely to be related to true outcome, with either imbalance in numbers or reasons for missing data across intervention groups;; - For dichotomous outcome data, the proportion of missing outcomes compared with observed event risk enough to induce clinically relevant bias in intervention effect estimate;; - For continuous outcome data, plausible effect size (difference in means or standardized difference in means) among missing outcomes enough to induce clinically relevant bias in observed effect size;; - ‘As-treated’ analysis done with substantial departure of the intervention received from that assigned at randomization;; - Potentially inappropriate application of simple imputation.
Criteria for the judgment of ‘Unclear risk’ of bias. | Any one of the following:; - Insufficient reporting of attrition/exclusions to permit judgement of ‘Low risk’ or ‘High risk’ (e.g. number randomized not stated, no reasons for missing data provided);; - The study did not address this outcome.

[underlined: Thresholds for converting the Cochrane Risk of Bias tool to AHRQ standards (good, fair, and poor):]

Good quality: All criteria met (i.e. low for each domain)

Using the Cochrane ROB tool, it is possible for a criterion to be met even when the element was technically not part of the method. For instance, a judgment that knowledge of the allocated interventions was adequately prevented can be made even if the study was not blinded, if EPC team members judge that the outcome and the outcome measurement are not likely to be influenced by lack of blinding.

Fair quality: One criterion not met (i.e. high risk of bias for one domain) or two criteria unclear, and the assessment that this was unlikely to have biased the outcome, and there is no known important limitation that could invalidate the results

Poor quality: One criterion not met (i.e. high risk of bias for one domain) or two criteria unclear, and the assessment that this was likely to have biased the outcome, and there are important limitations that could invalidate the results

Poor quality: Two or more criteria listed as high or unclear risk of bias

Table 6 Quality ratings for randomized control trials

Citation | Quality Rating | Random Sequence Generation | Allocation Concealment | Selective Reporting | Other Sources of Bias | Blinding (Participants and Personnel) | Blinding (Outcome Assessment) | Incomplete Outcome Data
Abboud et al.,2 1995 | Poor | L | L | L | L | H | H | L
Abboud et al.,3 1989 | Poor | U | U | L | L | H | H | L
Abboud et al.,4 1981 | Poor | U | U | L | U | H | H | L
Arora et al.,5 1992 | Fair | L | L | L | U | L | L | L
Bergsjo and Lindbaek,6 1971 | Poor | L | L | L | U | U | U | L
Carstoniu et al.,7 1994 | Poor | L | H | L | L | H | H | L
Chia et al.,8 1990 | Poor | H | H | L | H | H | H | L
Constantine et al.,9 1989 | Poor | U | H | L | U | H | H | L
Einarsson et al.,10 1996 | Poor | U | U | L | U | U | U | L
Jones et al.,11 1969 | Poor | U | U | L | U | L | U | L
Jones et al.,12 1969 | Poor | U | U | L | U | U | U | L
McGuinness and Rosen,13 1984 | Poor | U | U | L | U | U | L | L
McLeod et al.,14 1985 | Poor | U | U | L | U | L | U | L
NA,15 1970 | Fair | U | L | L | L | L | L | L
Phillips and Macdonald,16 1971 | Poor | U | U | L | H | U | U | H
Rosen et al.,17 1972 | Poor | H | U | L | L | H | U | L
Talebi et al.,18 2009 | Poor | L | U | L | U | U | U | U
Westling et al.,19 1992 | Poor | H | H | L | U | H | H | L
Yeo et al.,20 2007 | Poor | U | H | H | U | H | H | L

H = high; L = low; U = unclear

Table 7 Quality ratings for cohort studies (including case series, cross-sectional, uncontrolled and nonrandomized trials)

Newcastle-Ottawa Quality Assessment Form for Cohort Studies

| | Selection (0-4 Stars) | | | | Comparability (n/a, 0-2 Stars) | Outcome (0-3 Stars)
Citation | Quality Rating | Representativeness of Exposed Cohort | Selection of Nonexposed | Ascertainment of Exposure | Outcome Not Present at Start of Study | Comparability of Cohorts | Assessment | Long Enough Followup | Adequacy of Followup
Ahlborg et al.,21 1996 | Fair | c)selected group | a)drawn from same community | c)written self report | a) yes | N/A | c)self report | a) yes | b)unlikely to introduce bias
Arfeen et al.,22 1994 | Poor | a)truly representative | a)drawn from same community | a)secure record | a) yes | no | b)record linkage | a) yes | b)unlikely to introduce bias
Arthurs et al.,23 1979 | Poor | d)no description | a)drawn from same community cohort | a)secure record | a) yes | no | c) self report | a) yes | a)complete follow up for
Axelsson et al.,24 1996 | Poor | c)selected group | a)drawn from same community | c)written self report | a) yes | N/A | c)self report | a) yes | b)unlikely to introduce bias
Beppu25 1968 | Poor | d) no description | c) no description | a)secure record | a) yes | NC | b) record linkage | a) yes | a)complete follow up
Bodin et al.,26 1999 | Poor | c)selected group | a)drawn from same community | c)written self report | a) yes | no | b)record linkage | a) yes | b)unlikely to introduce bias lost
Clark et al.,27 1967 | Fair | d) no description | c) no description | a)secure record | a) yes | no | b) record linkage | a) yes | a)complete follow up
Deckardt et al.,28 1987 | Poor | d)no description | a)drawn from same community | a)secure record | a) yes | no | b) record linkage | a) yes | a)complete follow up
Harrison et al.,29 1987 | Poor | b)somewhat representative | a)drawn from same community | a)secure record | a) yes | no | c) self report | a) yes | a)complete follow up
Harrison and Cullen30 1986 | Poor | b)somewhat representative | a) drawn from same community | a) secure record | a) yes | no | a)independent assessment | a) yes | a)complete follow up
Henderson et al.,31 2003 | Fair | a)truly representative | a)drawn from same community | a)secure record | b) no | N/A | a)independent assessment | a) yes | a)complete follow up
Henry and Nand,32 2004 | Poor | b)somewhat representative | a)drawn from same community | a)secure record | a) yes | no | c) self report | a) yes | b)unlikely to introduce bias
Holdcroft and Morgan,33 1974 | Poor | b)somewhat representative | a)drawn from same community | c)written self report | a) yes | no | c) self report | a) yes | b)unlikely to introduce bias
Landon et al.,34 1992 | Poor | a)truly representative | a)drawn from same community | a)secure record | a) yes | no | b) record linkage | a) yes | a)complete follow up
Leong et al.,35 2000 | Good | b)somewhat representative | a)drawn from same community | a)secure record | a) yes | both | c) self report | a) yes | b)unlikely to introduce bias
Marx et al.,36 1970 | Poor | c)selected group | a)drawn from same community | a)secure record | a) yes | NC | b) record linkage | a) yes | d) no statement
McAneny and Doughty,37 1963 | Poor | d) no description | a) drawn from same community | a)secure record | a) yes | no | a)independent blind assessment | a) yes | b)unlikely to introduce bias
Mills et al.,38 1996 | Fair | c)selected group | a) drawn from same community | a)secure record | a) yes | N/A | b) record linkage | a) yes | a)complete follow up
Morgan et al.,39 1982 | Poor | a)truly representative | a)drawn from same community | a)secure record | a) yes | no | c) self report | a) yes | a)complete follow up
Murphy et al.,40 1984 | Poor | a) truly representative | a) drawn from same community | a)secure record | a) yes | no | b) record linkage | a) yes | a)complete follow up
Newton et al.,41 1999 | Fair | c)selected group | a) drawn from same community | a)secure record | a) yes | N/A | b) record linkage | a) yes | b)unlikely to introduce bias
Peach,42 1999 | Fair | a)truly representative | a)drawn from same community | a)secure record | a) yes | N/A | c) self report | a) yes | b)unlikely to introduce bias lost
Ranta et al.,43 1995 | Fair | a) truly representative | a) drawn from same community | a)secure record | a) yes | N/A | c) self report | a) yes | b)unlikely to introduce bias
Ranta et al.,44 1994 | Poor | b)somewhat representative | a) drawn from same community | a)secure record | a) yes | no | c) self report | a) yes | b)unlikely to introduce bias
Reed et al.,45 1988 | Poor | b)somewhat representative | a)drawn from same community | a)secure record | a) yes | no | b) record linkage | a) yes | a)complete follow up
Rosen et al.,46 1969 | Poor | a)truly representative | a) drawn from same community | a)secure record | a) yes | no | c) self report | a) yes | b)unlikely to introduce bias -
Ross et al.,47 1999 | Poor | c)selected group | c)no description | a)secure record | a) yes | NC | b) record linkage | a) yes | b)unlikely to introduce bias
Smith et al.,48 1968 | Poor | a) truly representative | a) drawn from same community | a)secure record | a) yes | no | a)independent assessment | a) yes | b)unlikely to introduce bias
Soyannwo,49 1985 | Poor | d)no description | a)drawn from same community | a)secure record | a) yes | no | c) self report | a) yes | a)complete follow up
Stirk et al.,50 2002 | Poor | b)somewhat representative | a) drawn from same community | a)secure record | a) yes | no | b) record linkage | a) yes | a) complete follow up
Waldenstrom and Irestedt,51 2006 | Fair | a)truly representative | a)drawn from same community | c) written self report | a) yes | N/A | c) self report | a) yes | b)unlikely to introduce bias -
Waldenstrom,52 1999 | Fair | b)somewhat representative | a)drawn from same community | a) secure record | a) yes | N/A | c) self report | a) yes | b)unlikely to introduce bias -
Waldenstrom et al.,54 1996 | Fair | a) truly representative | a) drawn from same community | a)secure record | a) yes | N/A | c) self report | a) yes | b)unlikely to introduce bias
Westberg et al.,53 2008 | Fair | c)selected group | a) drawn from same community | a)secure record | a) yes | N/A | b) record linkage | a) yes | a)complete follow up
Zelcer et al.,55 1989 | Poor | d)no description | c)no description | a)secure record | a) yes | no | b) record linkage | a) yes | b)unlikely to introduce bias

[underlined: Thresholds for converting the Newcastle-Ottawa scales to AHRQ standards (good, fair, and poor):]

Good quality: 3 or 4 stars in selection domain AND 1 or 2 stars in comparability domain AND 2 or 3 stars in outcome/exposure domain

Fair quality: 2 stars in selection domain AND 1 or 2 stars in comparability domain AND 2 or 3 stars in outcome/exposure domain

Poor quality: 0 or 1 star in selection domain OR 0 stars in comparability domain OR 0 or 1 stars in outcome/exposure domain

The Vanderbilt EPC included two additional options in the comparability domain not generally included in the Newcastle-Ottawa scales: “no comparison group” and “not applicable”. This was necessary because the review included single-arm studies for both the effectiveness and harms assessments.

Studies of the effectiveness of nitrous oxide for the management of labor pain that included only one study arm were marked as “no comparison group”, which equates to receiving no stars and an automatic rating of poor quality.

Cross sectional studies used to identify potential harms and measures of environmental exposure could appropriately have no comparison group, and were marked for comparability as “not applicable.” The quality scores for these studies were downgraded to account for their noncomparative study designs. For example, a study with three or four stars in the selection domain and two or three stars in the outcome/exposure domain, which would normally equate to a “good” quality rating, would be deemed “fair” quality if the comparability domain response was “not applicable”.

Table 8 Quality ratings for case-control studies

Newcastle-Ottawa Quality Assessment Form for Case-control Studies

| | Selection (0-4 Stars) | | | | Comparability (n/a, 0-2 Stars) | Outcome (0-3 Stars)
Citation | Quality Rating | Adequate Case Definition | Representativeness of Cases | Selection of Controls | Definition of Controls | Comparability of Cases and controls | Ascertainment of Exposure | Same Method of Ascertainment | Nonresponse rate
Jacobson et al.,56 1990 | Poor | b) yes, e.g., record linkage or based on self report | b) potential for selection biases or not stated | a)community | a) no history of disease (endpoint) | no | a) secure record | a) yes | a) same
Jacobson et al.,57 1988 | Poor | b) yes, e.g., record linkage or based on self report | b) potential for selection biases or not stated | a)community | a) no history of disease (endpoint) | no | a)secure record ( | a) yes | a) same
Nyberg et al.,58 1992 | Poor | b) yes, e.g., record linkage or based on self report | a) consecutive or obviously representative series of cases | a)community | a) no history of disease (endpoint) | no | a) secure record | a) yes | a) same
Zack et al.,59 1991 | Good | b) yes, e.g., record linkage or based on self report | a) consecutive or obviously representative series of cases | a)community | a) no history of disease (endpoint) | other | a) secure record | a) yes | a) same

[underlined: Thresholds for converting the Newcastle-Ottawa scales to AHRQ standards (good, fair, and poor):]

Good quality: 3 or 4 stars in selection domain AND 1 or 2 stars in comparability domain AND 2 or 3 stars in outcome/exposure domain

Fair quality: 2 stars in selection domain AND 1 or 2 stars in comparability domain AND 2 or 3 stars in outcome/exposure domain

Poor quality: 0 or 1 star in selection domain OR 0 stars in comparability domain OR 0 or 1 stars in outcome/exposure domain

The Vanderbilt EPC included two additional options in the comparability domain not generally included in the Newcastle-Ottawa scales: “no comparison group” and “not applicable”. This was necessary because the review included single-arm studies for both the effectiveness and harms assessments.

Studies of the effectiveness of nitrous oxide for the management of labor pain that included only one study arm were marked as “no comparison group”, which equates to receiving no stars and an automatic rating of poor quality.

Cross sectional studies used to identify potential harms and measures of environmental exposure could appropriately have no comparison group, and were marked for comparability as “not applicable.” The quality scores for these studies were downgraded to account for their noncomparative study designs. For example, a study with three or four stars in the selection domain and two or three stars in the outcome/exposure domain, which would normally equate to a “good” quality rating, would be deemed “fair” quality if the comparability domain response was “not applicable”.

1 Martin JA, Hamilton BE, Sutton PD, et al. Births: Final Data for 2008. National Vital Statistics Reports. Released. December. 8. 2010;59(1):1-72. [pmid: 22145497].
2 Abboud TK, Swart F, Zhu J, et al. Desflurane analgesia for vaginal delivery. Acta Anaesthesiol Scand. Feb. 1995;39(2):259-61. [pmid: 7793195].
3 Abboud TK, Gangolly J, Mosaad P, et al. Isoflurane in obstetrics. Anesth Analg. Mar. 1989;68(3):388-91. [pmid: 2919779].
4 Abboud TK, Shnider SM, Wright RG, et al. Enflurane analgesia in obstetrics. Anesth Analg. Mar. 1981;60(3):133-7. [pmid: 7193989].
5 Arora S, Tunstall M, Ross J. Self-administered mixture of Entonox and isoflurane in labour. Int J Obstet Anesth. Sep. 1992;1(4):199-202. [pmid: 15636826].
6 Bergsjo P, Lindbaek E. Comparison between nitrous oxide and methoxyflurane for obstetrical analgesia. Acta Obstet Gynecol Scand. 1971;50(3):285-90. [pmid: 4942713].
7 Carstoniu J, Levytam S, Norman P, et al. Nitrous oxide in early labor. Safety and analgesic efficacy assessed by a double-blind, placebo-controlled study. Anesthesiology. Jan. 1994;80(1):30-5. [pmid: 8291726].
8 Chia YT, Arulkumaran S, Chua S, et al. Effectiveness of transcutaneous electric nerve stimulator for pain relief in labour. Asia Oceania J Obstet Gynaecol. Jun. 1990;16(2):145-51. [pmid: 2378593].
9 Constantine G, Luesley DM, O'Connor A, et al. The use of Entonox in conjunction with a rebreathing humidifier. J Obstet Gynaecol. 1989;10(1):23-25.
10 Einarsson S, Stenqvist O, Bengtsson A, et al. Gas kinetics during nitrous oxide analgesia for labour. Anaesthesia. May. 1996;51(5):449-52. [pmid: 8694158].
11 Jones PL, Rosen M, Mushin WW, et al. Methoxyflurane and nitrous oxide as obstetric analgesics. I. A comparison by continuous administration. Br Med J. Aug. 2. 1969;3(5665):255-9. [pmid: 4895338].
12 Jones PL, Rosen M, Mushin WW, et al. Methoxyflurane and nitrous oxide as obstetric analgesics. II. A comparison by self-administered intermittent inhalation. Br Med J. Aug. 2. 1969;3(5665):259-62. [pmid: 4895339].
13 McGuinness C, Rosen M. Enflurane as an analgesic in labour. Anaesthesia. Jan. 1984;39(1):24-6. [pmid: 6696214].
14 McLeod DD, Ramayya GP, Tunstall ME. Self-administered isoflurane in labour. A comparative study with Entonox. Anaesthesia. May. 1985;40(5):424-6. [pmid: 4014617].
15 Clinical trials of different concentrations of oxygen and nitrous oxide for obstetric analgesia. Report to the Medical Research Council of the Committee on Nitrous Oxide and Oxygen Analgesia in Midwifery. Br Med J. Mar. 21. 1970;1(5698):709-13. [pmid: 5440545].
16 Phillips TJ, Macdonald RR. Comparative effect of pethidine, trichloroethylene, and Entonox on fetal and neonatal acid-base and PO2. Br Med J. Sep. 4. 1971;3(5774):558-60. [pmid: 5571451].
17 Rosen M, Latto P, Asscher AW. Kidney function after methoxyflurane analgesia during labour. Br Med J. Jan. 8. 1972;1(5792):81-3. [pmid: 5007074].
18 Talebi H, Nourozi A, Jamilian M, et al. Entonox for labor pain: a randomized placebo controlled trial. Pak J Biol Sci. Sep. 1. 2009;12(17):1217-21. [pmid: 19943458].
19 Westling F, Milsom I, Zetterstrom H, et al. Effects of nitrous oxide/oxygen inhalation on the maternal circulation during vaginal delivery. Acta Anaesthesiol Scand. Feb. 1992;36(2):175-81. [pmid: 1549939].
20 Yeo ST, Holdcroft A, Yentis SM, et al. Analgesia with sevoflurane during labour: ii. Sevoflurane compared with Entonox for labour analgesia. Br J Anaesth. Jan. 2007;98(1):110-5. [pmid: 17158129].
21 Ahlborg G Jr., Axelsson G, Bodin L. Shift work, nitrous oxide exposure and subfertility among Swedish midwives. Int J Epidemiol. Aug. 1996;25(4):783-90. [pmid: 8921457].
22 Arfeen Z, Armstrong PJ, Whitfield A. The effects of Entonox and epidural analgesia on arterial oxygen saturation of women in labour. Anaesthesia. Jan. 1994;49(1):32-4. [pmid: 8311209].
23 Arthurs GJ, Rosen M. Self-administered intermittent nitrous oxide analgesia for labour. Enhancement of effect with continuous nasal inhalation of 50 per cent nitrous oxide (Entonox). Anaesthesia. Apr. 1979;34(4):301-9. [pmid: 378022].
24 Axelsson G, Ahlborg G Jr., Bodin L. Shift work, nitrous oxide exposure, and spontaneous abortion among Swedish midwives. Occup Environ Med. Jun. 1996;53(6):374-8. [pmid: 8758031].
25 Beppu K. Transmission of the anesthetic agents through the placenta in painless delivery and their effects on newborn infants. Keio J Med. Jun. 1968;17(2):81-107. [pmid: 5727834].
26 Bodin L, Axelsson G, Ahlborg G Jr. The association of shift work and nitrous oxide exposure in pregnancy with birth weight and gestational age. Epidemiology. Jul. 1999;10(4):429-36. [pmid: 10401879].
27 Clark RB, Cooper JO, Brown WE, et al. An evaluation of methoxyflurane analgesia and anesthesia for obstetrics. South Med J. Jul. 1968;61(7):687-91. [pmid: 5664516].
28 Deckardt R, Fembacher PM, Schneider KT, et al. Maternal arterial oxygen saturation during labor and delivery: pain-dependent alterations and effects on the newborn. Obstet Gynecol. Jul. 1987;70(1):21-5. [pmid: 3601266].
29 Harrison RF, Shore M, Woods T, et al. A comparative study of transcutaneous electrical nerve stimulation (TENS), entonox, pethidine + promazine and lumbar epidural for pain relief in labor. Acta Obstet Gynecol Scand. 1987;66(1):9-14. [pmid: 3300138].
30 Harrison RF, Cullen R. A comparative study of the behaviour of the neonate following various forms of maternal intrapartum analgesia and anaesthesia. Ir J Med Sci. 1986;155(1):12-18. [pmid: 3700061].
31 Henderson KA, Matthews IP, Adisesh A, et al. Occupational exposure of midwives to nitrous oxide on delivery suites. Occup Environ Med. Dec. 2003;60(12):958-61. [pmid: 14634189].
32 Henry A, Nand SL. Intrapartum pain management at the Royal Hospital for Women. Aust N Z J Obstet Gynaecol. Aug. 2004;44(4):307-13. [pmid: 15282001].
33 Holdcroft A, Morgan M. An assessment of the analgesic effect in labour of pethidine and 50 per cent nitrous oxide in oxygen (Entonox). J Obstet Gynaecol Br Commonw. Aug. 1974;81(8):603-7. [pmid: 4424256].
34 Landon MJ, Creagh-Barry P, McArthur S, et al. Influence of vitamin B12 status on the inactivation of methionine synthase by nitrous oxide. Br J Anaesth. Jul. 1992;69(1):81-6. [pmid: 1637609].
35 Leong EW, Sivanesaratnam V, Oh LL, et al. Epidural analgesia in primigravidae in spontaneous labour at term: a prospective study. J Obstet Gynaecol Res. Aug. 2000;26(4):271-5. [pmid: 11049237].
36 Marx GF, Joshi CW, Orkin LR. Placental transmission of nitrous oxide. Anesthesiology. May. 1970;32(5):429-32. [pmid: 5445031].
37 McAneny T, Doughty A. Self-administered nitrous-oxide/oxygen analgesia in obstetrics. Anaesthesia. 1963. 1963;18(4):488-497. [pmid: 14071377].
38 Mills GH, Singh D, Longan M, et al. Nitrous oxide exposure on the labour ward. Int J Obstet Anesth. Jul. 1996;5(3):160-4. [pmid: 15321342].
39 Morgan B, Bulpitt CJ, Clifton P, et al. Effectiveness of pain relief in labour: survey of 1000 mothers. Br Med J (Clin Res Ed). Sep. 11. 1982;285(6343):689-90.
40 Murphy JF, Dauncey M, Rees GAD. Obstetric analgesia, anaesthesia and the Apgar score. Anaesthesia. 1984;39(8):760-763. [pmid: 6476311].
41 Newton C, Fitz-Henry J, Bogod D. The occupational exposure of midwives to nitrous oxide - a comparison between two labour suites. Int J Obstet Anesth. Jan. 1999;8(1):7-10. [pmid: 15321169].
42 Paech MJ. The King Edward Memorial Hospital 1,000 mother survey of methods of pain relief in labour. Anaesth Intensive Care. Aug. 1991;19(3):393-9. [pmid: 1767909].
43 Ranta P, Spalding M, Kangas-Saarela T, et al. Maternal expectations and experiences of labour pain - options of 1091 Finnish parturients. Acta Anaesthesiol Scand. 1995;39(1):60-66. [pmid: 7725885].
44 Ranta P, Jouppila P, Spalding M, et al. Parturients' assessment of water blocks, pethidine, nitrous oxide, paracervical and epidural blocks in labour. Int J Obstet Anesth. 1994;3(4):193-198. [pmid: 15636949].
45 Reed PN, Colquhoun AD, Hanning CD. Maternal oxygenation during normal labour. Br J Anaesth. Mar. 1989;62(3):316-8. [pmid: 2930673].
46 Rosen M, Mushin WW, Jones PL, et al. Field trial of methoxyflurane, nitrous oxide, and trichloroethylene as obstetric analgesics. Br Med J. Aug. 2. 1969;3(5665):263-7. [pmid: 4895340].
47 Ross JA, Tunstall ME, Campbell DM, et al. The use of 0.25% isoflurane premixed in 50% nitrous oxide and oxygen for pain relief in labour. Anaesthesia. Dec. 1999;54(12):1166-72. [pmid: 10594414].
48 Smith BE, Moya F. Inhalational analgesia with methoxyflurane for vaginal delivery. South Med J. Apr. 1968;61(4):386-90. [pmid: 5644074].
49 Soyannwo OA. Self-administered Entonox (50% nitrous oxide in oxygen) in labour: report of the experience in Ibadan. Afr J Med Med Sci. Mar-Jun. 1985;14(1-2):95-8. [pmid: 2994447].
50 Stirk P, Staines J, Brown DW. Maternal diamorphine administration during labour: the effect on neonate admissions to NNU. J Neonatal Nurs. 2002;8(2):56-7.
51 Waldenstrom U, Irestedt L. Obstetric pain relief and its association with remembrance of labor pain at two months and one year after birth. J Psychosom Obstet Gynaecol. Sep. 2006;27(3):147-56. [pmid: 17214449].
52 Waldenstrom U. Experience of labor and birth in 1111 women. J Psychosom Res. Nov. 1999;47(5):471-82. [pmid: 10624845].
53 Westberg H, Egelrud L, Ohlson CG, et al. Exposure to nitrous oxide in delivery suites at six Swedish hospitals. Int Arch Occup Environ Health. 2008;81(7):829-836. [pmid: 17952690].
54 Waldenstrom U, Bergman V, Vasell G. The complexity of labor pain: Experiences of 278 women. J Psychosom Obstet Gynaecol. 1996;17(4):215-228. [pmid: 8997688].
55 Zelcer J, Owers H, Paull JD. A controlled oximetric evaluation of inhalational, opioid and epidural analgesia in labour. Anaesth Intensive Care. Nov. 1989;17(4):418-21. [pmid: 2596676].
56 Jacobson B, Nyberg K, Gronbladh L, et al. Opiate addiction in adult offspring through possible imprinting after obstetric treatment. BMJ. Nov. 10. 1990;301(6760):1067-70. [pmid: 2249068].
57 Jacobson B, Nyberg K, Eklund G, et al. Obstetric pain medication and eventual adult amphetamine addiction in offspring. Acta Obstet Gynecol Scand. 1988;67(8):677-82. [pmid: 3250180].
58 Nyberg K, Allebeck P, Eklund G, et al. Socio-economic versus obstetric risk factors for drug addiction in offspring. Br J Addict. Dec. 1992;87(12):1669-76. [pmid: 1490081].
59 Zack M, Adami HO, Ericson A. Maternal and perinatal risk factors for childhood leukemia. Cancer Res. Jul. 15. 1991;51(14):3696-701. [pmid: 2065325].