# Evidence Tables

Tables are sorted by last name of first author.

Evidence Table 1 Nitrous oxide for management of labor pain