# Sample Data Abstraction Forms

Abstract Review Form

Full-text Review Form